# Introduction

This is a comparative effectiveness review of alternative radiation therapy (RT) modalities in the treatment of head and neck cancer including: conventional or two-dimensional (2DRT), three-dimensional conformal (3DCRT), intensity-modulated (IMRT), and proton beam radiotherapy. Key questions that will be addressed are whether any of these modalities is more effective than the others: (1) in reducing normal tissue toxicity and adverse events, and improving quality of life; (2) in improving local tumor control, time to disease progression, and survival; (3) when used in certain anatomic locations or patient subpopulations; and, finally, (4) whether there is more variation in patient outcomes with any modality secondary to user experience, treatment planning, or target volumes.

## Background

### Burden of Illness

Head and neck cancers, specifically those arising in the oral cavity, larynx, hypopharynx, oropharynx, nasopharynx, paranasal sinuses/nasal cavity, salivary glands and occult primaries, account for approximately 3 to 5 percent of cancers in the U.S. According to the National Comprehensive Cancer Network, it was estimated that 47,560 new cases would occur in 2008, with an estimated 11,260 deaths.1

Major risk factors for the development of head and neck cancer include tobacco and alcohol abuse, with other less-common risk factors including occupational exposures, nutritional deficiencies, and poororal health. 1 Viral etiologies have also been established, with human papillomavirus infection appearing to be a risk factor, particularly within the oropharynx, in younger people without a history of tobacco or alcohol abuse. In addition, an association has been made between Epstein-Barr virus and nasopharyngeal cancer.

### Classification and Staging

The majority of head and neck cancers arise from a noninvasive precursor in surface squamous epithelium, progressing to a squamous carcinoma. Other less-common tumors arise from other structures, including the major and minor salivary glands, and give rise to a variety of other tumor types, like adenocarcinomas.

The staging of head and neck cancer varies slightly by anatomic site, but in general, early stage (stage I and II), which comprises approximately 40 percent of cases, defines a small primary tumor without lymph node involvement.1 Locally advanced tumors (stage III and IV) include large primary tumors, which may invade adjacent structures and/or spread to regional lymph nodes, and represent approximately 60 percent of cases.1 Metastatic disease is uncommon at the time of diagnosis of a head and neck cancer, with the exception of certain subsites (e.g., nasopharynx, hypopharynx, advanced neck disease).

### Clinical Management

The management of head and neck cancer is complex, and usually involves a multidisciplinary team. In general, the approach to managing this type of cancer is dictated by the disease site and extent, as well as by the histologic type and grade of tumor. Early stage disease may be treated by a single-modality (surgery or radiation), whereas patients with locally advanced disease are generally treated with combined modalities,1 and depending upon the extent of disease spread, a cervical lymph node dissection may be performed.

Nearly all patients with locally advanced head and neck cancer receive chemotherapy in addition to radiation as a part of initial curative treatment.2 The integration of chemotherapy into the treatment of head and neck cancer has resulted in improvements in overall survival and local-regional control, reduced the incidence of distant metastases, and has provided more opportunity for organ preservation in certain settings.2

### Radiation Therapy

The main challenge in radiation therapy for cancer is to attain the highest probability of tumor control or cure with the least amount of morbidity and toxicity to normal surrounding tissues (sometimes referred to as organs at risk).

Two-Dimensional and Three-Dimensional Conformal Radiation Therapy. Modern advances in computers have led to parallel advances in imaging technologies, allowing for higher levels of complexity in radiotherapy treatment planning systems.3 Radiation therapy designs have evolved over the past 20 years from being based on two-dimensional (2D) to three-dimensional (3D) images, incorporating increasingly complex computer algorithms.

2DRT consists of a single beam from one to four directions with the radiation fields designed on 2D fluoroscopic simulation images, whereas 3D conformal radiotherapy (CRT) employs computed tomography (CT) simulation.4 Three -dimensional radiotherapy represented a major advance over 2D, allowing for more accurate dose calculations by taking into account axial anatomy and complex tissue contours.

IMRT. IMRT, which has been implemented over the last decade, has further refined radiation dose delivery. IMRT allows for the modulation of both the number of fields and the intensity of radiation within each field, allowing for greater control of the dose distribution to the target.3 Potential benefits include the ability to deliver higher doses to the tumor, while sparing normal, surrounding tissues, thereby decreasing toxicity. Reducing the radiation dose to normal structures offers potential benefits which include sparing of salivary gland tissue to reduce the severity of xerostomia (dryness of the mouth due to decreased salivary function), and reducing the dose to structures related to swallowing (e.g., pharyngeal constrictor muscles and the larynx).5

There are several disadvantages to IMRT. Patients receive a higher total body dose of radiation, there is decreased dose homogeneity, and increased risk of a marginal miss (in which case, the eradication of the tumor may be unsuccessful).5 Compared to mo re conventional radiotherapy techniques, IMRT is more expensive and time consuming. Difficulties have arisen in set-up reproducibility and patient immobilization, and it has been shown that variations in daily patient positioning and changes in patient anatomy (e.g., weight loss, tumor shrinkage) may result in significant dose perturbations compared with the original treatment plan.6 Finally, there has been concern about variations in prescribed doses versus what is actually delivered to the patient, and variations between medical institutions has raised concerns about the validity of comparing clinical outcomes for IMRT.

Radiation Treatment Planning. Both 2D and 3DCRT use forward planning to create radiation dose distributions, in which the radiation treatment fields are designated by a physician and a physicist then defines the number, direction, and shapes of the radiation beams. The treatment plan dose distribution shows how much dose is delivered to the tumor and normal structures.4

IMRT uses CT simulation images like 3DCRT; however, inverse planning is used to outline target volumes. Inverse planning requires the treatment planner to input the desired radiation dose to the tumor and the constraints for normal surrounding structures. Then, computer software is used to arrive at the radiation beam characteristics most likely to meet the requirements designated at the start of treatment planning.4 Although repeat treatment planning may be chosen during the course of treatment, it is not typically performed.

In order to standardize image-based tumor volume definitions for three-dimensional radiation planning, the Internal Commission of Radiation Units and Measurements created terminology for use across institutions.7 Definitions include gross tumor volume (GTV), clinical target volume (CTV) and planning target volume (PTV). The GTV pertains to gross disease identified by clinical workup (e.g., physical exam and imaging), CTV includes the GTV and any areas at risk for microscopic disease, and PTV is an expansion of the CTV by a margin (usually 3–5 mm in the head and neck patient) to account for patient/organ motion and day-to-day setup variation.4

Photons, Electrons, and Protons. The main form of treatment of deep tumors is with photons (as is used in 2D, 3D, and IMRT). Photons spare the skin and deposit dose along their entire path until the beam leaves the body.8 As each beam continues on its path beyond the tumor, the use of multiple beams means that a significant volume of normal tissue receives a low dose.8

Electrons are the most widely used forms of radiation for superficial tumors, and because the depth of penetration can be well controlled by the energy of the beam, it is possible to spare underlying normal structures.8

Although proton beam therapy has been used to treat tumors for more than 50 years, it has been used mostly in the treatment of prostate cancer, as well as brain tumors, including those in children.8 Charged particle beams like proton, differ from photons in that they interact only modestly with tissue until they reach the end of their path, where they deposit the majority of their energy and stop.8 The ability to stop at a chosen depth offers the potential advantage of treating tumors close to critical structures, and with the potential to decrease regions of low dose, decreasing the chance of second malignancies. In the two-and three -dimensional era, proton therapy could deliver higher doses to the target than photon therapy because protons produce a more rapid falloff of dose between the target and normal tissues.8 In the modern IMRT era, it is difficult to determine whether protons will allow a higher dose to be delivered to the target.8 Another major issue is that proton beam facilities are substantially more expensive than a similar-sized photon facility.8 The exact role of intensity -modulated proton therapy in the treatment of head and neck cancer is not well defined.

### Adverse Effects of Radiation Therapy in Head and Neck Cancer

Radiation is associated with early and late toxicities, which can have a profound effect on a patient’s quality of life, and chemoradiation may be associated with enhancement of these toxicities (particularly mucositis and xerostomia). Additionally, confounding factors may make it difficult to attribute all of the symptoms of an adverse event to treatment effect. For example, there are several other causes of xerostomia which include diseases that affect the salivary glands, numerous medications and various others, that may be present in the population with head and neck cancer.

Therapy-related toxicities are particularly relevant in the treatment of head and neck cancer because of the close proximity of many important dose-limiting normal tissues. Treatment effects can impact basic functions like chewing, swallowing, and breathing; the senses (e.g., taste, smell and hearing), and significantly alter appearance and voice.

Traditionally, acute and late toxic effects are defined as occurring before and after 90 days, respectively. In an attempt to standardize the reporting of therapy-related acute and late toxicities, several grading instruments have been created, including the National Cancer Institute’s Common Toxicity Criteria (NCI CTC) and the Radiation Therapy Oncology Group/European Organization for Research and Treatment of Cancer (RTOG/EORTC) grading system. Other tools include the Subjective, Objective, Management, Analytic (SOMA) system, subjective and objective questionnaires, including some that are tailored specifically for the head and neck (e.g., EORTC QLQ-H&N35) and visual analog scales (VAS).

## Key Questions for this Comparative Effectiveness Review

This comparative effectiveness review addresses four key questions regarding the use of alternative radiotherapy modalities in the treatment of head and neck cancer. The radiotherapy modalities to be compared are intensity-modulated radiation therapy (IMRT), three-dimensional conformal radiation therapy (3DCRT), two-dimensional radiation therapy (2DRT), and proton beam therapy.

1. What is the comparative effectiveness of IMRT, 3DCRT, 2DRT, and proton beam therapy regarding adverse events and quality of life?
2. What is the comparative effectiveness of IMRT, 3DCRT, 2DRT, and proton beam therapy regarding tumor control and patient survival?
3. Are there differences in comparative effectiveness of IMRT, 3DCRT, 2DRT and proton beam therapy for specific patient and tumor characteristics?
4. Is there variation in comparative effectiveness of IMRT, 3DCRT, 2DRT and proton beam therapy because of differences in user experience, target volume delineation, or dosimetric parameters?