# Single-Arm Studies

## Questions 1–3: Toxicity, Efficacy and Differences in Comparative Effects of IMRT, 3DCRT, PBT and 2DRT

Table E-A Design, participant selection and enrollment

Study | Design | Participant Selection (Treatment Period) | Therapeutic Setting | n, Enrolled | n, Evaluated | n, Withdrawn (Lost to F/U)
560, Biagioli et al., 2007 | Retrospective | Histologically proven locoregionally recurrent or second primary HNC with no distant metastases (01/2001–11/2006) | Definitive or salvage IMRT plus CTx Cisplatin or carboplatin with or w/out docetaxel or 5- FU, induction or concurrent | 62 | 41 Ctx 54 21 excluded (n = 4 treated 2x daily; n = 2 no records available; n = 15 treated w/non- IMRT method) | 1 Died during tx 7 did not complete prescribed RT course
580, Dirix et al., 2007 | Prospective | Histologically proven AJCC stage T2-T4 primary sinonasal malignancy (01/2003–03/2007) | Adjuvant IMRT | 43 | 25 18 excluded for recurrence (n = 3); melanoma or sarcoma (n = 7); too short F/U (n = 8) | 0
1010, Urbano et al., 2007 | Prospective dose- escalation | Histologically proven locally advanced stage T2–4, N1–3, M0 laryngeal or hypopharyngeal SCC (02/2002) | Definitive IMRT plus CTx Neoadjuvant cisplatin and 5-FU plus concurrent cisplatin during IMRT | 30 (15 per dose cohort) | 30 Neoadjuvant CTx 15 DL1 13 DL2 Concurrent CTx 15 DL1 14 DL2 | 0
1420, Feng et al, 2007 | Prospective | Stage III/IV oropharyngeal or nasopharyngeal cancer | Definitive IMRT plus CTx Concurrent carboplatin and taxane (oropharynx) or cisplatin (nasopharynx) | 36 | 36 CTx 36 | 0
1430, Scrimger et al., 2007 | Prospective | Histologically proven AJCC stage I-IV SCC at various head and sites (07/2000–12/2004) | Definitive or adjuvant IMRT with or w/out concurrent CTx Usually platinum- based CTx | 64 | 47 CTx 12 | 17 incomplete salivary flow data or lost to F/U
1500, Lee et al., 2007 | Retrospective | Histologically proven AJCC stage III–IV laryngeal and hypopharyngeal SCC (01/2002–06/2005) | Definitive IMRT plus CTx Concurrent cisplatin alone, carboplatin plus 5-FU, or carboplatin plus paclitaxel | 37 | 31 CTx 37 | 6 2 had early-stage disease 3 had postoperative IMRT 1 refused CTx
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | Retrospective | Histologically proven AJCC stage T0–4, N2–3 SCC at various head and neck sites (12/1999–07/2005) | Definitive IMRT alone or plus CTx Concurrent or induction cisplatin Neck dissection in 13 pts | 100 | 90 CTx 74 | 10 4 with NPH carcinoma 5 with pre-RT neck dissection, 1 lost to F/U
1780, Lee et al., 2007 | Retrospective | Histologically proven recurrent cancer of the head and neck (07/1996–09/2005) | Definitive or adjuvant IMRT with or w/out CTx Induction, concurrent, or adjuvant mostly platinum-based regimens | 155 | 105 CTx 45 | 5 did not complete prescribed RT 6 lost to F/U
1900, Ben- David et al., 2007 | Retrospective | Histologically proven AJCC stage I–IVB or recurrent head and neck cancer at various sites (03/1996–03/2005) | Definitive or adjuvant IMRT, with or w/out CTx Concurrent cisplatin, carboplatin or carboplatin plus paclitaxel | 188 | 176 CTx 108 | 12 5 lost to F/U at < 6 mos 2 died of pneumonia or trauma 2 died of lung metastases 3 did not complete RT course
1990, Yao et al., 2007 | Retrospective | Histologically proven AJCC stage I–IV SCC of the oral cavity (05/2001–07/2005) | Definitive or adjuvant IMRT, with or w/out CTx Concurrent, adjuvant, or neoadjuvant cisplatin | 55 CTx 6 | 55 | 0
2180, Daly et al., 2007 | Retrospective | Histologically proven AJCC stage Tis-T4 malignancies of the nasal cavity and paranasal sinuses (04/1998–12/2004) | Definitive or adjuvant IMRT, with or w/out CTx CTx not described | 45 CTx 8 | 36 | 9 3 excluded received boost IMRT after CRT 3 treated for recurrent disease 3 had inadequate F/U
2290, Yao et al., 2006 | Retrospective | Histologically proven AJCC stage I–IV oropharyngeal SCC (01/2000–07/2004) | Definitive or adjuvant IMRT, with or w/out CTx Cisplatin alone or with 5-FU | 69 | 66 Ctx 46 | 3 2 presented with metastatic disease 1 lost to F/U after 6 mos. of tx
2370, Garden et al., 2007 | Retrospective | Histologically proven AJCC stage T1-x primary SCC of the oropharynx (10/2000–06/2002) | Definitive or adjuvant IMRT, with or w/out CTx CTx not described | 54 | 51 CTx 5 | 3 1 received IMRT to boost field only 1 received boost with CRT 1 switched from IMRT to CRT
2430, Vosmik et al., 2006 | Prospective | Histologically proven stage I–IV (staging system not identified) carcinoma of the head and neck region with regional nodal involvement (12/2003–09/2005) | Definitive or adjuvant IMRT, with or w/out concurrent CTx Cisplatin | 41 | 38 CTx 5 | 3 RT terminated early due to toxicity and inability to continue
2770, Cheng et al., 2006 | Prospective | Histologically proven AJCC stage T1–4, N0–3b, M0 primary NPC with regional nodal involvement (04/1990–12/2002) | Definitive 3DCRT with or w/out CTx Concurrent cisplatin plus 5-FU | 719 CTX 586 | 630 | 89 48 presented with metastatic disease 9 did not receive full RT dose 32 had no MRI data for F/U analysis
3080, Meirovitz 2006 | Prospective cross- sectional | Pts with H & N cancer txd with IMRT at a single institution (11/2001–10/2003) | IMRT Adjuvant or definitive Concurrent CTx | 38 Definitive 20 (15 also rec’d concurrent CT) Post op RT 18 (1 rec’d concurrent CT) | 38 | 0
3220, Portaluri et al., 2006 | Prospective | Histologically proven locally advanced AJCC staged, previously untreated SCC of the head and neck (2001–2003) | Definitive or adjuvant 3DCRT with or w/out CTx Cisplatin alone or plus 5-FU | 49 | 49 CTx 13 | 0
3340, Studer 2006 | CS with historical controls (3DCRT) | Consecutive patients with HYP cancer (01/2002-07/2005) | SIB IMRT Adjuvant or definitive Concurrent CTx | 29 definitive 25 adjuvant 4 CTx cisplatin-based 25 | 29 | 0
3400, Studer 2006 | CS with historic controls (IMRT v 3DCRT) | OPH or oral cancer | IMRT with simultaneously integrated boost (SIB) Adjuvant or definitive Concurrent CTx | 123 21 adjuvant 52 definitive CTx cisplatin-based 56 | 73 73 considered “at risk” for ORN (defined as receiving >60Gy for primary OPH or oral cancer) OPH (n=55) Oral cancer (n=18) | 0
3570, Saarilahti2006 | Cohort | Cohort with stage 2 or higher primary squamous ca H & N and at least one parotid gland spared from PTV. (07/2000-04/2004) | IMRT Adjuvant or definitive Concurrent CTx | 36 Definitive 16 Adjuvant20 CTx16 | 36 (evaluated as whether or not the contralateral submandibular gland was spared [n=18] or not [n=18]). | 0
3790, Ozsahin et al., 2006 | Retrospective | Histologically proven IUAC locally advanced cancer of the head and neck with regional nodal involvement (11/2000-01/2003) | Definitive or adjuvant 3DCRT with or w/out CTx Concurrent cisplatin plus 5-FU | 33 | 33 CTx 26 | 0
3820, McMillan 2006 | Prospective, longitudinal | Histologically confirmed NPC Stage 1 and 2 | IMRT with parotid sparing | 32 | 32 | 0
4290, Lau et al., 2006 | Retrospective | Histologically proven AJCC stage I–IV primary, non-nasopharyngeal SCC of the head and neck (09/2000-12/2002) | Definitive or adjuvant 3DCRT with or w/out CTx Concurrent cisplatin | 57 | 56 CTX 57 | 1 Died with MI 1 wk after CRT
4430, Kwong 2006 | CS | Histologically proven NPC, locally advanced (skull base involvement or intracranial extension by CT scan). No evidence distant mets. (09/2000-06/2004) | IMRT with dose escalation. Concurrent, adjuvant or induction CTx | 50 CTx cisplatin plus 5-FU 34 | 50 | 0
4630, Yao | CS | H & N squamous ca txd at one institution (U of Iowa) (10/1999-04/2004). | IMRT Concurrent or induction CTx | 151 Definitive n=99 Post op n=51 Concurrent or induction cisplatin-based CTx 68 | 150 | 1 (lost to f/u p 2 mos.)
5020, Nishimura et al., 2005 | Retrospective cohort study assessing Xerostomia incidence after IMRT w/boost | 33 patients with pharyngeal cancer (32 SCC, 1 Non-Hodgkin lymphoma) treated w/whole neck IMRT Stage II, III, IV | Definitive, Postoperative RT Definitive RT, Postop RT 45, 55 Concurrent Chemotherapy: Cisplatin, Docetaxel, None 30, 39, 30 | 33 | 33 | 0
5120, Wolden et al., 2006 | Retrospective 2-arm 3DCRT vs. IMRT | Histologically proven stage I–IV NPC (AJCC) T1-T4/N0-N3, without prior treatment or distant metastasis (07/1998-11/2004) | Definitive RT | 109 | 109 (3DCRT: 35, IMRT: 74) | 6 1 refusal T3N0 5 not receiving chemotherapy due to stage I
5210, Duthoy et al., 2005 | Prospective cohort comparing postoperative IMRT to historic 3DCRT control | Patients treated w/postoperative IMRT for adenocarcinoma or SCC of the paranasal sinuses or nasal cavity. T2, T3, T4a, T4b | Postoperative RT | 39 | 39 | 2
5310, Zheng et al., 2005 | Prospective | Histologically proven locally recurrent AJCC T1-4, N0-2 NPC (07/1997-03/2003) | Salvage 3DCRT with or w/out CTx | 86 | 86 CTx 46 | 0
5330, Lu et al., 2005 | Prospective | Histologically proven AJCC stage II nasopharyngeal squamous cell carcinoma (SCC) (08/2001-02/2003) | Definitive 3DCRT | 25 | 24 | 1 Declined to participate due to inconvenience
5420, Pan et al., 2005 | Prospective | Histologically proven stage I–IV head and neck cancer at various sites | Definitive or adjuvant 3DCRT with or w/out CTx Concurrent cisplatin | 40 | 35 CTx 4 | 5 Did not participate in hearing tests
5740, Thorstad et al., 2004 | Prospective | Histologically proven AJCC staged, previously untreated SCC of the head and neck | Adjuvant IMRT | 27 | 25 | 2 Discontinued treatment
6430, Kwong et al, 2004 | Prospective cohort of | Newly diagnosed NPC treated w/IMRT T1, N0-N1, M0 | Definitive RT | 30 | 30 | 0
7090, Chao et al., 2004 | Retrospective cohort | TIV, TII, TII, TI SCC of oropharynx were treated w/IMRT | Definitive and postoperative RT | 74 | 74 | 0
7110, Sze et al., 2004 | Retrospective | Histologically proven AJCC T1-T4 NPC (11/1998-06/2001) | Definitive 3DCRT with or w/out CTx Concurrent cisplatin Induction cisplatin plus 5-FU | 308 | 308 CTx 128 | 1 Discontinued treatment
7370, Lu et al., 2004 | Prospective | Histologically or clinically diagnosed 1992 Fuzhou, China staging system I–IV locoregional recurrent NPC (01/2001-02/2002) | Definitive IMRT with or w/out adjuvant CTx Cisplatin plus 5-FU | 49 | 49 CTx 3 | 0
7570, Levendag et al., 2004 | Prospective | Histologically proven AJCC node-positive or node-negative primary squamous cell carcinoma (SCC) of the head and neck (12/1998-03/2001) | Definitive or adjuvant 3DCRT | 57 | 46 | 11 Received brachytherapy boost to primary tumor and ipsilateral neck dissection
7750, Liu et al., 2003 | Prospective | Histologically proven AJCC I–IV nasopharyngeal carcinoma (NPC) (06/1999-04/2003) | Definitive IMRT with or w/out concurrent CTx Cisplatin alone or plus 5-FU | 103 | 83 CTx 63 | 20 6 distant metastasis 7 local recurrence with previous RT 7 did not complete RT
8250, Munter et al., 2003 | Prospective | Histologically proven AJCC staged carcinoma of the head and neck (10/1999-04/2002) | Definitive or adjuvant IMRT with or w/out CTx | 48 | 48 CTx 9 | 1 Did not complete RT
8270, Braaksma 2003 | CS, prospective | Consecutive pts with LN negative histologically proven squamous ca of the LAR, for whom elective LN irradiation was indicated (07/1998-01/2000) | 3DCRT | 26 | 26 | 0
8370, Padovani 2003 | Prospective | Consecutive patients with PNS CA (01/1995-07/2001) | 3DCRT CTx Resection | 25 CTx 7 Resection 22 | 25 | 0
8400, Amosson 2003 | CS | Histologically confirmed H & N cancer (01/1996-06/2000) No evidence of mets | SMART boost technique with IMRT | 30 | 30 | 0
9290, Teh 2002 | CS | 28 pts with primary H & N cancer | IMRT with SMART boost with parotid preservation. No chemotx | 28 | 28 | 0
9330, Kovacs 2002 | CS | Histologically proven primary squamous cell ca of the OC or OPH | Adjuvant 3DCRT Concurrent CTx | 73 Concurrent CTx | 50 CTx 42 | 0
9510, Jian 2002 | Prospective phase 2 | T3 or T4 histologically proven NPH Ca with apparent base of skull and intracranial disease. ECOG PS 0-1 Adeq renal and BM fxn (01/1992112/1998) | 3DCRT and concomitant and adjuvant CT | 48 | 48 | 0
10740, Pommier et al, 2000 | Retrospective review 3D CRT | Primary tumor including the paranasal sinuses and undergoing CRT | Definitive(10) or Postoperative (30) RT | 40 | 40 | 3
11650, Kuppersmith et al., 1999 | Retrospective | Histologically proven AJCC staged primary or recurrent cancer of the head and neck (03/1994-04/1997) | Definitive or palliative IMRT | 28 | 28 | 0
13270, Lawson 2008 | CS Retrospective | Pts who underwent definitive RT for BOT SCC using SMART and CT (01/2003-08/2005) | Definitive IMRT (SMART) and platinum-based CT | 34 | 34 | 0
13340, Ikushima et al, 2008 | Retrospective cohort study SIC and CRT | Stage III and IV SCC of the oral cavity treated with CRT and Superselective intra-arterial infusion chemotherapy (SIC) | Preoperative RT | 40 | 40 | 0
16840, Wu et al, 2006 | Retrospective cohort study IMRT | Histologically confirmed nasopharyngeal carcinoma patients treated with modulated accelerated radiation therapy boost technique. | Definitive RT | 75 | 75 | 0
26140, Scorsetti 2001 | CS | Relapsed H & N cancer (04/1993-06/2000) | 3DCRT | 58 | 58 | 0
24330, Pfreunder et al., 2003 | Prospective Cohort paclitaxel/cisplatin induction chemotherapy (ICHT) and RT | Patients eligible for total laryngectomy (TL) and TL plus partial pharyngectomy (TLPP) were enrolled in an ICHT RT study | Postoperative RT | 50 | 50 | 0
37660, Wendt et al, 2006 | Prospective cohort study examining tissue sparing of 3D-c-IMRT w/compensators | SCC of HnN using 3D conformal IMRT | Definitive, Postoperative, concomitant RT | 39 | 38 | 1
38290, Anand et al., 2008 | Prospective | Histologically proven AJCC staged locoregionally advanced cancer of the head and neck (12/2002-12/2004) | Definitive or adjuvant IMRT with or w/out CTx Concurrent cisplatin alone, or cisplatin ifosphamide, and 5-FU | 67 | 62 CTx 29 | 5 Did not complete RT 13 had interruption of RT
38530, Studer et al., 2008 | Retrospective | Histologically proven stage pT1-pT4, N0-N2c recurrent SCC of the head and neck (04/2003-09/2008) | Definitive or adjuvant salvage IMRT with or w/out CTx Concurrent cisplatin or cetuximab | 44 | 44 CTx 32 | 0
38640, Studer et al., 2008 | Prospective | Histologically proven AJCC staged Tx-T4, N0-N3 primary or recurrent head and neck cancer at various sites (01/2002-12/2007) | Definitive or adjuvant IMRT with or w/out CTx Concurrent cisplatin or cetuximab | 409 | 409 CTx 343 | 0
38840, Seung 2008 | CS Retrospective | Histologically proven cancer of NPH or OPH (04/2003-04/2007) | All with curative intent. Concurrent CTx | 69 definitive 60 adjuvant 9 CTx 45 | 69 | 0
38850, Caglar 2008 | CS Retrospective | Consecutive pts with newly dxd HNSCC between Excluded if had distant mets, previous RT, sal gl tumor or did not have pharynx in the field. (09/2004-08/2006) | IMRT Concurrent or induction CTx | 96 definitive 82 adjuvant 14 Induction CTx 28 Concurrent CTx 59 | 96 | 0
39000, Sanguineti 2008 | CS | Pathologically proven OPH SCC, no surgery x pretx tonsillectomy (05/2002-02/2006) | Definitive IMRT | 50 | 50 | 0
39020, Rosenthal 2008 | CS Retrospective | Consecutive pts for OPH cancer (09/2002-11/2006) | IMRT definitive or IMRT with concurrent CTx | 160 IMRT alone 93 Concurrent cisplatin 40 Other concurrent CTx 27 | 160 | 0
39300, Hoppe et al., 2008 | Retrospective | Histologically proven AJCC staged recurrent or primary T1-T4, N0-N2 head and neck cancer at various sites (11/1999-06/2006) | Adjuvant IMRT with or w/out CTx Concurrent or adjuvant platinum containing regimens | 151 | 37 CTx 6 | 114 39 received RT at different center 29 received definitive RT or CRT only for stage 4B disease 7 treated with 3DCRT 7 treated with IMRT boost 5 had prior RT for paranasal sinus cancer 27 had melanoma 1 did not complete RT (received 40 Gy)
39390, Worden et al., 2008 | Prospective | Histologically confirmed, previously untreated stage III–IV SCC of the oropharynx (01/2000-11/2002) | Definitive IMRT with CTx Neoadjuvant cisplatin or carboplatin plus 5-FU, concurrent cisplatin or carboplatin | 66 | 53 CTx 53 concurrent | 13 11 did not respond to induction CTx prior to RT 1 died due to CTx toxicity 1 died from disease prior to RT

Table E-B Participant characteristics

Study | Age (yrs) | Race (%) | Female (%) | Disease Stage/Category (%) | | Disease Histology/Site (%) | History of Tobacco Use (%) | Comorbidities or Other Prognostic Factors (%)
560, Biagioli et al., 2007 | med 63 rng 19–82 | | 10 | Recurrent | | SCC 85 Malignant neoplasm 4 Adenoid cystic carcinoma 2 Adenocarcinoma 2 Mucoepidermoid 2 Small cell carcinoma 2 Larynx 29 Oropharynx 29 Parotid 15 Oral cavity 12 Paranasal sinuses 5 Unspecified 5 Nasopharynx 2 Hypopharynx 2
580, Dirix et al., 2007 | med 65 rng 39–82 | | 20 | T2 T3 T4 | 16 32 52 | Adenocarcinoma 68 Neuroendocrine 16 Esthesioneuroblastoma 8 SCC 8 Ethmoid sinus 72 Nasal cavity 16 Maxillary sinus 12
580, Dirix et al., 2007 | med 65 rng 39–82 | | 20 | None had evidence of LN or DM at diagnosis | | Adenocarcinoma 68 Neuroendocrine 16 Esthesioneuroblastoma 8 SCC 8 Ethmoid sinus 72 Nasal cavity 16 Maxillary sinus 12
1010, Urbano et al., 2007 | 63 Gy cohort med 59 rng 37–77 67.2 Gy cohort med 66 rng 60–85 | | 30 | T1 T2 T3 T4 N0 N1 N2a N2b N2c N3 | 3.3 20 53.3 23.3 40 20 3.3 16.7 16.7 3.3 | SCC Laryngeal 47 Hypopharyngeal 53
1420, Feng et al, 2007 | 56 ± 9 | | 17 | T1 T2 T3 T4 N0 N1 N2 N3 | 6 31 25 39 8 11 72 8 | Oropharyngeal 31 Nasopharyngeal 5 Tongue base 53 Tonsil 33 Nasopharynx 14
1430, Scrimger et al., 2007 | ≤ 50≤n = 16 > 50 n = 31 | | 21 | T0 T1 T2 T3 T4 N0 N1 N2 N3 AJCC I II III IV | 4 15 43 26 13 32 26 40 1 4 23 23 49 | SCC 100 Oral cavity 42 Nasopharynx 21 Oropharynx 19 Larynx/hypopharynx 13 Unknown primary 4 | Current 28 Past 49 Never 17 Unknown 6
1500, Lee et al., 2007 | med 57 rng 36–78 | | 32 | T1–2 T3 T4a T4b N0 N1 N2 AJCC III IVA IVB | 26 42 29 3 23 23 54 29 68 3 | SCC 100 Larynx 65 Hypopharynx 35 | | KPS 90 70–80 | 65 35
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | med 57 rng 36–85 | | 19 | T0 Tx T1 T2 T3 T4 N2a N2b N2c N3 | 2 7 11 34 20 26 12 43 31 13 | SCC 100 Oropharynx 71 Larynx 13 Hypopharynx 3 Oral cavity 3 Sinus/nasal 2 Unk primary 7
1780, Lee et al., 2007 | med 58 (rng 31–84) | | 34 | Recurrent | | SCC 86 Adenoid cystic 5 Mucoepidermoid 5 Adenocarcinoma 4 Nasopharynx 20 Neck 20 Paranasal sinus 17 Oropharynx 15 Larynx 10 Oral cavity 8 Parotid 6 Hypopharynx 4 | | Neck dissection pre-RT 10
1900, Ben-David et al., 2007 | med 55 rng 29–86 | white 98 Black 1 Asian 1 | 48 | AJCC I II III IVA IVB Rec | 1 4 23 65 7 1 | Oropharynx 68 Oral cavity 18 Hypopharynx 7 Larynx 4 Other 2
1990, Yao et al., 2007 | med 62 rng 26–90 | | 40 | T0 T1 T2 T3 T4 N0 N1 N2A N2B N2C | 4 14 25 11 45 31 33 4 27 5 | SCC 100 Tongue 36 Mouth floor 27 Buccal mucosa 11 Retromolar trigone 11 Alveolar ridge 11 Lip 4
2180, Daly et al., 2007 | ≤ 60 n = 19 > 60 n = 17 | | 53 | Tis T1 T2 T3 T4 | 3 3 3 22 69 | SCC 33 Esthesio 19 Adeno 14 Adenoid cystic ca 14 Sinonasal undiff ca 14 Mucoepidermoid 3 Neuroendocrine ca 3
2290, Yao et al., 2006 | med 53 rng 36–84 | | 12 | T1 T2 T3 T4 N0 N1 N2A N2B N2C N3 AJCC I II III IV | 20 39 12 29 12 6 11 38 20 14 2 6 4 88 | Tonsil 47 Tongue base 39 Oropharynx 9 Oropharyngeal wall 3 Soft palate 1
2370, Garden et al., 2007 | med 54 rng 30–75 | | 14 | T1 T2 Tx N0 N1 N2A N2B N2C N3 Nx | 37 35 27 16 14 20 27 2 4 18 | Tonsil 65 Tongue base 31 Pharyngeal wall 4 | | > 10 drinks/wk 20 1–10 drinks/wk 43 Rare/never drink 37
2430, Vosmik et al., 2006 | med 55 rng 25–83 | | 16 | I II III IV | 3 18 29 50 | SCC 92 Other 8 Oropharynx 34 Larynx 21 Hypopharynx 16 Nasopharynx 13 Maxillary sinus 10 Nasal cavity 5
2770, Cheng et al., 2006 | ≤ 40 223 > 40 407 | | 30 | T1 T2a T2b T3 T4 N0 N1 N2 N3a N3b | 25 7 19 22 27 11 23 55 4 6 | WHO 1 3 WHO 2 21 WHO 3 76 | | Parapharyngeal space extension 60 Cranial nerve involvement 12 LDH ≤ 410 13 LDH < 410 87
3080 Meirovitz 2006 | | | n=8 (21%) | Stage I n=2 II n=4 III n=6 IVA n=24 IVB n=2 | | OPH n=26 OC n=9 LAR n=1 HYP n=1 UNP n=1
3320, Portaluri et al., 2006 | med 61 rng 37–81 | | 25 | AJCC II III IVA IVB | 12 31 33 4 | SCC 100 Larynx 36 Oropharynx 24 Oral cavity 24 Nasopharynx 12 Other 4
3340 Studer 2006 | Mean 60.8 (34–87 years) | | F:M ratio 1:5 (6:23) | T1N2a n=1 T1N3 n=1 T2N0 n=3 T2N2a n=1 T2N2b n=8 T2N2c n=2 T3N0 n=1 T3 N1 n=1 T3N2a n=1 T 3N2b n=2 T3N2c n=1 T4N0 n=1 T4N1 n=2 T4N2b n=2 T4N2c n=2 Stage 1 n= ( %) Stage 2 n= ( %) Stage 3 n= ( %) Stage 4 n= ( %) | | HYP cancer (100%)
3400 Studer, 2006 | Mean 60.2 (41–85) | | 14(19.2%) | Locally advanced stage ¾ n=37 T1/2N2c n=5 Recurrent dz n=6 T1–2 N0–2b N=25 | | OPH (75%) Oral cavity (25%)
3570 Saarilahti 2006 | Submandibular gland spared Mean 55.4 (29–78) Not spared 52.0 (36–68) | | 21/36 (58%) | [underlined: Tumor stage Submand gl spared:] T0: n=1 (6) T1–2: n=12 (67) T3–4: n=5 (28) [underlined: Submand gl not spared:] T0: n=0 (0) T1–2: n=10 (56) T3–4: n=8 (44) Nodal stage NPH [underlined: Submand gl spared:] N0: 1 N1: 1 N2: 1 [underlined: Submand gl not spared:] N0: 2 N1: 2 N2: 1 OPH [underlined: Submand gl spared:] N0: 1 N1: 3 N2a: 3 N2b: 0 N2c: 0 N3: 0 [underlined: Submand gl not spared:] N0: 2 N1: 2 N2a: 0 N2b: 5 N2c: 3 N3: 2 | | NPH 8/36 (22.2%) OPH 28/36 (77.8%) | | WHO PS Subgl spared 0 n=10 1 n=8 Subgl not spared 0 n=9 1 n=9
3790, Ozsahin et al., 2006 | med 54 rng 39–76 | | 18 | T1–2 T3–4 N0–1 N2–3 | 30 70 45 55 | Oropharynx 34 Oral cavity 27 Nasopharynx 15 Hypopharynx 12 Larynx 12
3820 McMillan 2006 | Mean 45.9 (28–63) | Southern Chinese | n=13 (40.6%) | AJCC Tumor stage 1: n=15(47%) 2: n=17 (53%) | | NPH (100%)
4290, Lau et al., 2006 | med 58 (rng 38–77) | | 25 | Tx T1 T2 T3 T4 N0 N1 N2 N3 AJCC X II III IV | 12 14 27 25 21 18 20 59 3 12 7 20 61 | SCC Oropharynx 48 Hypopharynx 18 Larynx 16 Unknown primary 12 Oral cavity 5 | | KPS 90–100 75 70–80 21 ≤ 60 4
4430 Kwong 2006 | Median 48 (24–74 years) | | n=11 (28%) | T3 (n=16) T4 (n=34) Stage III (n=14) Stage IVA-B (n=36) No evidence distant mets. | | NPC either poorly or undifferentiated (100%)
4630 Yao | 56 (20–90) | | n=32 (21%) | AJCC Stage I n=1 II n=10 III n=25 IV n=103 Unk n=11 | | NPH n=5 OPH n=56 LAR n=33 OCL n=29 HYP n=8 PNS n=8 UNP n=11
5020, Nishimura et al., 2005 | 57 (35 – 81) | | 21 | UICC II, III, IV 27, 15, 58 | | Nasopharynx, Oropharynx, Hypopharynx: 39, 30, 30 | | Performance Status: 0, 1, PS2 67, 30, 3
5120, Wolden et al., 2006 | Med (rng) 48 (13–79) | Caucasian, Asian, Black, Hispanic, Other 3DCRT 43, 29, 11, 6, 11 IMRT 35, 32, 19, 8, 5 | 3DCRT 26 IMRT 28 | AJCC I, IIB, III, IV A/B 3DCRT 0, 20, 31, 49 IMRT 7, 16, 30, 47 T1,2,3,4 3DCRT 11, 23, 29, 37 IMRT 20, 28, 20, 31 999N0, 1, 2, 3 3DCRT 9, 40, 13, 5 IMRT 22, 31, 23, 24 | | NPC | | LCC at 3-yr negatively influenced by increasing T stage p=.001
5210, Duthoy et al., 2005 | IMRT Group: 62 (30–78) | | | IMRT: T1=0, T2=13, T3=4, T4=11 Historic 3DCRT Cohort: T1=2, T2=8, T3=9, T4=11 | | IMRT: Adenocarinoma: 31 SCC: 8 Ethmoid Sinus: 30 Maxillary Sinus: 6 Nasal Cavity: 3 | | IMRT Group: 2 patients treated for recurrent tumor 24 patients w/history of occupational wood exposure 3 patients w/neurological symptoms 5 patients w/cheek swelling 14 patients w/epitaxis 26 patients w/nasal obstruction
5310, Zheng et al., 2005 | med 47 (rng 25–71) | | 30 | T1 T2 T3 T4 N0 N1–2 | 18 31 28 23 91 9 | WHO II 13 WHO III 87 | | Complications at dx Grade0/1 61 Grade 2 31 Grade 3 8
5330, Lu et al., 2005 | med 44 ≥ 60 5 (20) < 60 20 (80) | | 36 | T1 T2 N0 N1 | 52 48 16 84 | WHO I 4 WHO II 8 WHO III 88 | | KPS ≥ 70 100
5420, Pan et al., 2005 | mn 58 (SD 16) | | 49 | Nonmalignant I/II III IV | 9 20 23 49 | Oral cavity 31 Paranasal 26 Salivary gland 23 Nasopharynx 11 Skin 9 Oropharynx 3 | | Hypertension 31 Diabetes mellitus 15
5740, Thorstad et al., 2004 | > 18 | | | | | SCC Oropharynx Hypopharynx Larynx Paranasal sinus | | KPS > 70 100
6430, Kwong et al, 2004 | 43 (29–74) | | 51.5 | T1, T2, T3 94, 3, 3% N0, N1 81.8, 18.2% | | NPC 100% | | Two patients found not to be T1 stage after MRI (1 T2, 1 T3)
6530 Zheng 2004 | ≤45 n=26 >45 n=28 | | N=15 (28%) | AJCC Stage 1 n=5 (9.3) Stage 2 n=16 (29.6) Stage 3 n=18 (33.3) Stage 4 n=15 (27.8) rT1 n=15 rT2 n=25 rT3 n=14 T1 n=7 T2 n=16 T3 n=18 T4 n=13 N0 n=15 N1 n=17 N2 n=17 N3 n=5 | | NPC (100%) WHO type 2 n= 6 (11%) type 3 n=48 (89%)
7090, Chao et al., 2004 | 55 (35–76) | | 17.6 | T1, T2, T3, T4: 22, 35, 19, 26 N0, N1, N2, N3: 17, 22, 58, 6 | | Tonsil, base of tongue, soft palate: 70, 25, 5
7110, Sze et al., 2004 | med 48 rng 17–83 | | 29 | T1 T2 T3 T4 | 9 41 35 21 | WHO II-III 99 Nasopharynx
7370, Lu et al., 2004 | med 45 rng 28–70 | | 24 | T1 T2 T3 T4 N0 N1 N2 N3 AJCC I II III IV | 8 18 22 51 94 4 0 2 8 18 20 51 | Carcinoma 100
7570, Levendag et al., 2004 | mn 61 rng 41–82 | | 21 | N0 N+ | 72 28 | SCC 100 Larynx 48 Oropharynx 39 Hypopharynx 11 Oral cavity 2
7570, Levendag et al., 2004 | mn 61 rng 41–82 | | 21 | AJCC stage III/IV reported in 75% of all cases | | SCC 100 Larynx 48 Oropharynx 39 Hypopharynx 11 Oral cavity 2
7750, Liu et al., 2003 | med 48 rng 25–85 | | 16 | T1 T2 T3 T4 N0 N1 N2 N3 AJCC I II III IV | 23 42 7 28 23 33 30 14 7 30 24 39 | WHO I 2 WHO II 56 WHO III 42
8250, Munter et al., 2003 | med 55 rng 21–78 | | 33 | AJCC I-IVB T1–T4 N0-N1 M0-M1 (not clearly compiled) | | SCC 54 Adenoid cystic carcinoma 38 Adenocarcinoma 8 Salivary glands 38 Maxillary sinus 19 Oropharynx 19 Nasopharynx 17 Larynx/hypophar 4 Unknown primary 4
8270 Braaksma 2003 | Median 62 (42–81) | | n=6 (23.1%) | T1 n=6 (23.1) T2 n=10 (38.5) T3 n=9 (34.6) T4 n=1 (3.8) | | Squamous ca (100) Well diff n=3 (11.5) Mod diff n=15 (57.7) Poor diff n=4 (15.4) Unk n=4 (15.4)
8370 Padovani 2003 | 67 (34–86) | | | T4 n=17 T3 n=4 T2 n=4 (disease was recurrent in 4 pts) | | 25 PNS CA (18 ETH and 7MAX) 13 adenoca and 12 sq ca | | Major adverse px fx was initial involvement of CNS (n=3) or base of skull or dura mater (n=8) and mets to LNs.
8400 Amosson 2003 | Mean 60.5 Median 63.0 Range 43–73 | | 20% | Stage 1 n=3 (10.0%) Stage 2 n=7 (23.3%) Stage 3 n=9 (30.0%) Stage 4 n=9 (30.0%) Recurrent n=1 (3.3%) | | OPH n=16 (53.3) NPH n=4 (13.3) OC n=2 (6.7%) LAR n=4 (13.3) HYP n=1 (3.3) PNS n=2 (6.7) UNP n=1 (3.3) Included squamous cell ca, adenoca and adenoid cystic ca (numbers not provided)
9290 Teh 2002 | | | | | | NPH n=7 (25%) OPH n=12 (43%) HYP n=3 (11%) LAR n=4 (14%) OC n=2 (7%)
9330 Kovacs 2002 | Ave 59.6 | | 27% *note= these numbers include all 73 pts and are not broken out for the pts who rec’d RT vs. those that did not | Stage 1 n=12 (16.4%) Stage 2 n=19 (26.1%) Stage 3 n=10 (13.7%) Stage 4 n=32 (43.8%) *note= these numbers include all 73 pts and are not broken out for the pts who rec’d RT vs. those that did not | | OPH n=10 (14%) OC n=63 (86%) *note= these numbers include all 73 pts and are not broken out for the pts who rec’d RT vs. those that did not | | ECOG status 0: 84% I: 15% II: 1% *note= these numbers include all 73 pts and are not broken out for the pts who rec’d RT vs. those that did not
9510 Jian 2002 | n (%) ≥40 n=14 (29.2) 41–50 n=16 (33.3) 51–60 n=7 (14.6) >60 n=11 (22.9) | | 8 (16.7) | T3 n=11 (23) T4 n=37 (77) | | NPC (100) WHO type 2 n=17 (35.4) WHO type 3 n=31 (64.6)
10740, Pommier et al, 2000 | 67 (28–86) | | 35% | | | Paranasal Sinuses: 70% Nasal cavities: 10% Hard Palate: 20%
13270 Lawson 2008 | Mean 61 (34–76) | | 11 (32) | AJCC Stage 1 0(0) Stage 2 2 (6) Stage 3 3 (9) Stage 4 29 (85) T1N0–3 n=10 T2N0–3 n=10 T3N0–3 n=4 T4N0–3 n=10 | | BOT SCC 100% | 24 (71)
11650, Kuppersmith et al., 1999 | med 55 rng 10–92 | | 14 | T1-T4 N0-N2C M0 | | SCC 64 Other 36 Nasopharynx 25 Maxillary sinus 14 Base of tongue 14 Other 47
13340 Ikushima et al, 2008 | 63.1 (27–81) | | 35 | III, IV 33, 77 | | Tongue, gingiva, bucca mucosa, oral floor, soft palate 35, 47.5, 10, 5, 4 | | SIC chemotherapy
16840, Wu et al, 2006 | 52 (24–82) | | 28 | I, II, III, IV 5.3, 38.6, 38.6, 17.3 WHO type 1,2,3 2.6, 88, 9.3
26140 Scorsetti 2001 | 46 (20–71) | | 20 (34.5) | | | Undiff NPC n=16 (27.6%) Squamous cell ca n=10 (17.2) Adenoid cystic ca n=9 (15.5) Adenocarcinoma n=8 (13.8) Various n=15 (25.9)
24330, Pfreunder et al., 2003 | 58 (42–77) | | 16 | T2N0, T3N0, T3N1, T3N2a, T3N2c, T4n), T4N1, T4N2b, T4N2c, T4N3 2, 28, 8, 2, 2, 6, 18, 10, 6, 14, 4% | | Resectable carcinomas of the glottic (T3-T4) and supraglottic larynx/hypopharynx (T2-T4, N0-N3, M0)
38840 Seung 2008 | Median 56 yrs (35–89) | | 14 (20) | AJCC stage I n=2 (3) II n=11 (16) III n=16 (23) IV n=40 (58) | | NPH n=11 (16 ) BOT n=18 ( 26) Tonsil n=40 (58) n=66 (95.7) SCC n=2 (2.9) LELCarc n=1 (1.4) undiff carc
38850 Caglar 2008 | Median 55 (20- 87) | White n=70 (73) Nonwhite n=9 (9) Unk n=17 (18) | 17 (18%) | Stage I n=1 (1) II n=3 (3) III n=23 (24) IV n=69 (72) | | OPH n=43 (45%) NPH 11(11) OC 13(14) HYP 17(18) MAX 2(2) UNP 10(10) | Yes n=48 (50%) No 48 (50)
39000 Sanguineti 2008 | | | | Stage 1 n=1 (2%) 2 n=5 (10%) 3 n=15 (30%) 4 n=29 (58%) | | Tonsil n= 34 (68%) BOT n=8 (16) Pharyngeal wall 2 (4) Soft palate 6 (12)
39020 Rosenthal 2008 | Median 58 (34- 81) | | 21 (13.1) | T1N0–3 n=48 T2N0–3 n=72 T3N0–3 n=21 T4N0–3 n=19 | | BOT n=78 (48.8) Tonsil n=80 (50) OPH n=2 (1.2)
37660, Wendt et al, 2006 | 57 (37–76) | | 10% | | | Nasopharynx, oropharynx, oral cavity/tongue, hypopharynx/supraglottic larynx, CUP-syndrome 10, 51, 23, 13, 3% | | Radical RT alone: 26% Postoperative RT: 74% RT without simultaneous chemotherapy: 51 RT with simultaneous cDDP: 49
38290, Anand et al., 2008 | med 56 rng 27–85 | | 23 | AJCC I II III IVA IVB | 6 16 27 39 11 | SCC 89 Adenoid cystic carcinoma 6 Mucoepidermoid carcinoma 3 Adenocarcinoma 2 Nasopharynx 24 Larynx 21 Oropharynx 16 Tongue 14 Hypopharynx 13 Alveolus 6 Paranasal sinus 5
38530, Studer et al., 2008 | mn 64 rng 35–87 | | 36 | pT1 pT2 pT3 pT4 T unk N0 N1 N2a/b N2c N unk | 32 52 2 7 7 59 11 20 5 5 | SCC 100 Oral cavity 66 Glottic 18 Oropharynx 9 Sinonasal 5 Skin 2 | | Grade 1 Grade 2 Grade 3 unk | 5 34 27 25
38640, Studer et al., 2008 | mn 60 rng 21–87 | | 22 | Tx T1 T2 T3 T4 N0 N1 N2a/b N2c N3 Recurrent 17 | 1 11 31 17 28 17 12 32 27 5 | SCC 95 Lymphoepithelial carcinoma 5 Oropharynx 40 Oral cavity 19 Hypopharynx 15 Larynx 12 Nasopharynx 10 Sinonasal 2 Unknown 1
39300, Hoppe et al., 2008 | med 55 rng 15–88 | White 73 Asian 11 Black 11 Other 5 | 49 | T1 T2 T3 T4 N0 N1 Kadish A B C | 0 17 17 55 90 10 0 66 33 | SCC 46 Sarcoma 14 Adenoid cystic 11 Undifferentiated 8 Adenocarcinoma 8 Esthesioneuroblastoma 8 Myoepithelial 5 Maxillary sinus 54 Nasal cavity 27 Ethmoid sinus 11 Lacrimal gland 3 Sphenoid sinus 3 Frontal sinus 3 | | KPS med 90 (rng 70–100)
39390, Worden et al., 2008 | Male med 55 rng 37–77 Female med 61 rng 50–74 | | 23 | T1 T2 T3 T4 N0 N1 N2 N3 | 8 26 35 32 18 23 50 9 | SCC 100 Base of tongue 61 Tonsil 39 | Never 24 Past 42 Current 33 | HPV titer pos neg unk KPS 80 90 100 | 41 23 36 9 20 71

Table E-C Treatment characteristics

Study | Localization or Staging Methods | Computerized Treatment Planning (system/vendor) | Radiation Delivery Source (energy level) | Duration of Treatment, Dose, Fractionation, Boost | Beam Characteristics (number, shaping) | Immobilization/Repositioning Procedures | Scope of treatment (bilateral, lymph nodes in neck) | Measures to reduce toxicity, e.g., moving salivary gland
560, Biagioli et al., 2007 | CT | Yes (Nomos.) | Photons (6-MV) | 60 Gy, 2 Gy/frac, 5 frac/wk Lifetime dose to spinal cord ≥ 60 Gy | | | GTV = gross tumor volume PTV = GTV and areas at risk of microscopic disease expanded by 5–20-mm margin
580, Dirix et al., 2007 | CT, MRI | Yes (Helios, Cadplan, Eclipse) | Photons (6-MV) | 60 Gy 2 Gy/frac, 5 frac/wk IMRT boost 6 Gy, 2 Gy/frac in 10 pts In regions where PTV and OAR overlapped (optic structures) underdosage of the PTV was tolerated No elective irradiation of cervical LNs | Non-coplanar 6- field arrangement consisting of 5 fields of 6-MV photons and 1 filed of 10 or 18 MV photons from LA | 3-point fixation thermoplastic mask | CTV included GTV plus margin (not defined) to account for microscopic disease at margin, encompassing resection cavity plus all paranasal sinuses that were invaded PTV included CTV plus 5-mm margin
1010, Urbano et al., 2007 | CT | Yes (Helios, Cadplan, Eclipse or Helax- TMS and Pinnacle) | Photons (6-MV) | Dose level (DL) 1: Primary tumor site 63 Gy, 2.25 Gy/frac Elective nodal areas 51.8 Gy, 1.85 Gy/frac With IMRT SIB DL 2: Primary tumor site 67.2 Gy, 2.4 Gy/frac Elective nodal areas 56 Gy, 2 Gy/frac Mn Tx time: DL1 = 39±3 days DL2 = 38±1 days Maximum mean dose to parotids 24 Gy where possible | 5- and 7-beam arrangements | Custom-made cabulite head and neck mask | CTV1 = entire larynx and hypopharynx complex, including thyroid cartilage, from 1 cm above the tip of the epiglottis to below the cricoid cartilage; adjacent sites invaded by tumor as well as all involved nodal areas and retropharyngeal nodes were included; CTV2 = elective nodal volume, including uninvolved levels 2–5 and supraclavicular fossa nodes bilaterally; PTV1/PTV2 = CTV1/CTV2 plus 3-mm margin
1420 Feng et al, 2007 | CT | Yes (in-house system) | | 70 Gy, 2.0 Gy/frac to gross disease 59–63 Gy, 1.7–1.8 Gy/frac to low- and high-risk subclinical targets Maximal mandibular dose < 72 Gy Mean parotid gland dose ≥ 26 Gy Mean noninvolved oral cavity dose ≥ 30 Gy | Inverse-planned beamlet (not further described) | | CTV = primary tumor and include lateral retropharyngeal (RP) nodes PTV = CTV plus a 3- mm margin Targets in low neck were included I IMRT plans, but anterior low neck fields abutting upper neck plans were not used
1430, Scrimger et al., 2007 | | Yes (Helax v.6.02) | Photons | 2 Gy/frac, 5 frac/wk initially, then 1.8–2.2 Gy/frac in SIB protocol Planning goal to keep RT dose to spared portion of parotids as low as possible (mean dose to spared portion of parotid 18.4 Gy Mean dose to all parotid tissue 27.1 Gy | 7 gantry angles, 128-leaf MLC | | In most patients, the CTV was immediately adjacent to the deep lobe of the parotid; entire target volume, including low neck, treated as 1 volume with no separate supraclavicular field PTV = CTV plus 5-mm margin PTV66 = areas of gross disease PTV60 = high-risk operative bed PTV54 = low-risk operative bed or undissected nodal regions
1500, Lee et al., 2007 | CT with contrast | Yes (MSKCC tx planning system) | Photons (6-MV) | 70–72 Gy, 1.64- 2.12 Gy/frac, once daily with concomitant boost (n = 4) or SIB (n = 27) When possible, a mean parotid dose of ≥ 26 Gy was achieved; efforts were made to prevent unwarranted hot spots within the glottic larynx | 7-field | Thermoplastic head, neck, and shoulder mask | GTV = any visible tumor on imaging studies and/or physical examination CTV = GTV plus 5–10- mm margin, including levels II-IV nodal regions in the neck, retropharyngeal region in pts with clinically involved neck nodes, levels I-II in pts with node-positive disease at level II, and pts who had a primary hypopharyngeal tumor PTV = GTV or high- risk CTV plus a 3-mm margin In some cases a low- risk CTV and corresponding low-risk PTV involved the clinically uninvolved contralateral neck and base of skull
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | CT, MRI | Yes (Corvus v.3.0, Nomos.) | Photons | 50–74 Gy, 1.2- 1.25 Gy/frac, once daily (n = 83), twice-daily (n = 5), 2 with accelerated fractionation with noncomitant boost | Multivane, intensity- modulating collimator | Thermoplastic facemask | CTV1 = primary tumor and involved lymph nodes with margins CTV2 = high-risk areas harboring microscopic disease, including soft tissue surrounding CTV1 and lymphatic areas with high risk of metastasis CTV3 = areas with intermediate risk of microscopic disease
1780, Lee et al., 2007 | CT with or w/out contrast | Yes (MSKKC in- house) | Photons (6-MV) | 30–70 Gy med 59 Gy Dose constraints: Spinal cord 50 Gy | Beams chosen to ensure at least 95% of dose encompassed the target volume | Thermoplastic mask | GTV = any visible evidence of disease CTV = at minimum the preoperative GTV and postop tumor bed PTV = GTV and CTV plus 10–20-mm margins
1900, Ben- David et al., 2007 | CT | Yes | Photons | 70 Gy, 2 Gy/frac to gross tumor, 56–64 Gy, 1.6–1.8 Gy/frac to low- and high-risk targets Maximal mandibular dose < 72 Gy Mean parotid gland dose ≤ 26 Gy Mean noninvolved oral cavity dose ≤ 30 Gy | Static multisegmental or inverse- planned beamlet (not further described) | | CTV = not described PTV = CTV plus 5-mm margin | Radiation guards used in all pts with metallic dental restorations to reduce electron backscatter to adjacent soft tissue
1990, Yao et al., 2007 | CT | Yes | Photons | 50–70 Gy, 2 Gy/frac Definitive IMRT pts received additional SIB of 10 Gy, 2 Gy/frac High-risk postoperative sites (extracapsular extension, positive or close margins, tumor involvement of soft tissue or bone) received additional SIB of 4–6 Gy, 2 Gy/frac No SIB given for intermediate-risk sites (w/out extracapsular extension, no positive or close margins, no soft tissue or bone involvement) | | | CTV1 = tumor bed, including preoperative primary tumor volumes and involved LNs CTV2 = high-risk areas harboring microscopic disease, including normal structures immediately surrounding CTV1 with high risk of local tumor invasion (primary tumor CTV2) and high-risk lymphatic regions (lymphatic CTV2) CTV3 = intermediate- risk lymphatic areas PTV = CTV plus 5–8- mm margin
2180, Daly et al., 2007 | CT | Yes (Nomos.) | Photons | 60–70 Gy, 1.8- 2.12 Gy/frac, once daily Dose constraints: 1% of brainstem and optic nerves volume 54 Gy < 1% temporal lobes volume 60 Gy Half the contralateral parotid gland 25 Gy Upper neck or high-risk subclinical region 60 Gy Low neck and supraclavicular region 50–54 Gy | Continuous course RT delivered using an auto- sequence MLC | Perforated, thermoplastic head mask | GTV = gross extent of tumor CTV = GTV plus margin of 10–20 mm for microscopic disease PTV = CTV plus 3–5- mm margin to account for patient setup error Elective neck radiation administered at the discretion of the treating physician (n = 10) Two methods used to treat neck: Primary tumor and upper neck above vocal cords treated with IMRT, anterior field for lower neck and supraclavicular fossae Extended field IMRT for primary tumor plus all regional LNs including supraclavicular
2290, Yao et al., 2006 | CT | Yes (Nomos.) | Photons | Definitive IMRT: 70–74 Gy to PTV1, 60 Gy tp PTV2, 50–54 Gy to PTV3 Adjuvant IMRT: 60–66 Gy to PTV1, 60 Gy to PTV2, 50–54 Gy to PTV3 | Multivane intensity modulating collimator | | CTV1 = primary tumor and involved cervical LNs CTV2 = high-risk areas harboring microscopic disease CTV3 = intermediate- risk lymphatic areas PTV 1–2 = CTV 1–3 plus 5-mm margin
2370, Garden et al., 2007 | CT | Yes (CORVUS v.4.0, Nomos.) | Photons (6-MV) | 66–70 Gy, 1.8–2.2 Gy/frac to CTV1 57–64 Gy, 1.9–2.1 Gy/frac to CTV2 54 Gy, 1,8 Gy/frac to CTV3 Concomitant boost 15–18 Gy in10 frac in 4 pts Dose constraints: Parotid glands 26 Gy Larynx 30–40 Gy | MLC | | CTV1 = gross disease with minimum 5-mm margin CTV2 = CTV1 with additional margin CTV3 = subclinical sites in both sides of upper neck Lower neck treated with anterior field matched to inferior borders of IMRt delivery
2430, Vosmik et al., 2006 | CT (with or w/out contrast), MRI in some cases | Yes (CadPlan, Helios) | Photons | 54–66 Gy, 1.8–2.2 Gy/frac, 6 wks 66 Gy to PTV66 60 Gy to PTV60 54 Gy to PTV54 With IMRT simultaneous integrated boost (SIB) Dose constraints: Spinal cord maximum dose < 44 Gy Brain stem maximum dose < 54 Gy mean dose < 28 Gy Larynx (if not part of PTV) 67% volume < 50 Gy | Dynamic MLC, 2x26 leafs | Thermoplastic mask | CTV, GTV, PTV defined according to ICRU Report 50 GTV = all macroscopic disease CTV = gross disease plus 0.5–20-mm margin for microscopic disease PTV = CTV plus 0.5–20-mm margin for setup errors
2770, Cheng et al., 2006 | CT | Yes | Photons (6-MV and 18-MV) | 70 Gy, 2 Gy/frac, 5 frac/wk 74.4 Gy, 1.2 Gy/frac, 2 frac daily, 10 frac/wk Dose constraints: Spinal cord 43–44 Gy | Opposed fields with or w/out anterior field | | Bilateral, off-cord or posterior cord boost, separate anterior field for low neck and supraclavicular fossa
3080 Meirovitz 2006 | | | | Tumor dose NR Mean dose to contra and ipsilateral parotid ave 22 Gy (SD 5 Gy) and 53 Gy (SD 7 Gy) Mean dose to contra and ipsilat submandibular gland 57 Gy (SD 8) and 65 Gy (SD 7) | | | Bilateral neck in all 38
3320, Portaluri et al., 2006 | CT with or w/out contrast | Yes (Eclipse) | Photons (6-MV) | 44–64 Gy to PTV1, 2 Gy/frac, 5 frac/wk Boost to CTV2 Dose constraints: Median Dmax (overall population) Spinal cord 44 Gy Ipsilateral parotid 48 Gy Contralateral parotid 42 Gy | Multileaf collimator with 80 leaves, 11 fields (minimum 10, maximum 14) | Head-and-shoulder mask | CTV1 = tumor bed and bilateral LN levels depending on tumor site and stage CTV2 = tumor bed and involved LNs PTV1 and PTV2 = CTV1 and CTV 2 plus 4-mm margin
3340 Studer 2006 | CT, MRI and PET | Varian treatment-planning system (Eclipse®, Version 7.3.10, Varian Medical Systems, Hansen Way, Palo Alto CA, USA) | 6 MV photon beams | Simultaneous integrated boost (SIB) doses between 60 and 71 Gy (five fractions/week) with 2.0 (n = 8), 2.11 (n = 17), and 2.2 Gy (n = 4)/fraction to the boost volume (planning target volume, PTV1) were applied. Organs at risk: Sp cd max <45 Gy, parotids mean <26 Gy, OC mean <35 Gy, nuchal tissue mean <45 Gy. Mean total treatment time was 45.4 days (32–58 days). | 5-field equiangular. | Commercially available thermoplastic mask | GTV with a margin of 10–15 mm was included in the SIB volume. Elective lymph node regions (PTV2, 50–57 Gy) level 2–5 were included bilaterally.
3400 Studer 2006 | | IMRT: Varian Treatment planning system (Eclipse®, version 7.3.10, Varian medical system, Hansen Way, Palo Alto, CA, USA) | IMRT: 6-MeV photon beams | In all patients, SIB-IMRT technique was performed using the following schedules: • 30 × 2.2/1.8 Gy to 66 Gy (PTV1)/54 Gy (PTV2; n = 28); • 33 × 2.11/1.64 Gy to 69.6 Gy/54 Gy (n = 25); • 30 × 2.11/1.8 Gy to 63.3/54 Gy (n = 3); • 30–35 × 2.0 Gy to 60–70 Gy (n = 16 postoperative patients). In one case with large necrotic nodes, a higher SIB dose of 2.35 Gy per fraction to 75.2 Gy to the nodal GTV was chosen. Dose to spinal cord, parotids, TMJ, brain, OC outside of PTV, nuchal tissue: Max <45 Gy, mean ≤26, <50, <40, mean <35, mean <45 | Most were 5-field arrangements (n=61) 6-fields (n=5) 7-fields (n=7) Sliding window MLC | | | Doses delivered to partial volumes of mandibular bone using IMRT with doses between 60–75Gy (mean 67) on average 7.8, 4.8, 0.9 and 0.3 cm^3^ were exposed to doses >60, 65, 70 and 75 Gy respectively. [mean mandibular bone volume 58.4 cm^3^ (33–88cm^3^)
3570 Saarilahti 2006 | | IMRT: Helios inverse treatment planning software with Cadplan® system version 6.27(Varian Medical Systems, Helsinki, Finland) | IMRT: 6 MV photon beam | IMRT: Parotids excluded from PTV: Max 25 Gy 1^st^ 5 patients and 16–20 Gy in rest of patients. Dose constraints for spared submandibular glands varied 20–25 Gy. Mean total dose to parotids and submand gl not treated as OAR was 49 Gy(45–54) | | Conventional thermoplastic mask for immobilization in 1^st^ 10 patients (Posicast®, Sinmed BV, EM Reenwijk, the Netherlands). Remaining pts stereotactic H & N immobilization device (BrainLab, Heinstetten, Germany). | | Both parotids spared in 7 (19%) patients, one contralateral parotid in 29 (81%). Contralateral submandibular spared in 18 (50%) of patients.
3790, Ozsahin et al., 2006 | CT, MRI | | Photons (6-MV) and electrons | Definitive tx: 70 Gy, 2 Gy/frac, 6 wks Adjuvant RT: 66 Gy, 2 Gy/frac, 5 wks, 3 days RT delivered as concomitant-boost accelerated schedule in single daily fracs M-Th, 2 frac on F Parotids received ≥ 50 Gy in all pts | | Thermoplastic mask | Surgical margins, extracapsular nodal infiltration, regional nodes | Amifostine 500 mg sc prior to each RT frac except Friday pm session
3820 McMillan 2006 | CT | Corvus system (version 3.0) | | IMRT: To PTV 66–68 Gy (included deep lobe of parotid and posterior ½ of submandibular) To GTV 68–72 Gy 34 fractions over 7 weeks | | Cast | IMRT: CTV= GTV + 1 cm PTV added 2 mm margin and included level 2 and 4 Cx LNs.
4290, Lau et al., 2006 | CT w/contrast | Yes (Pinnacle3) | Photons (6-MV) and electrons | 70 Gy, 2 Gy/frac, 7 wks 50 Gy to areas of microscopic spread Dose constraints: Spinal cord 36–40 Gy | Shaped lateral opposed fields, matching anterior low-neck field 0.5-cm multileaf collimator (MLC) | Hard plastic immobilization shell | GTV = primary tumor and involved LNs Upper and lower neck
4430 Kwong 2006 | CT | Inverse planning Corvus System version 3.0 (NOMOS. Corp, Sewickley, PA) | | Prescribed dose: GTV: 76 Gy. Nodal GTV: 72 PTV: 70 35 fractions over 7 weeks. Fractional dose PTV: 2 Gy daily GTV: 2.17 Gy daily (SMART boost technique) Dose to lower neck 60 Gy if N0, 66 Gy if node-positive in 2 Gy daily fractions. | 9 coplanar equally spaced beam angles | Tailor-made thermoplastic cast from head to shoulders with neck support and mouth bite. | IMRT: GTV includes whole NP, tumor extending out of NP, any skull-base erosion and intracranial disease. GTVn: enlarged neck nodes CTV: in some cases, just GTV (if close to critical structures), some were GTV + 5mm–1.5 cm. If palpable residual neck node present after IMRT completion, boost dose of up to 10 Gy may have been given.
4630 Yao | CT, MRI, FDG-PET | Corvus treatment planning system, NOMOS Version 3.0 | | [underlined: Definitive IMRT] Prescribed dose PTV1 70–74 Gy PTV2 60 PTV3 50–54 [underlined: Postop high risk] Prescribed dose PTV1 64–66 PTV2 60 PTV3 50–54 [underlined: Postop intermediate risk] PTV1 60 PTV2 60 PTV3 50–54 Total (daily) dose SEB=sequential boost [underlined: Definitive IMRT:] SIB: CTV1/CTV2: 60 (2) CTV3: 54 (1.8) SEB: CTV1:10–14 (2) [underlined: High risk post op] SIB: CTV1/CTV2: 60 (2) CTV3: 54 (1.8) SEB: CTV 1: 4–6 (2) [underlined: Intermed risk postop] SIB: CTV 1/CTV 2: 60 (2) CTV 3: 54 (1.8) SEB: CTV1: no Max to normal tissues: Sp cd 45 Gy Br stm 54 Optic n/chiasm 54 Retina 50 Temp lobes 60 Glottic larynx 2/3 < 50 Mandible 70 Parotid mean <30 or 50% of either <30. | | Thermoplastic face mask | CTV1: GTV with 5–10 mm margins CTV2: high-risk areas harboring microscopic disease (incl normal structures immediately surrounding CTV with high risk of local tumor invasion and high risk lymphatic regions. CTV3: Intermediate-risk lymphatic areas.
5020, Nishimura et al., 2005 | CT | IMRT treatment planning done by Cadplan Helios, Varian associates, Palo Alto, CA; Eclipse, Varian Medical Systems International Inc, Baden, Switzerland) Treatment delivery by: Clinac-600C accelerator (Varian Associates) | 4MV X-Ray | Whole neck irradiation with 46 to 50 Gy in 23–25 frac IMRT boost to PTV to a total dose of 56 to70Gy in 28–35 frac (med, 68 Gy) Dose constraints to spinal cord, brain, ipsilateral parotid gland, contralateral parotid glad: 40, 50, 25–30, 20–25 Gy | 5 or 7 co-planar beams: angles of 60–75, 105–115, 135–150, 180, 210–225, 245–255m 285–300 | Type-S theromoplastic based system (med-tec, Orance City, IA) | Bilateral and submandibular (Ib) and jugular chain (level II–IV) nodes were included in CTV. The planning organ at risk volume a 3mm margin was added for the spide with no margin to parotid | .
5120, Wolden et al., 2006 | CT, MRI | 3DCRT (not specified) IMRT (not specified) | | IMRT 70 Gy total dose; accelerated fractionation/ 59 patients treated with hyperfractionated concomitant boost/ 15 patients dose painting (PTVm 1.8 Gy/frac 54 Gy total and PTVg 2.34 Gy/frac 70.2 Gy) | IMRT Multiple beams tailored to patient anatomy and NPC distribution using dynamic multileaf collimators | Aquaplast masks for IMRT | IMRT PTVg included GTV w/1-cm margin increase with the exception of posterior dimension to the primary tumor where a 5-mm margin was added. PTVm consisted of PTVg plus the area encompassing the nasopharynx and all cervical lymph nodes w/ a 5-mm margin. | Limitation of parotid gland mean dose limited to 26 Gy when possible; cochlea dose reduced as much as possible
5210, Duthoy et al., 2005 | CT/MRI | | | IMRT: End dose of 60 Gy in 4 patients, 66 Gy in 6 patients and 70 Gy in 29 patients all in 35 frac. Prescribed dose not reached in 2 patients (1 death after 21 frac and 1 was stopped due to liver mets) 3DCRT: 19 patients had 65Gy (61–70Gy) 1.8Gy/ frac 11 patients had noncoplanar beam w/ median dose of 66 Gy (54–66Gy) 2Gy/frac | 3DCRT: 19 patients had coplanar beams 10 had non-coplanar | ‘ | No elective radiation of cervical lymph nodes (ELNI) 3mm margin used for expansion from CTV to PTV
5310, Zheng et al., 2005 | CT, MRI | | Photons (6-MV) | 66–72 Gy, 2 Gy/frac, once daily 5 days/wk, 6–7 wks Dose constraints: Mean Dmax Gy(rng) Brainstem 32 (19–45) Spinal cord 24 (13–42) Temporal lobe I 42 (17–68) Temporal lobe C 23 (7–47) Optic nerve I 36 (7–67) Optic nerve C 31 (6–56) Optic chiasm 31 (6–56) Eyeball I 21 (2–39) Eyeball C 15 (1–22) | 5–7 static coplanar or noncoplanar beams with 3–7- mm block aperture margin from the PTV boundary, with wedges to improve dose conformity and homogeneity as needed | | GTV = primary tumor CTV = GTV plus extent of subclinical microscopic disease, usually 5–10-mm margin For high risk subclinical sites (eg, skull base, parapharyngeal space, oropharynx) 8–10 mm of CTV margin was delineated PTV = CTV plus 2.5- mm margin PRV (planning risk volume) = 2.5-mm margin around organs at risk
5330, Lu et al., 2005 | CT | Yes | | Total to CTV 72 Gy, 1.7 Gy/frac, 6 wks Initial dose to GTV 54 Gy, 1.8 Gy/frac, 5 frac/wk, 6 wks Accelerated boost added 1.5 Gy/frac as second daily frac for 12 days Dose constraints: Spinal cord 39.6 Gy | | | GTV = primary tumor plus draining anterior neck LNs Clinically involved and uninvolved posterior neck Boost target volume included primary tumor plus involved LNs plus 2-cm margin Supraclavicular fossae
5420, Pan et al., 2005 | CT | Yes (UMPlan in-house) | | 40–70 Gy med 64 Gy | | | Primary tumor Unilateral neck
5740, Thorstad et al., 2004 | CT | Yes (Nomos.) | Photons (6-MV) | | | Aquaplast face mask | CTV1 = preop gross tumor volume plus 10-2—cm margin, including resection bed with invasion, or extracapsular extension by metastatic neck LNs CTV2 = uninvolved cervical LNs | Amifostine 500 mg sc prior to each RT frac
6430, Kwong et al, 2004 | CT | IMRT delivered with Mimic (NOMOS. Corporation) Inverse planning by Corvus v3.0 (NOMOS. Corporation) | 4 or 6 MV | GTV: 68–70Gy to at least 95% and 70 Gy to macroscopically enlarged nodes in 2–2.06Gy/34 frac PTV:66–68Gy to 95% 1.9–2.0Gy/frac 60–66Gy 2Gy daily frac from neck caudal to the chin or caudal to the most distal enlarged lymphnode. Organ atrisk Gy are listed in rightmost column. Dose constraints to organs at risk: Spinal cord, [Eye, optic nerve, optic chiasm, temporal lobes, brain], brainstem, parotid glands, pituitary glands, [inner ears, middle ears, tempromandibular joints] – 40, 50, 50, 20, 25, 50 Gy | 9 co-planar beam angels equally spaced. 0, 40, 80, 120, 160, 200, 240, 280, 320, 360 degrees | Custom thermoplastic cast from head to shoulders | Potential sites of local infiltration 1mm from GTV were included in CTV. CTV included: sphenoid sinus caudal to the base of pituitary fossa, cavernous sinuses on both sides, base of skull, including petrous temporal bones and excluding internal auditory canals and cochleae, inferior orbital fissures, foramen ovale and foramen spinosum, anterior half of the clivus and posterior third nasal cavity and antrum, medial pterygoid muscles and parapharyngeal space up to the styloid process and anterior one-half of the arch of the cervical vertebrae (C1) and prevertebral muscles inferior to C1. Enlarged cervical lymph nodes were localized as separate GTV
6530 Zheng 2004 | CT/MRI | 3D planning (AcQPlan 3D RTP, Marconi Medical Systems) | | Salvage dose ranged from 16–38 Gy (median 24) with 2 Gy/fraction, one fraction daily, 5d/wk. (Initial external beam RT doses: median to NPH 70 Gy, to negative neck 50, and to positive neck 68, fraction 2.0/d). | | | PTV= persistent disease + 5mm margin
7090, Chao et al., 2004 | CT | i | | 70 + or − 1.1 Gy to CTV1 definitive, 66.3 + or − 3.6Gy, CTV for definitive patients was 64+ or −4.2 Gy, and 66.3 + or − 3.6 Gy. 1.9 to 2.0 Gy/frac 5 frac/wk | | | CTV1 encompassed GTV and region adjacent to GTV, the surgical bed w/soft-tissue invasion, and regions with extracapsular extension by metastatic neck nodes, CTV2 was primarily prophylactically treated nodal stations. Dose to each target volume was normalized to 80–90% of maximal isodose reference point.
7110, Sze et al., 2004 | CT w/out contrast | Yes (Helax TMS) | | 70 Gy, 2 Gy/frac, 5 or 6 frac/wk, 7 wks 70 Gy to grossly enlarged LNs 50–60 Gy to supraclavicular fossae med 46 days (rng 36–55 days | 5–7 beams | Rigid immobilzation device | GTV-P = gross tumor volume plus adjoining involved retro-pharyngeal LNs PTV = GTV-P and whole nasopharynx, plus 7–12-mm margin Parapharyngeal spaces, posterior nasal fossae and maxillary sinuses, sphenoid and posterior ethmoid sinuses, base of skull and cavernous sinuses
7370, Lu et al., 2004 | CT, MRI | Yes (Nomos.) | | 66–70 Gy, 1.8–2.8Gy/frac, 5 frac/wk 60 Gy to positive LNs in neck Dose constraints: According to ICRU 50 guidelines Brainstem mn dose 28 Gy Optic chiasm mn dose 22 Gy Optic nerves mn dose 19 Gy Lens mn dose 4 Gy Temporal lobes mn dose 22 Gy Temporomandib28 Gy Mandible mn dose 20 Gy Pituitary mn dose 33 Gy | Dynamic multivane intensity modulating collimator (MIMiC) using segmental tomotherapy techniques | | GTV = gross extent of tumor shown on imaging studies CTV = GTV plus 5–10- and 10–15-cm margins
7570, Levendag et al., 2004 | CT | Yes (3D Cadplan) | Photons (6-MV) | 70 Gy to gross primary tumor and involved neck LNs 46 Gy to uninvolved neck LNs | Dynamic multileaf collimator, abutted AP portal with midline shield for lower neck | PVC head cast | CTV = primary tumor plus neck PTV = CTV plus 5-mm margin Unilateral and bilateral neck
7750, Liu et al., 2003 | CT, MRI | Yes (Pinnacle3) | Photons (6- or 15- MV) | 60–77 Gy, 1.8 Gy/Frac, 5 frac/wk 70–77 Gy to primary tumor and positive neck LNs 60–65 Gy to CTV 50 Gy to clinically negative neck Limit dose to 1% of volume of critical structures as follows: Brainstem and optic nerves 50 Gy Spinal cord and optic chasm 45 Gy Temporal lobes60 Gy 50% of contralateral parotid 25 gy | Static multisegmental multileaf collimator Split-beam technique for anterior lower neck field | | GTV = gross extent of tumor, including nasopharyngeal primary and retropharyngeal lymphadenopathy CTV = GTV plus margin of potential microscopic spread
8250, Munter et al., 2003 | CT, MRI | Yes (KonRad, VIRTUOS) | Photons (6- or 15- MV) | 55–72 Gy to primary PTV, GTV, positive LNs, 1.6–2.0 Gy/frac or 1.6–2.0 Gy/frac IMRT boost or integrated boost also used 50–65 Gy to secondary PTV Dose constraints: Cervical spinal cord 50 Gy Brainstem 60 Gy Optic nerve and chiasm 54 Gy Protected parotid < 26 Gy | Integrated multileaf collimator, 5–9 beams (med 7) | Scotch-Cast mask | GTV = visible tumor in imaging studies CTV = GTV plus 5-mm margin; in postop cases GTV included surgical bed and margins according to assessed risk Primary PTV = CTV plus 3-mm margin to compensate internal organ motion and setup variability Secondary PTV = LNs or surgical neck levels at risk of sub clinical disease, including LN level II–V (depending on tumor site), retropharyngeal LNs, and in some cases level I All pts with ipsilateral LN involvement also had contralateral neck RT Tumor suspicious LNs and LN levels with radiographic evidence were defined as a target volume
8270 Braaksma 2003 | CT | Non commercial inverse planning module “Optimize” Computer planning purposes: Cadplan versions 2.7.9 and 3.1.2, Varian-Dosetek, Finland. | 10 MV | 3DC 46 Gy to primary tumor and LN levels of neck (PTV1); then boosted to cumulative dose of 70 Gy primary tumor (PTV2). Mean dose to R and L parotids was 29.2 and28.7, respectively. | | | PTV= CTV + 5mm margin
8370 Padovani 2003 | | Focus logical, CMS, St Louis, MO | 6–18 MV | 3DC RT delivered in doses of 2 Gy/fraction at 5 fractions weekly. Median dose PTV was 63 Gy (range 30–70). Ipsilateral neck 60 Gy Max dose to chiasma and CNS limited to 54 and 60 Gy, respec, ipsi optic n and retina 60 Gy. | Noncoplanar | Thermoplastic face mask | CTV = pretx GTV and microscopic extension PTV= CTV plus additional uniform 5 mm expansion Ipsi Cx LN in 5 pts; contra Cx LN in 1 pt.
8400 Amosson 2003 | CT | NOMOS. Peacock | 10 MV | Ipsilat and contralat parotids had threshhold limits of 35 Gy and 25 Gy, respectively. (ave mean doses to ipsilat and contralat parotids were 24.2 and 19.1 Gy, respectively) No attempt made to avoid submandibular glands. Sp cd 40 Mandible 58 | | n=13 with “Talon” fixation device n=17 Reinforced Aquaplast mask.
9290 Teh 2002 | | | | Daily fractions of 2.4 and 2 Gy to primary and secondary targets to a total dose of 60 and 50 Gy, respectively. Overall tx course was five weeks (daily tx). Dose to parotids limited- for midline tumors to 25 Gy, for unilateral tumors the ipsilat parotid was limited to 30–35 and contralat 25 Gy.
9330 Kovacs 2002 | | HELAX TMS | 6 MeV | Prescription dose 51.3 Gy with 1.9 Gy/d | | Mask fixation | Planning included pretherapeutic tumor extension and cx LN bilaterally
9510 Jian 2002 | CT | FOCUS (computerized medical systems, Inc., St Louis, MO) | 6MV, 18MV and 9MeV | 40.8–43.2 Gy @ 1.2/frac, 2 frac/day, 6 hr interval betw doses with 6 MV. After 1 wk brk, off-cord 16.8–19.2, 1.2/frac, 2 frac/d with 18MV. Finally, an additional 14.4 Gy in 12 fracs off brnstm. Boost to upper neck by electron beam if necessary. Total dose to primary tumor 74.4 Gy, to involved neck nodes 68–74.4 and to uninvolved neck nodes 50–60 Gy. Dose constraints: Brstm 60–65 Gy Sp cd 50 Gy | | | NPH and upper neck
10740, Pommier et al, 2000 | CT | Elektra linear accelerator w/multileaf collimator | Mixed X-ray 6 to 18 MV | 63.5 Gy (56–68) 2 Gy frac/5 frac wk | 6 to 15 (median 11 ) portals w/multileaf collimation field shaping | Thermoplastic face mask | PTV including CTV plus 5 mm expansion Ipsilateral lymph nodes treated In 7 patients | Palatine prosthesis to protect floor of mouth Dose limited to 12 Gy for contralateral eye, 56 Gy to optic chiasm and contralateral optic nerve, 60 Gy to frontal CNS
11650, Kuppersmith et al., 1999 | CT with contrast | Yes | | 14–71 Gy, 1.5–4.0 Gy/frac, 1 frac/day Dose constraints: Parotid glands 30 Gy | Dynamic multivane collimator, 40 beams | Screws in skull vertex attached top docking device
13270 Lawson 2008 | CT and PET | Eclipse (Varian Medical Systems) | 6 MV | Mean (median, range) total dose to gross dz: 70.14 Gy (70.29, 69.3–70.4). Per fraction to gross dz: 2.13 (2.13, 2.1–2.2). To remainder of clinically involved neck: 61.05 (63.03, 54.4–63.03). Per fraction to clinically invol neck: 1.85 (1.91, 1.7–1.95). Clinically uninvolved neck: 58.34 (57.75, 54.4–63.03). Per fraction to clinically uninvolved neck: 1.77 (1.75, 1.7–1.91). 5 daily fractions per week, to median (range) of 33 fractions (31–35). | | | CTV= PTV + 1–1.5 cm margins.
13340 Ikushima et al, 2008 | CT MRI | Clinac 2100C, Arian Alpatro | 4 and 10 MV | 30 Gy, 2.0 Gy daily frac | Three to five ports with a 1.5 cm margin to CTV
16840, Wu et al, 2006 | CT, MRI | | Electron beam | Simultaneous modulated accelerated RT-GTV, CTV70/2.5 Gy frac, 56/2.0 Gy frac With 28 frac within 6 weeks | IMRT using split-beam technique w/middle and lower neck fields treated with single anterior field joined by CRT Coplanar means positioned every 40 degrees from the posterior and lateral directions | BrainLAB noninvasive thermoplast mask and localizer frame | CTV plus areas of potential microscopic spread including: nasopharynx, retropharyngeal nodes, clivus, skull base, pterygoid fossae, parapharyngeal space, inferior sphenoid sinus, posterior third of the nasal cavity and maxillary sinuses. Included ipsilateral and contralateral neck nodes of level 1,2,3, 5 | Brainstem, spinal cord, parotid glands, and lens specified at risk for inverse planning with different weights.
24330, Pfreunder et al., 2003 | CT | | 5 MV linear accelerator | HnN compartments and lymphatic drainages were irradiated with 50.4 Gy/1.8 frac 5 frac/wk GTV received 2^nd^ 1.4 Gy frac after wk 4 of RT resulting in total 69.9 Gy in 5.5 weeks to GTV and 50.4 total to lymphatic drainage | Static wedge fields | Individualized masks for patient fixation
26140 Scorsetti 2001 | | | 6MV | 1–18 fractions (med 8) at median dose of 30 Gy (range 6–54). Second boost of 10–30 Gy to reduced target volume if good responders. | | | PTV= GTV + 2–10 mm margin.
37660, Wendt et al, 2006 | CT | Mevatron KD2, Siemens Medical Solutions, Germany Inverse planning software: Helax TMS, Nucletron, Europe w/KonRad, Siemens | | 5 frac/wk Median parotid gland dose 30 Gy or less in 37 or 39 patients and less than 26 in 29 patients rng 21–52.8 Gy. | Bilateral 3D-C-IMRT using standard 7-portal arrangement. Each portal modified by # D metallic compensator Lower neck and supraclavicular fossae (region II, IV, IV B) used single anterior field | | Tumors of the nasopharynx, oropharynx, oral cavity, floor of mouth, gross primary tumor bed and lymph node down to the level of hyoid bone were irradiated | Median dose to one parotid gland at aimed at 26Gy or less
38290, Anand et al., 2008 | CT, MRI | Yes (Plato ITPc or Primus) | Photons (6-MV) | Definitive IMRT 66 Gy, 1.9–2.0 Gy/frac, 33–35 frac to CTV1 and 70 Gy, 2.0–2.1 Gy/frac, to GTV for pts receiving CTx 70 Gy, 1.9–2.0 Gy/frac, 35–37 frac for pts receiving IMRT alone Adjuvant IMRT 56–62 Gy toCTV1, 50–54 Gy to CTV2 and CTV3 50–52 Gy to supraclavicular region Dose constraints: Median Dmax Gy (rng) Spinal cord 45 (37–48) Brainstem 51 (33–58) Optic nerve 24 (1–61) Optic chiasm 26 (2–62) Cochlea 42 (0.5–53) Mandible 72 (28–77) | Multileaf collimator or compensators, 7–9 fields Separate low anterior field with midline laryngeal block | Thermoplastic mask for head and neck | GTV = primary tumor volume and metastatic LNs CTV1 = GTV plus 10–12-mm margin CTV2 = ipsilateral high risk but clinically negative LNs CTV3 = contralateral uninvolved LNs CTV1 for adjuvant IMRT included preop GTV and 15–20-mm margin to encompass surgical bed with soft tissue or bone invasion, or metastatic neck node regions with extracapsular extension PTV = CTV1 plus 5-mm margin
38530, Studer et al., 2008 | CT | | | Definitive IMRT 69–72 Gy, 2.0–2.2 Gy/frac, 5 frac/wk Postop IMRT 66 Gy, 2 Gy/frac, 5 frac/wk All schedules based on SIB delivery
38640, Studer et al., 2008 | CT | | | Definitive IMRT 70–73 Gy, 2.1–2.2 Gy/frac, 33–35 frac to boost PTV 73 Gy, 2,2 Gy/frac, 33 frac to large GTVs 70 Gy, 2 Gy/frac, 35 frac in pts with CNS structures in the PTV Adjuvant IMRT 60–66 Gy, 2 Gy/frac, 30–33 frac to boost PTV Elective dose 54 Gy in most pts, 60–66 Gy prescribed for higher risk pts All schedules based on SIB delivery | | | GTV = primary or total gross tumor volume
38840 Seung 2008 | CT | ADAC Pinnacle version 7.4; Phillips/ADAC | 6 MV | SIB Median prescribed dose 69.96 Gy (66–70) to PTV70/66; 59.4 Gy (59.4–60) to PTV59.4; and 54 (54–54.12) to PTV 54. Median dose per frac: 2.12 (2.12–2.2) to PTV70/66; 1.8 (1.8–2.0) to PTV59.4 and 1.64 (1.64–1.8) to PTV54. Normal tissue dose limitation max ≤45 to sp cd, and ≤54 brstm. Mean to parotids ≤26. | 7–9 equally placed coplanar beams | Aquaplast mask | Primary tumor and upper neck above VCs GTV:gross extent of tumor and LNd > 1cm diameter. CTV70:GTV plus margin for potential microscopic spread. CTV59.4 (highrisk CTV):CTV70 + retropharyngeal nodes and levels IB-V on LN positive side. PTV: CTV + margin 0.3–1 cm
38850 Caglar 2008 | | ECLIPSE (Varian Medical Systems) | | IMRT 70 Gy at 2Gy/fraction to GTV, 64 to high-risk CTV, and 60 to low-risk CTV. Post op cases 64 Gy. Parotid glands mean dose 26 Gy. Sp cd dose 46 Gy. | | thermoplastic | GTV: for definitive cases = tumor and involved LNs High-risk CTV for definitive = GTV plus margin for subclinical dz and neck nodal regions at greatest risk of subclinical involvemt. Low risk CTV included uninvolved Cx LNs. PTV: CTV + 5 mm margin.
39000 Sanguineti 2008 | CT | Pinnacle^3^ | 6 MV | Early stage lesions (stage 1–2) hypofractionated schedule. Adv stage dz acc/hyperfrac 78 Gy to PTV1 at 1.3 Gy twice daily. Others rec’d conventional frac at 2 Gy/frac to PTV1. | | Thermoplastic | CTV1=CTV + GTV CTV2=included tissue at high risk of containing microscopic dz. CTV3=included tissue at low risk of microsc dz. PTV1, PTV2 and PTV3 expanded the corresponding CTV by 5mm.
39020 Rosenthal 2008 | | ADAC Pinnacle | | To primary site: 60–63/30 fx n=5 66/30 fx n=79 66–68/33 fx n=5 70/33 fx n=56 72/40 fx (concomitant boost) n=15
39300, Hoppe et al., 2008 | CT, MRI | Yes (MSKKC system) | Photons (6-MV) | 70 Gy, 2.1 Gy/frac to PTV1 60 Gy, 2 Gy/frac to PTV2 54 Gy, 1.8 Gy/frac to PTV3 54 Gy to involved neck All treated once daily, 5 days/wk Dose constraints: Brainstem < 50 Gy Spinal cord < 45 Gy Cochlea < 50 Gy Retina/eye < 45 Gy Optic nerve < 54 Gy Optic chiasm < 54 Gy | Dynamic multileaf collimator with dynamic leaf sequencing | Custom Aquaplast mask that also immobilizes shoulders when neck is treated | CTV1 = clinical tumor volume included gross disease with 3–5-mm margin CTV2 = surgical bed and areas at high risk of microscopic disease CTV3 = LN regions at risk PTV1, 2, 3 = CTV 1, 2, 3 plus 5–10-mm margin, expanded 1-mm in areas adjacent to critical normal structures Bilateral or ipsilateral neck irradiation for involved LNs
39390, Worden et al., 2008 | CT, PET | | | 70 Gy, 2 Gy/frac daily, 5 frac/wk to gross disease and 10–20-cm margins 59–63 Gy, 1.7–1.8 Gy/frac to tissue volumes at risk of harboring subclinical disease | | | Gross tumor volume plus 10–20-cm margins Bilateral neck

### Single-Arm Studies

Table E-D Outcome assessment

Study | Primary Outcomes | Secondary Outcomes | Tumor Response Criteria | Independent Response Assessor | F/U Frequency/Duration
560, Biagioli et al., 2007 | Tumor response, DFS, PFS, OS, LRRFS | Acute and late toxicities | CR = NED after tx PR = ≥ 50% reduction of tumor SD = < 50% reduction to 25% enlargement of tumor PD = > 25% tumor enlargement | | med 14 mos. (rng 1–53 mos.)
580, Dirix et al., 2007 | 2-yr LC, OS, DFS Acute and late toxicities, in particular ocular | | | | Baseline, every 2 mos. in first 2 yrs, every 3 mos. in third yr, every 4 mos. in fourth yr, every 6 mos. in fifth yr, annually thereafter med 24 mos. (rng 7–47 mos.)
1010, Urbano et al., 2007 | Acute and late toxicities, in particular laryngeal | Tumor control | CR: No evidence of disease (clinical, radiographic, or pathologic | | Acute toxicity: 2.5 mos. after commencement of CRTx (1.5 mos. of Tx plus 1 mo after) and at wk 14 ( 2mos. post Tx) Late toxicity: 3, 6, 12, 18, 24 mos, yearly thereafter Tumor response: 1–1.5 mos. post-Tx
1420 Feng et al, 2007 | Dysphagia measures | Patient-reported QoL Acute and late observer-assessed toxicity | | | Baseline, weekly during therapy, 1 (acute) and 3 (late) mos. after therapy
1430, Scrimger et al., 2007 | Salivary function, QoL | QoL, late salivary gland and other toxicities
1500, Lee et al., 2007 | 2-yr LPFS, LRPFS, RPFS, DMFS, OS, laryngectomy-free survival | Tracheostomy tube placement, acute and late toxicities | | | Weekly during treatment, every 1–2 mos. for first 2 yrs, every 4–6 mos. thereafter
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | LRFS, RRFS, DMFS, OS | | | | 1 mo after treatment, every 1.5–2 mos. for first yr, every 2–3 mos. in second yr med 29 mos. (rng 0.2–74 mos.)
1780, Lee et al., 2007 | 2-yr LRPFS | | | | Baseline, every 1–2 mos. post-RT for first 2 yrs, then every 4–6 mos med 35 mos (rng 2–80 mos.)
1900, Ben-David et al., 2007 | Mandibular osteoradionecrosis (ORN) | | | | Every 1.5–2 mos. during first 2 yrs after therapy, every 3–4 mos. thereafter
1990, Yao et al., 2007 | OS, DSS, LRFS, LRRFS, DMFS | | | | 1 mo post-RT, every 1.5–2 mos. in first yr, every 2–3 mos. in second yr med 17 mos. (rng 0.3–59 mos.)
2180, Daly et al., 2007 | OS. LPFS, DFS | Acute and late toxicities | | | Every 1–2 mos. for first 6 mos. post RT, every 3 mos. for next 6–12 mos, every 4–6 mos. from 18–36 mos, annually thereafter med 39 mos. (rng 6–82 mos.)
2290, Yao et al., 2006 | OS, LPFS, LRC, DMFS, DFS | Acute and late toxicities | | | 1 mo post RT, every 1.5–2 mos. in the first yr, every 2–3 mos. in the second yr
2370, Garden et al., 2007 | OS, LRC, RFS | Acute and late toxicities | | | med 45 mos. (rng 15–63 mos.)
2430, Vosmik et al., 2006 | Acute toxicities
2770, Cheng et al., 2006 | 5-yr LRC, DMFS, OS | | | | med 58 mos
3080 Meirovitz 2006 | XST SLF | | | | At 6–24 months (median 12 mos.) after completion of therapy same
3320, Portaluri et al., 2006 | Xerostomia | | | | med 18 mos. (rng 16–19 mos.)
3340 Studer 2006 | LC Distant control Nodal control Overall DFS | SKN MUC DYS LX SPN QOL (weight loss) | | | Mean 16 months (4–44 months) During treatment, pts clinically assessed at weekly intervals, and at 2 weeks and 2 months after completion of treatment.
3400 Studer, 2006 | ORN | LRC
3570 Saarilahti 2006 | XST and SLF | MUC LRC | | | XST: 2–3 month intervals after IMRT SLF: measured before therapy (baseline), and 6 and 12 months after last date of RT. LRC: median F/U 31 months (14–62 mos.)
3790, Ozsahin et al., 2006 | Acute and late toxicities | OS, LRC, | | | med 36 mos. (rng 8–37 mos.)
3820 McMillan 2006 | QoL SLF XST | | | | SLF assessed baseline, then 2,6, and 12 months after IMRT.
4290, Lau et al., 2006 | OS, DSS, LRRFS | Acute toxicities | CR according to physical examination with or w/out imaging | | Every mo during first yr, every 2 mos. in second yr, every 3–4 mos. in third yr med 16 mos
4430 Kwong 2006 | LRC MFS PFS OS | MUC SKN | | | Median follow-up 25 months (3–55.5 months) Assessed weekly during treatment. At 6 and 8 weeks after completion of IMRT, biopsied to assess dz remission. After IMRT completion, f/u q month during 1^st^ yr, q 2 mos. during 2^nd^ yr, then q 3–6 mos. afterwards.
4630 Yao | LC LRC MFS OS | | | | Median time from tx completion to LR recurrence was 4.7 mos. (1.8–15.6 mos.)
5020, Nishimura et al., 2005 | Xerostomia and parotid dose volume
5120, Wolden et al., 2006 | 3-yr LC, LRC, MFS, PFS, OS | Other acute and late toxicities | | | Median follow up 35 mos. (3–74)
5210, Duthoy et al., 2005 | OS, DFS, DSS, LC | Toxicity
5310, Zheng et al., 2005 | OS, LFFS | Major late toxicities | | | med 35 mos. (rng 9–71 mos.)
5330, Lu et al., 2005 | LC, LRC, DFS, OS | Acute and late toxicities | PCR defined as no evidence of malignant cells in tumor bed biopsy 4 mos. after completion of RT | | Every 2–3 mos. for first 3 yrs post RT, every 4–6 mos. for next 2 yrs, annually thereafter med 24 mos. (rng 15–31 mos.)
5420, Pan et al., 2005 | Hearing loss | | | | Baseline, 1, 6, 12, 24, 36 mos
5740, Thorstad et al., 2004 | Salivary function | Acute nonhematologic toxicities | | | Baseline, 6 mos, 12 mos
6430, Kwong et al, 2004 | Salivary Function | Dose Volume | | | Weekly during RT, 6–8 wks after RT completion. Every month of 1^st^ year, every 2 months 2^nd^ year, 3–6 mo thereafter
6530 Zheng 2004 | LFFS (local failure free survival) DSS OS | Radiation induced toxicities | | | After salvage tx completion, q 2–3 months for first 2 yrs, then q 4–6 mos. thereafter. Median f/u58 mos. (12–95)
7090, Chao et al., 2004 | DMFS, LRC, DFS, Gross tumor volume | Toxicity
7110, Sze et al., 2004 | LFFS, PFS, OS | | | | med 23 mos. (rng 1–47 mos.)
7370, Lu et al., 2004 | LRC | Acute toxicities | | | med 9 mos. (rng 3–13 mos.)
7570, Levendag et al., 2004 | 3-yr RRFS, LRRFS, OS, DFS | | | | med 29 mos
7750, Liu et al., 2003 | OS, DFS, DSS | Acute and late toxicities | | | Every 1–2 mos. post-RT for first yr, every 3 mos. for second yr, every 6 mos. thereafter med 17 mos. (rng 3–42 mos.)
8250, Munter et al., 2003 | 2-yr OS, LC | Acute and late toxicities | | | 1.5 mos. post-RT, every 3 mos. for first yr, every 6 mos. thereafter med 14 mos. (rng 3–34 mos.)
8270 Braaksma 2003 | SLF XST | LRC DFS OS | | | Median f/u 18 mos. (2.4–39.6)
8370 Padovani 2003 | PFS OS | Acute and late toxicities | | | Med f/u 25 mos. (4–51 mos.) Note: ?? should we abstract the number of local relapses??
8400 Amosson 2003 | XST
9290 Teh 2002 | QOL TAE XST | | | | Median f/u 11.5 months
9330 Kovacs 2002 | Toxicities and survival
9510 Jian 2002 | LRC DFS OS | acute toxicity (MUC and QOL incl weight loss) | | | q 2 mos. 1^st^ 2 yrs q 3–6 mos. yrs 3–5 and 1 yr intervals thereafter
10740, Pommier et al, 2000 | OS, LPFS, LPFR, | Toxicity
11650, Kuppersmith et al., 1999 | Acute toxicity
13270 Lawson 2008 | LC LRC MFS OS | Acute and late toxicities (MUC, ESO, LAR, sal gl, SKN, SUB, blood cnt) | | | Mean (median, range) 22.2 mos. (20.1, 3.6–42.8) F/U 1 month p tx, then q 1–3 mos.
13340 Ikushima et al, 2008 | SR, cause of death | Toxicity
16840, Wu et al, 2006 | Local regional FS, OS | Toxicity
24330, Pfreunder et al., 2003 | OS, LTC, larynx preservation | Toxicity
26140 Scorsetti 2001 | OS TAE
37660, Wendt et al, 2006 | RTOG toxicity | | | | Median FU 21 mo
38290, Anand et al., 2008 | 2-yr LRC, OS | Acute and late toxicities | | | Baseline, 3 mos, 6 mos med 19 mos. (rng 6–36 mos.)
38530, Studer et al., 2008 | LC, DSS, DFS | | | | med 21 mos. (rng 3–67 mos.)
38640, Studer et al., 2008 | 3-yr LC, LRC, DFS, OS, DMFS | | | | med 20 mos. (rng 3–72 mos.)
38840 Seung 2008 | LC OS Cause specific survival (CSS) | Acute and late toxicities | | | p RT, q 2–3 mos. for first 2 yrs, then q 3–6 mos. thereafter.
38850 Caglar 2008 | DYS | Aspiration (*I did not abstract this intermediate outcome) | | | Median 10 mos
39000 Sanguineti 2008 | Local and regional failure LC LRC | | | | Q 2–3 mos. dur 1^st^ 2 yrs, then q 3–4 mos. dur yrs 3–5.
39020 Rosenthal 2008 | Acute toxicities
39300, Hoppe et al., 2008 | 2-yr LPFS, OS | Acute and late toxicities | | | 1–2 mos. post-RT, every 3 mos. for the next 3 yrs, annually thereafter med 28 mos. (rng 11–57 mos.)
39390, Worden et al., 2008 | Tumor response, DSS, OS | Acute and late toxicities | Biopsy-proven residual disease | | 2 mos. post-RT for initial assessment med 64 mos

Table E-E Time to event outcomes

Study | Outcome | Grp | N | Med (mos.) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
560, Biagioli et al., 2007 | OS | | 41 | 18 | 77 | 49 | ~ 40 | ~ 34
560, Biagioli et al., 2007 | OS w/CR | | 24 | 33
560, Biagioli et al., 2007 | OS w/PR | | 7 | 12
560, Biagioli et al., 2007 | OS w/SD | | 4 | 12
560, Biagioli et al., 2007 | OS w/PD | | 6 | 7
560, Biagioli et al., 2007 | OS w/resect | | 17 | 31 | ~ 77 | ~ 66 | ~ 66 | ~ 66 | | M-C | 0.14
560, Biagioli et al., 2007 | OS w/out resect | | 24 | 23 | ~ 69 | ~ 36 | ~ 28 | ~ 18
560, Biagioli et al., 2007 | OS + cisplatin OS + | | 15 | 32 | ~ 70 | ~ 63 | ~ 48 | ~ 48 | | M-C | 0.17
560, Biagioli et al., 2007 | carboplatin OS | | 26 | 13 | ~ 44 | ~ 39 | ~ 39 | ~ 29
560, Biagioli et al., 2007 | w/induction CTx | | 13 | 13 | ~ 60 | ~ 37 | ~ 37 | | | M-C | 0.4
560, Biagioli et al., 2007 | OS w/out induction Ctx | | 28 | 19 | ~ 70 | ~ 44 | ~ 34
560, Biagioli et al., 2007 | DFS (CR only) | | 24 | 27 | ~ 60 | 48 | ~ 48 | ~ 48
560, Biagioli et al., 2007 | PFS (CR only) | | 24 | 11 | ~ 42 | 38 | ~ 38 | ~ 38
580, Dirix et al., 2007 | LC | | 25 | nr | ~ 88 | 81 | ~ 80
580, Dirix et al., 2007 | DFS | | 25 | nr | ~ 85 | 77 | ~ 78
580, Dirix et al., 2007 | OS | | 25 | nr | ~ 93 | 88 | ~ 88
580, Dirix et al., 2007 | DMFS | | 25 | nr | | 88
1010, Urbano et al., 2007 | OS | DL1 | 15 | 17 (12–37)
1010, Urbano et al., 2007 | OS | DL2 | 15 | 8 (1–14)
1010, Urbano et al., 2007 | TTR | DL1/DL2 | 30 | 9 (6–13)
1420 Feng et al, 2007
1430, Scrimger et al., 2007
1500, Lee et al., 2007 | LPFS | | 31 | | ~88 | 86 | 86 | 86 | 86
1500, Lee et al., 2007 | LRPFS | | | | 84 | 84 | 84 | 84
1500, Lee et al., 2007 | RPFS | | | | | | 94
1500, Lee et al., 2007 | DMFS | | | | | | 92
1500, Lee et al., 2007 | OS | | | | | | 63
1500, Lee et al., 2007 | OS | larynx pts | 20 | | ~84 | 69 | 69
1500, Lee et al., 2007 | | hypopharynx | 11 | | ~82 | 53 | 53 | 53
1500, Lee et al., 2007 | laryngectomy-FS | | | | ~92 | 89 | 89 | 89
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | LRFS | | 90 | | ~98 | 96 | 96 | ~96 | ~96
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | RRFS | | 90 | | ~95 | 95 | 95 | ~95 | ~95
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | DMFS | | 90 | | ~88 | 82 | 80 | ~80 | ~80
1770, Yao et al., 2007 (see 4630, Yao et al., 2005) | OS | | 90 | | ~88 | 80 | 68 | ~68 | ~68
1780, Lee et al., 2007 | 2-yr LRPFS | IMRT | | 28 | | 52 | | | | L-R | < 0.001 | | Not comparative study but gave separate data for IMRT and non-IMRT
1780, Lee et al., 2007 | 2-yr LRPFS | non-IMRT | | ~4 | | 20 | | | | L-R | < 0.001 | | Not comparative study but gave separate data for IMRT and non-IMRT
1900, Ben- David et al., 2007
1990, Yao et al., 2007 | OS | | 55 | | ~70 | 68 | 68 | 68 | 68
1990, Yao et al., 2007 | DSS | | 55 | | ~75 | 74 | 74 | 74 | 74
1990, Yao et al., 2007 | LRFS | | 55 | | ~85 | 85 | 85 | 85 | 85
1990, Yao et al., 2007 | LRRFS | | 55 | | ~84 | 82 | 82 | 82 | 82
1990, Yao et al., 2007 | DMFS | | 55 | | ~94 | 89 | 89 | 89 | 89
2180, Daly et al., 2007 | OS | | 36 | ~48 | ~100 | 69 | ~69 | ~45 | 45
2180, Daly et al., 2007 | LPFS | | 36 | ~48 | ~84 | 62 | ~62 | ~58 | 58
2180, Daly et al., 2007 | DFS | | 36 | ~48 | ~84 | 62 | ~60 | ~60 | 55
2290, Yao et al., 2006 | OS | | 66 | | ~96 | 91 | 78 | ~80 | ~80
2290, Yao et al., 2006 | LPFS | | 66 | | ~98 | 98 | 92 | ~92 | ~92
2290, Yao et al., 2006 | LRC | | 66 | | ~98 | 98 | 92 | ~92 | ~92
2290, Yao et al., 2006 | DMFS | | 66 | | ~87 | 88 | 80 | ~80 | ~80
2290, Yao et al., 2006 | DFS | | 66 | | ~92 | 84 | 64 | ~64 | ~64
2370, Garden et al., 2007 | OS | | 51 | | 100 | 93 | 87 | 87 | ~80
2370, Garden et al., 2007 | LRC | | 51 | | ~95 | 93 | 93 | 93 | 93
2370, Garden et al., 2007 | RFS | | 51 | | ~93 | 87 | 84 | ~82 | ~82
2430, Vosmik et al., 2006
2770, Cheng et al., 2006 | LRC | overall | 630 | | | | | | 89
2770, Cheng et al., 2006 | LRC | T1 dis | 155 | | ~98 | 96 | ~96 | ~95 | 95 | L-R | 0.001
2770, Cheng et al., 2006 | LRC | T2 dis | 163 | | ~98 | 97 | ~96 | ~96 | 91
2770, Cheng et al., 2006 | LRC | T3 dis | 140 | | ~98 | 92 | ~91 | ~90 | 87
2770, Cheng et al., 2006 | LRC | T4 dis | 172 | | ~96 | 91 | ~92 | ~85 | 81
2770, Cheng et al., 2006 | LRC | < 40 yrs | 223 | | ~98 | 97 | ~96 | ~95 | 93 | L-R | 0.018
2770, Cheng et al., 2006 | LRC | > 40 yrs | 407 | | ~95 | 93 | ~90 | ~88 | 87
2770, Cheng et al., 2006 | LRC | WHO I, II | 148 | | ~92 | 89 | ~85 | ~82 | 81 | L-R | 1E-04
2770, Cheng et al., 2006 | LRC | WHO III | 482 | | ~98 | 96 | ~94 | ~92 | 91
2770, Cheng et al., 2006 | LRC | LDH < 410 | 548 | | ~98 | 95 | ~93 | ~92 | 91 | L-R | 3E-04
2770, Cheng et al., 2006 | LRC | LDH > 410 | 82 | | ~95 | 89 | ~85 | ~81 | 75
2770, Cheng et al., 2006 | LRC | AG2 < 2 sites | 373 | | ~98 | 96 | ~95 | ~94 | 93 | L-R | < 0.0001
2770, Cheng et al., 2006 | LRC | AG2 > 2 sites | 257 | | ~95 | 91 | ~89 | ~83 | 81
2770, Cheng et al., 2006 | LRC | RS0 (low) | 96 | | ~100 | 100 | ~100 | ~100 | 100 | L-R | < 0.0001
2770, Cheng et al., 2006 | LRC | RS1 (int-low) | 266 | | ~98 | 96 | ~95 | ~95 | 93
2770, Cheng et al., 2006 | LRC | RS2 (int-high) | 184 | | ~98 | 94 | ~91 | ~87 | 83
2770, Cheng et al., 2006 | LRC | RS>3 (high) | 84 | | ~90 | 81 | ~78 | ~73 | 71
2770, Cheng et al., 2006 | MFS | RS0 (low) | 96 | | ~98 | 97 | ~97 | ~95 | 95 | L-R | 0.002
2770, Cheng et al., 2006 | MFS | RS1 (int-low) | 266 | | ~95 | 88 | ~86 | ~86 | 85
2770, Cheng et al., 2006 | MFS | RS2 (int-high) | 184 | | ~95 | 85 | ~81 | ~80 | 78
2770, Cheng et al., 2006 | MFS | RS>3 (high) | 84 | | ~88 | 81 | ~78 | ~76 | 73
2770, Cheng et al., 2006 | OS | RS0 (low) | 96 | | ~100 | 100 | ~98 | ~96 | 94 | L-R | < 0.0001
2770, Cheng et al., 2006 | OS | RS1 (int- low) | 266 | | ~98 | 93 | ~89 | ~88 | 87
2770, Cheng et al., 2006 | OS | RS2 (int-high) | 184 | | ~96 | 93 | ~86 | ~83 | 76
2770, Cheng et al., 2006 | OS | RS>3 (high) | 84 | | ~90 | 83 | ~70 | ~63 | 63
3320, Portaluri et al., 2006
3340, Studer, 2006 | Local DFS | | | | ~90 | 90 | ~90
3340, Studer, 2006 | Regional DFS | | | | ~93 | 93 | ~93
3340, Studer, 2006 | Distant DFS | | | | ~93 | 93 | ~93
5120, Wolden et al., 2006 | LC | IMRT | 74 | 35 | ~95 | ~93 | 91 | ~91 | ~84 | | .11 | | P=.11
5120, Wolden et al., 2006 | LC | 3DCRT | 35 | 35 | ~95 | ~82 | 79 | ~74 | ~74 | | .11 | | P=.11
5120, Wolden et al., 2006 | LRC | IMRT | | 35 | | | 78 | | | | | | P=.11
5120, Wolden et al., 2006 | MFS | IMRT | | 35 | | | | | | | | | P=.11
5120, Wolden et al., 2006 | PFS | IMRT | | 35 | | | 67 | | | | | | P=.11
5120, Wolden et al., 2006 | OS | IMRT | | 35 | ~97 | ~87 | 83 | ~79 | 73 | | | | P=.11

Table E-F Time to event outcome regression modeling

Study | Design/Outcome/Model | Candidate predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
4290, Lau et al., 2006 | OS | age, initial Hb, KPS, % CTX (< 50%, > 50%), T, N, overall stage, tumor site | age, initial Hb, < 50% CTx, T, N stage (< 0.07, 2- tailed) | age, initial Hb, KPS, % CTx, T, N, overall stage | | CTX, N stage (<0.07, 2- tailed)
4290, Lau et al., 2006 | LRRFS | same | age, KPS, CTX, T, N stage (< 0.07. 2- tailed) | age, initial Hb, KPS, % CTx, T, N, overall stage | | CTX, N stage (<0.07, 2- tailed)
5020, Nishimura et al., 2005 | Dose to parotid correlated w/incidence of Xerostomia grade Mean and median parotid dose decreased significantly from CT1CT2 | Initial Volume of parotid glands CT-1 43.1+ or − 15.2 ml CT-2 (3–4 wks of IMRT) 32 + or − 11.4ml | 0.04 P<0.0001 (regression rate of parotid glands not significantly correlated w/grade of xerostomia p=.186)
5310, Zheng et al., 2005 | OS LFFS | age, sex, histo, mn dose primary RT, vol irrad primary RT, T stage, GTV local recurrence, int initial RT to dx recur, late tox from prev RT, CTx, simultan RR | T stage, GTV (< 0.01) | same | | T stage (< 0.01)
6430, Kwong et al, 2004
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | Gender | .7, .5, .9 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | DFS: | | Standard Error
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | Subsite | .5, .6, .6 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | GTV .03 | | 0.01
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | IMRT(Postop/Definitive) | .02, .07, .2 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | nGTV .05 | | 0.03
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | Chemotherapy | .6, .7, .8 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | LRC
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | T stage | .14, .4, .2 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | GTV .03 | | 0.07
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | Nodal status | .56, .4, .9 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | nGTV .01 | | 0.01
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | AJCC stage | .2, .3, .4 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | DMFS
7090, Chao et al., 2004 | Univariate analysis of 4 yr estimate DFS, LRC, DMFS | Fraction size | .14, .5, .2 | Definitive IMRT Group DFS, LRC, DMFS | Gross tumor volume, nodal gross tumor volume | GTV .03 | | 0.009

Table E-G Tumor response

Study | Group | N | CR | PR | SD | PD | NE | Test | p | Comments
560, Biagioli et al., 2007 | | 41 | 24(58) | 7(17) | 4(10) | 6(15)
1010, Urbano et al., 2007 | DL1 DL2 | 15 15 | 80 87
4290, Lau et al., 2006 | | 56 | 82
4430 Kwong 2006 | | | | | | | | | | 2 pts had persistent NP disease after IMRT. (both received salvage stereotactic radiosurgery – 1 remained well, 1 died of progressive local dz) 3 pts relapsed 14–37 mos. after dx and all died of progressive dz.
4630 Yao | | | | | | | | | | 11 LR failures 7 local failures 3 regional failures 1 failure at both the primary and reg LN 16 patients failed distantly
5330, Lu et al., 2005 | | 25 | 96
7370, Lu et al., 2004 | | 49 | 100(at 3 mo f/u)
8370 Padovani 2003 | 3DRT | | | | | N=2 during RT
9290 Teh 2002 | | | n=25 (89%) | n=3 (11%)
38840 Seung 2008 | All | 69 | | | | | | | | Of 69, 1 had persistent local dz after tx.
39390, Worden et al., 2008 | CRT | 53 | 92 | | | 8

Table E-H Quality of life

Study | Scale | Domain | F/U | Group | Mos. | n | mn±sd | Comments
1420 Feng et al, 2007 | UWQOL | 1 swallowing question w/5 answers | Pre-RT, 3mos | Overall | | 36 | Med10 (rng 10–30), 20 (10–50) | P<0.001
1420 Feng et al, 2007 | HNQOL | 2 questions related to dysphagia with 5 answers each | Pre-RT, 3mos | Liquids | | 36 | Med 0(rng 0–3), 1 (0–3) | P<0.001
1420 Feng et al, 2007 | HNQOL | 2 questions related to dysphagia with 5 answers each | Pre-RT, 3mos | Solids | | 36 | Med 0 (rng 0–3), 2 (0–4) | P<0.001
1430, Scrimger et al., 2007 | UWQOL | 9 health-related questions, total score reported | Pre-RT, 3, 6, 12 mos | NPH | | 10 | 92.5, 77.5, 82.0, 78.5
1430, Scrimger et al., 2007 | UWQOL | 9 health-related questions, total score reported | Pre-RT, 3, 6, 12 mos | OPH | | 9 | 71.0, 73.0, 71.0. 78.0
1430, Scrimger et al., 2007 | UWQOL | 9 health-related questions, total score reported | Pre-RT, 3, 6, 12 mos | OC | | 20 | 73.0, 76.0, 76.5, 79.0
1430, Scrimger et al., 2007 | UWQOL | 9 health-related questions, total score reported | Pre-RT, 3, 6, 12 mos | LAR | | 6 | 83.5, 85.0, 86.5, 85.5
1430, Scrimger et al., 2007 | UWQOL | 9 health-related questions, total score reported | Pre-RT, 3, 6, 12 mos | UKP | | 2 | 80.5, 79.5, 83.0, 82.5
1430, Scrimger et al., 2007 | UWQOL | 9 health-related questions, total score reported | Pre-RT, 3, 6, 12 mos | All pts | | 47 | ~79, ~76, ~78, 80
1430, Scrimger et al., 2007 | Xerostomia QOL | 9 questions related to oral moisture, total score reported | Pre-RT, 3, 6, 12 mos | All pts | | 47 | ~.6, ~ 1.4, ~1.4, ~1.2
1430, Scrimger et al., 2007 | RTOG late xerostomia score | 0–5 scale total score | Pre-RT, 3, 6, 12 mos | All pts | | 47 | 0, ~1.2, ~1.0, ~1.0
3340 Studer 2006 | SOMA-LENT and RTOG/EORTC radiation morbidity score used to assess toxicity. | | | | | | | Feeding tube inserted in 9 patients (30%). Mean body weight loss at 1 yr after tx was 3.3% (+11% to −11%)
3820 McMillan 2006 | Medical outcomes short form (SF- 36) Scale of 0–100 (higher score better health status) | | | | BL, 2, 6, 12 | 32 | Mean (SD) BL, 2 mo, 6 mo, 12 mo/p value all 4 visits, BL vs. 2 mo, BL vs. 6 mo, BL vs. 12 mo Physical function 94.4 (9.0) 89.4 (6.3) 92.3 (6.2) 92.7 (8.6) <.001 .001 .028 .190 Role—physical 64.8 (35.3) 32.0 (38.2) 55.5 (41.5) 72.7 (40.3) <.001 .001 .291 .330 Bodily pain 88.2 (20.3) 75.6 (26.9) 84.6 (20.0) 81.1 (28.3) .387 .023 .498 .166 General health 57.2 (21.1) 48.3 (19.4) 52.7 (22.5) 62.0 (23.3) .014 .049 .163 .172 Vitality 72.7 (16.8) 55.9 (20.2) 64.4 (18.9) 67.7 (19.6) .006 .001 .012 .138 Social functioning 82.4 (24.4) 71.5 (26.8) 89.1 (19.8) 89.5 (19.9) .001 .049 .123 .085 Role—emotional 61.5 (38.0) 52.1 (47.1) 71.9 (40.7) 78.1 (37.5) .009 .462 .207 .073 Mental health 71.0 (17.7) 75.1 (19.1) 77.25 (16.8) 80.3 (19.0) .089 .121 .073 .036
3820 McMillan 2006 | EORTC QLC-30 questionnaire Scale of 0–100 (higher score higher/healthier level of functioning) | | | | BL, 2, 6, 12 | 32 | Mean (SD) BL, 2 mo, 6 mo, 12 mo/p value all 4 visits, BL vs. 2 mo, BL vs. 6 mo, BL vs. 12 mo [underlined: Global health status/QOL] Global health status 55.5 (19.6) 54.7 (15.4) 65.9 (19.6) 67.2 (20.3) .001 .989 .004 .004 Global health status(revised) 57.6 (18.9) 54.9 (13.4) 65.6 (18.2) 66.7 (19.6) .011 .474 .013 .006 [underlined: Functional scales] Physical functioning (revised) 92.7 (9.5) 83.3 (7.2) 88.5 (9.6) 89.6 (10.7) <.001 <.001 .027 .082 Role functioning 97.9 (7.0) 92.7 (10.3) 94.3 (10.0) 96.4 (8.2) .004 .002 .020 .180 Role functioning (revised) 85.9 (15.3) 81.3 (16.8) 90.1 (14.0) 92.2 (13.4) .008 .112 .290 .089 Emotional function 80.5 (15.5) 86.5 (12.3) 87.8 (15.0) 88.8 (15.2) .097 .036 .034 .014 Cognitive function 86.5 (15.5) 83.9 (19.2) 83.3 (13.4) 85.9 (16.5) .729 .533 .530 1.000 Social function 82.8 (21.8) 77.1 (21.5) 91.1 (13.4) 90.6 (16.9) <.001 .118 .016 .095 [underlined: Symptom scales] Fatigue 14.2 (15.5) 25.7 (17.3) 16.0 (13.5) 14.9 (16.6) <.001 .002 .479 .743 Nausea/vomiting 3.1 (6.6) 7.8 (15.3) 1.0 (4.1) 1.0 (4.1) .032 .101 .157 .157 Pain 7.8 (12.7) 8.3 (14.0) 8.3 (12.0) 7.3 (16.4) .685 .715 .793 .593 [underlined: Symptom items] Dyspnea 10.4 (17.8) 10.4 (19.7) 9.4 (15.2) 8.3 (14.7) .949 1.000 .763 .593 Insomnia 24.0 (31.9) 15.6 (23.9) 13.5 (23.7) 13.5 (20.5) .141 .118 .049 .062 Appetite loss 15.6 (20.7) 24.0 (22.8) 6.3 (13.2) 5.2 (12.3) <.001 .103 .013 .008 Constipation 5.2 (12.3) 8.3 (14.7) 6.3 (13.2) 9.4 (19.4) .447 .180 .655 .157 Diarrhea 5.2 (12.3) 2.1 (8.2) 9.4 (17.4) 7.3 (14.0) .120 .180 .248 .527 Financial difficulties 17.7 (25.4) 12.5 (20.3) 7.3 (14.0) 6.3 (15.7) .012 .218 .019 .005
3820 McMillan 2006 | EORTC QLQ- H&N35 Score of 1–100 (higher score higher/healthier level of functioning) | | | | BL, 2, 6, 12 | 32 | Mean (SD) BL, 2 mo, 6 mo, 12 mo/p value all 4 visits, BL vs. 2 mo, BL vs. 6 mo, BL vs. 12 mo Pain 8.3 (9.0) 18.5 (14.3) 14.8 (11.9) 9.1 (12.2) .001 <.001 .016 .797 Swallowing 1.6 (3.3) 11.5 (9.6) 9.6 (7.7) 9.6 (9.3) <.001 <.001 <.001 <.001 Senses problem 6.7 (15.2) 42.2 (22.4) 25.0 (18.5) 17.7 (19.8) <.001 <.001 .002 .048 Speech problem 6.3 (10.2) 12.8 (15.5) 11.1 (10.6) 8.7 (12.5) .006 .010 .008 .129 Trouble social eating 2.3 (6.1) 20.1 (16.0) 12.5 (12.5) 9.4 (11.3) <.001 <.001 <.001 .006 Trouble social contact 1.5 (5.3) 8.3 (11.0) 5.0 (7.4) 3.1 (7.8) <.001 .001 .003 .044 Less sexuality 16.1 (19.7) 35.1 (36.1) 23.0 (26.9) 25.0 (30.6) .017 .001 .194 .087 Teeth 5.2 (12.3) 9.7 (17.6) 8.3 (14.7) 9.4 (15.2) .712 .285 .366 .102 Open mouth 0.0 (0.0) 9.4 (15.2) 17.7 (18.9) 10.4 (15.7) <.001 .003 <.001 .002 Dry mouth 13.5 (20.5) 82.3 (20.7) 64.6 (26.7) 47.9 (29.3) <.001 <.001 <.001 <.001 Sticky saliva 4.2 (11.2) 63.9 (38.0) 40.7 (31.1) 34.6 (25.3) <.001 <.001 <.001 <.001 Coughing 19.8 (20.5) 14.6 (20.6) 11.5 (21.8) 10.4 (15.7) .742 .766 .315 .479 Felt ill 6.3 (13.2) 8.3 (14.7) 5.2 (12.3) 6.3 (13.2) .767 .068 .436 .238 Pain killers 9.4 (29.6) 0.0 (0.0) 12.5 (33.6) 3.1 (17.7) .141 .083 .655 .317 Nutrition supplement 18.8 (39.7) 28.1 (45.7) 25.0 (44.0) 25.0 (44.0) .809 .317 .564 .564 Feeding tube 0.0 (0.0) 0.0 (0.0) 0.0 (0.0) 0.0 (0.0) - - - - Weight loss 31.2 (47.1) 40.6 (49.0) 12.2 (33.6) 9.4 (29.6) .005 .467 .083 .020 Weight gain 15.6 (36.9) 15.6 (36.9) 21.9 (42.0) 40.6 (49.9) .050 1.000 .480 .033
9290 Teh 2002 | RTOG | | | | | | | 23 of 28 pts (82%) lost 10% or less of pre-tx weight. 13 of 28 (46%) required IV fluids and/or tube-feeding.
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP | | 31 | Grade 1 32.3%
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP | | 31 | Grade 2 22.6%
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP | | 31 | Grade 3 0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP | | 31 | Grade 4 0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP/5-FU | | 17 | Grade 1 17.6
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP/5-FU | | 17 | Grade 2 47.1
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP/5-FU | | 17 | Grade 3 0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Weight loss | Concomitant phase | CDDP/5-FU | | 17 | Grade 4 0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP | | 31 | Grade 1 25.8
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP | | 31 | Grade 2 35.5
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP | | 31 | Grade 3 6.5
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP | | 31 | Grade 4 3.2
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP/5-FU | | 17 | Grade 1 23.5
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP/5-FU | | 17 | 2 52.9
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP/5-FU | | 17 | 3 11.8
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Concomitant phase | CDDP/5-FU | | 17 | 4 0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP | | 28 | 1 25.0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP | | 28 | 2 25.0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP | | 28 | 3 7.1
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP | | 28 | 4 7.1
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP/5-FU | | 16 | 1 37.5
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP/5-FU | | 16 | 2 25.0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP/5-FU | | 16 | 3 0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Vomiting | Adjuvant phase | CDDP/5-FU | | 16 | 4 0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP | | 31 | 1 35.5/48.4/16.1
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP | | 31 | 2 22.6/9.7/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP | | 31 | 3 0/3.2/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP | | 31 | 4 0/0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP/5-FU | | 17 | 1 35.3/47.1/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP/5-FU | | 17 | 2 5.9/11.8/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP/5-FU | | 17 | 3 0/0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Concomitant phase | CDDP/5-FU | | 17 | 4 0/0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP | | 28 | 1 10.7/50.0/21.4
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP | | 28 | 2 42.9/25.0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP | | 28 | 3 7.1/0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP | | 28 | 4 0/0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP | | 28
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP/5-FU | | 16 | 1 31.3/50.0/18.8
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP/5-FU | | 16 | 2 31.3/6.3/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP/5-FU | | 16 | 3 0/0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Leukopenia/Hb/Plt | Adjuvant phase | CDDP/5-FU | | 16 | 4 0/0/0
9510 Jian 2002 | NCI toxicity criteria 1–4 | Tube feeding rate | Concomitant phase | CDDP | | 31 | 64.5%
9510 Jian 2002 | NCI toxicity criteria 1–4 | Tube feeding rate | Concomitant phase | CDDP/5-FU | | 17 | 35.3%

Table E-I Response/adverse event regression modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
5310, Zheng et al., 2005 | Major late tox | age, sex, histo, mn dose primary RT, vol irrad primary RT, T stage, GTV local recurrence, int initial RT to dx recur, late tox from prev RT, CTx, simultan RR | T stage, GTV (< 0.01) | same | | GTV (< 0.04)

Table E-J Xerostomia incidence

Study | Definition/Scale | Grade | F/U | Group | Mos. post Tx | n | % | Incidence (%) | | Comment
580, Dirix et al., 2007 | NCI CTC (v3.0) | 0, 1, 2 | acute | | | | 40, 56, 4
580, Dirix et al., 2007 | RTOG/EORTC | 0, 1, 2, 3, 4 | 6 mos | | | 20, 4, 1, 9, 9 | 80, 16, 4, 0, 0
1010, Urbano et al., 2007 | NCI CTC (v2.0) | 2, 3 | 12 mos | DL1 | 10, 14, 1 | 15 | 60/0
1010, Urbano et al., 2007 | NCI CTC (v2.0) | 2, 3 | 6 mos | DL2 | 10, 14, 1 | 15 | 73/7
1500, Lee et al., 2007 | NCI CTC (v 2.0) | 0–1 | 12 mos | | | 25 | 81
1500, Lee et al., 2007 | NCI CTC (v 2.0) | 2 | 12 mos | | | 1 | 3
1780, Lee et al., 2007 | NCI CTC | | | | | | 100 pre-RT
2430, Vosmik et al., 2006 | RTOG | 0,1,2,3,4 | | | | 0, 15, 23, 0, 0 | 0, 39, 60, 0
3080 Meirovitz 2006 | RTOG/EORTC | 0–3 | | | 6–24 (med 12 ) | 38 | 100 | Mean score of 3 observers 0.34 (SD 0.48) Range 0–2
3080 Meirovitz 2006 | XST questionnaire (0–100 with higher number representing greater levels of XST) | 0–3 | | | 6–24 (med 12 ) | 38 | 100 | Mean 37.3 (SD 24.4) Median 35 Range 0–86
3320, Portaluri et al., 2006 | RTOG/EORTC | 0,1,2,3 | | 38pts | | 12, 9, 14, 3 | 32, 24, 37, 8
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | [underlined: Subj XST Subman gl spared]
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Y | N
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Grade 0/1
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | 14 (78) | 7(39)
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Grade 2/3
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | 4 (22) | 11(61)
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | p=0.018
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | [underlined: Obj XST Subman gl spared]
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Y | N
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Grade 0/1
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | 14 (78) | 9 (50)
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Grade 2/3
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | 4 (22) | 9 (50)
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | P=0.083
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | [underlined: Managemt of XST Subman gl spared]
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Grade 0/1
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | 13 (72) | 7 (39)
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | (none needed)
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | Grade 2/3
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | 5 (28) | 11 (61) (occ/freq)
3570 Saarilahti 2006 | XST: LENT-SOMA scale(reported both by patient[subjective] and by radiotherapist[objective]. | | | | 12 | 36 | 100 | P=0.044
3790, Ozsahin et al., 2006 | RTOG/EORTC | 0, 1, 2, 3, 4 | | | | 33 | 13, 36, 36, 15, 0
5020, Nishimura et al., 2005 | RTOG | G0,1,2,3 | 3–4mo after start IMRT | | | 33 | | 3, 55, 36, 6%
5120, Wolden et al., 2006 | NCI | 0 1 2 3 | | IMRT | 12 mo | 59 | 80 | 25 42 32 0
5310, Zheng et al., 2005 | RTOG | 1, 2, 3 | acute | | | 45, 41 | 52, 48
5330, Lu et al., 2005 | RTOG | 1, 2, 3, 4 | <90 days >90 days | | | 1, 3, 1, 0 5, 9, 0, 0 | 4, 12, 4, 0 20, 36, 0, 0
7090, Chao et al., 2004 | | Grade 1,2 | | IMRT | | 32,9 | | 43, 12%
7370, Lu et al., 2004 | RTOG | 0, 1, 2, 3 | 9 mos | | | 0, 26, 23, 0 | 0, 53, 47, 0
7750, Liu et al., 2003 | RTOG | 1, 2, 3, 4 | > 90 days | | | 0, 3,0, 0 | 0, 4, 0, 0
8250, Munter et al., 2003 | RTOG | 0, 1, 2, 3 | acute | | | 23, 9, 10, 6 | 48, 19, 21, 12
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | | | | [underlined: Mean [25]^th^ [underlined: to 75]^th^ [underlined: percentile]]
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | BL | | | 0
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | End of RT | 21 | | 6.1 [~3.7–~8.8]
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | 1 | | | ~4.5 [~2.4–~6.8]
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | 3 | | | 7.0 [~1.0–~7.8]
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | 6 | | | ~6.8 [~2.0–~7.6]
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | 12 | 17 | | 3.2 [~1.8–~6.4]
8270 Braaksma 2003 | VAS score (10-point scale) 0=no complaints 10=severe complaints | | | | 24 | 15 | | 5.2 [~1.7–~8.2]
8400 Amosson 2003/8600 Amosson 2002 | Subjective questionnaire RTOG/EORTC Visual analog scale (VAS) | 1–4 | | IMRT with SMART boost | Median time from completion of IMRT 38.5 months (mean 39.9- range 16.6–71.4 months) | 30 | 100 | A questionnaire was used to assess long- term xerostomia. Thirty patients responded to the 10 question questionnaire for subjective assessment of mouth dryness. [underlined: Questions with significant correlation to dosimetric parameters] 1. “What is the overall comfort of your mouth?” n=9 (30%) felt that their mouth was very comfortable. n=11 (36.7%) had slight dryness (RTOG Grade 1) n=6 (20%) had moderate dryness (RTOG Grade 2) n=4 (13.3%) developed severe dryness (RTOG Grade 3). 2: “Does your mouth feel dry when eating?” n=9 (30%) no n=12 (40%) mild n=5 (16.7%) moderate n=4 (13.3) severe 3: “do you have difficulty swallowing any foods?” n=19 (63.3) yes n=11 (36.7%) no 4: “ do you need to sip liquids to swallow dry food?” n=23 (76.7%) yes n=7 (23.3%) no 6. “do you feel like the amount of saliva in your mouth is… n=14 (46.7%) too little n=16 (53.3%) adequate n=0 (0%) too much 9. “has your taste changed due to salivary gland function?” n=13 (43.4%) yes n=17 (56.7%) no [underlined: Questions without significant correlation to dosimetric parameters] 5. “do you feel thirsty all the time?” n=6 (20%) n=24 (80%) 7. “do you have problems with speech b/c of dry mouth?” n=10 (33.3) yes n=20 (66.7%) no 8. “does dry mouth interfere with your ability to sleep all the time?” n=17 (56.7%) no n=10 (33.3%) occasionally n=3 (10%) frequently 10. “do you need to carry a water bottle daily?” n=15 (50%) no n=4 (13.3%) occasionally n=4 (13.3%) frequently n=7 (23.3%) all the time | | Should we report p values from table 8??
9290 Teh 2002 | Subjective (none, mild, moderate and severe or complete) RTOG | 0 | | | | 2 | 7
9290 Teh 2002 | Subjective (none, mild, moderate and severe or complete) RTOG | 1 | | | | 13 | 46
9290 Teh 2002 | Subjective (none, mild, moderate and severe or complete) RTOG | 2 | | | | 13 | 46
9330 Kovacs 2002 | CTC v. 2.0 | 0 | | | | 4 | 8 | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
9330 Kovacs 2002 | CTC v. 2.0 | 1 | | | | 7 | 14 | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
9330 Kovacs 2002 | CTC v. 2.0 | 1–2 | | | | 0 | | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
9330 Kovacs 2002 | CTC v. 2.0 | 2 | | | | 32 | 65 | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
9330 Kovacs 2002 | CTC v. 2.0 | 2–3 | | | | 0 | | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
9330 Kovacs 2002 | CTC v. 2.0 | 3 | | | | 6 | 12 | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
9330 Kovacs 2002 | CTC v. 2.0 | 3–4 | | | | 0 | | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
9330 Kovacs 2002 | CTC v. 2.0 | 4 | | | | 0 | | | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49.
11650, Kuppersmith et al., 1999 | RTOG | | | | | 2 | 7 | Not defined
13340 Ikushima et al, 2008 | RTOG | 0, 1, 2, 3, 4 | 75 | IMRT | 36mo | | | 20, 49.3, 18.7, 12%
24330, Pfreunder et al., 2003 | RTOG | 1,2,3,4 | 50 | ICHT | | | | 22, 65, 12, 0%
37660, Wendt et al, 2006 | RTOG | 0,1,2,3,4 | 38 | IMRT | 21mo | 38 | | ~18, ~41, ~28, ~13, 0%
38290, Anand et al., 2008 | NCI CTC v3.0 | 0, 1, 2 | 3 mos 6 mos | | | 31, 24, 4 35, 18, 4 | 52, 41, 7 61, 32, 7
38840 Seung 2008 | RTOG | 0 | Acute | | | 0 | 0
38840 Seung 2008 | RTOG | 1 | Acute | | | 0 | 0
38840 Seung 2008 | RTOG | 2 | Acute | | | 29 | 42
38840 Seung 2008 | RTOG | 3 | Acute | | | 40 | 58
38840 Seung 2008 | RTOG | 4 | Acute | | | 0 | 0
38840 Seung 2008 | RTOG | 0 | Late (f/u at least 1 yr) | | | 0
38840 Seung 2008 | RTOG | 1 | Late (f/u at least 1 yr) | | | 27
38840 Seung 2008 | RTOG | 2 | Late (f/u at least 1 yr) | | | 17
38840 Seung 2008 | RTOG | 3 | Late (f/u at least 1 yr) | | | 0
38840 Seung 2008 | RTOG | 4 | Late (f/u at least 1 yr) | | | 0
39300, Hoppe et al., 2008 | RTOG | 0, 1, 2, 3, 4 | <3 mos > 3 mos | | | 7, 23, 7, 0, 0 30, 3, 3, 0, 0 | 19, 62, 19, 0, 0 83, 8, 8, 0, 0

Table E-K Salivary flow

Study | Definition/Scale | Grade | F/U | Group | Mos. post Tx | n | % | Salivary Flow | | | Comment
3080 Meirovitz 2006 | Stimulated (ml/min) | | | IMRT | 6–24 (med 12) | 38 | 100 | Mean 0.55 (SD 0.27) Median 0.57 (0.01–2.42)
3080 Meirovitz 2006 | Unstimulated (ml/min) | | | IMRT | Same | 38 | 100 | Mean 0.10 (SD 0.16) Median 0.13 (0–0.96)
3080 Meirovitz 2006 | % stimulated (relative to pretx) | | | IMRT | Same | 38 | 100 | Mean 40 (SD 32) Median 30 (0–140)
3080 Meirovitz 2006 | % unstimulated (relative to pretx) | | | IMRT | same | 38 | 100 | Mean 32 (SD 27) Median 18 (0–243)
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | [underlined: Basal SLF] | [underlined: Subman gl spared]
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | | Y | N
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | Grade 0 or 1 (76–100% of pretx value) | 10 (56) | 3 (17)
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | Grade 2,3 or 4 (0–75% of pretx value) p=0.015 | 8 (44) | 15 (83)
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | [underlined: Stimulated SLF] | [underlined: Subman gl spared]
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | | Y | N
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | Grade 0 or 1 | 10 (56) | 7 (39)
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | Grade 2,3 or 4 P=0.32 | 8 (44) | 11 (61)
3570 Saarilahti 2006 | SLF: LENT-SOMA score (percent of pretreatment value) | | | | 12 months after last RT | | | Six months following RT, mean unstimulated SLF was 57% of the BL value among the patients who had one submandibular gland spared and 27% among those who did not. Values 12 months after RT were 60 and 25%, respectively (p=0.006). One patient (6%) with contralateral submandibular gland sparing had severe (grade 4) reduction in the unstimulated SLF (to 0–25% of the pre-treatment value) 12 months after completion of IMRT as compared to 7 (39%) of the rest of the patients (p=0.016).
3820 McMillan 2006 | Stimulated whole salivary (SWS) flow rate (ml/min) | | | | BL,2,6,12 | 32 | 100 | Mean (SD) .91 (.53), .10 (.08), .18 (0.16), .28 (.27) p<.001 for all 4 visits, BL vs. 2 mo, BL vs. 6 mo and BL vs. 12 mo.
3820 McMillan 2006 | Stimulated parotid Salivary (SPS) flow rate (ml/min) | | | | BL,2,6,12 | 32 | 100 | .06 (.09), .01 (.02), .02 (.03), .06 (.10) p=.005 for all 4 visits, <.001 for BL vs. 2 mo and BL vs. 6 mo, .217 for BL vs. 12 mo
6430, Kwong et al, 2004 | Mean flow mL/min | | 0,2,6,12,18,24 mo | IMRT | 19 patients @ baseline 17 patients @ 12 mo, 7 patients @ 24 mo. | 19, 17, 7 | | Stimulated Whole Saliva (mL/min) 0,2,6,12,18,24 mo: 4.78, .47, .92, 1.33, 1.42, 2.73 Stimulated parotid saliva (mL/min) 0,2,6,12,18,24 mo: .92, .16, .21, .59, .62, .69
8270 Braaksma 2003 | Stimulated whole saliva flow measurements (WS)- mL/min as a % of BL before RT. | | | | BL, weekly during RT, and at regular intervals after (1-3-6-12-24 mos.) Median BL,1,3,6,12,24 (25^th^ to 75^th^ %) | 18 | 69 | Pretx median SLF 1.96 mL/min (range .06–6.25). SLF decreased to 35% of BL (at 6 mos. post RT) and 37% (at 12 mos.). Partial recovery observed with a median of 48% of pretx SLF at 2 yrs post tx in 9 pts. 1.96 mL/min (~1.3–2.75), ~.80 (~.4–~1.25),~.85 (~.3–~.9), ~.80 (~.5–~.9), ~.82 (~.25–~1.1), ~1.2 (~.4–~1.9)

Table E-L Dysphagia incidence

Study | Definition/Scale | Grade | F/U | Group | Mos. post Tx | n | % | Comment
580, Dirix et al., 2007 | NCI CTC (V 3.0) | 0, 1, 2, 3, 4 | Acute | | | 17, 7, 1, 0, 0 | 68, 28, 4, 0, 0
1010, Urbano et al., 2007 | NCI CTC (v 2.0) | 2,3 | 12 mos 6 mos | DL1 DL2 | | 15 15 | 20, 67 13, 87
1500, Lee et al., 2007 | NCI CTC (v 3.0) | 3 | 12 mos | | | 6 | 19
2370, Garden et al., 2007 | Chronic | Mild | | | | 3 | 6
2430, Vosmik et al., 2006 | RTOG | 0, 1, 2, 3, 4 | | | | 0, 10, 14, 14, 0 | 0, 26, 37, 37, 0
2770, Cheng et al., 2006
3320, Portaluri et al., 2006
3340 Studer 2006 | SOMA-LENT and RTOG/EORTC radiation morbidity score | 0/1 3/4 | | | | 24/27 n=2
3790, Ozsahin et al., 2006 | NCI CTC v 2.0 | 0, 1, 2, 3, 4 | | | | 0, 4, 16, 13, 0 | 0, 12, 49, 39, 0
4290, Lau et al., 2006 | RTOG | 0, 1, 2, 3, 4 | | | | 1, 13, 22, 20, 0 | 2, 23, 39, 36, 0
5210, Duthoy et al., 2005 | RTOG | G0,1,2, 3 | 31 | IMRT | 39 | 18, 54, 28, 0%
16840, Wu et al, 2006 | Dysphagia | | | | | 0 | 0
24330, Pfreunder et al., 2003 | Dysphagia | 1, 2, 3,4 | | | | 6, 25, 17, 0 | 12, 51, 35, 0
338850 Caglar 2008 | Swallowing Performance Scale (1–7) | 1 2 3 4 5 6 7 | | IMRT (all) | 1–2 | ~32 ~6 ~22 ~14 ~9 ~4 ~9 | 33.3 6.25 22.9 14.6 9.4 4.2 9.4
37660, Wendt et al, 2006 | RTOG | 0,1,2,3 | 38 | IMRT | 21 | | ~14, ~38, ~32, ~17
38290, Anand et al., 2008 | NCI CTC V 3,0 | 0, 1, 2 | 3 mos 6 mos | | | 41, 7, 11 44, 6, 7 | 69, 12, 19 77, 10, 12
38840 Seung 2008 | RTOG | 0 1 2 3 4 0 1 2 3 4 | Acute Late | | | 0 11 52 6 0 0 40 25 4 0 | 0 15.9 75.4 8.7 0 58.0 36.2 5.8 0

Table E-M Other toxicities to head and neck, e.g., osteoradionecrosis, radiation-induced caries

Study | Toxicity Type | Definition/Scale | Grade | F/U | Group | Mos. post Tx | n | % | Comment
3400 Studer 2006 | ORN | | 3 | | IMRT | 6 | 1 | 1.4 | Total dose of 66 Gy for T3N2b BOT cancer.
5020, Nishimura et al., 2005
6430, Kwong et al, 2004
6530 Zheng 2004 | ORN mandible | | | | 3DC | | 0 | 0
7090, Chao et al., 2004 | Trismus Jaw discomfort | | 1 2 | | IMRT IMRT | | 3 1

Table E-N Other adverse events

Toxicity Type | Study | Severity or Grade | F/U (mos.) | Group1 | n | % | Group2 | N | %
TRM | 5310, Zheng et al., 2005 | | 39 | | 11 | 13
TRM | 7750, Liu et al., 2003 | | 7, 10 | | 1,1 | 1,1
TRM | 8370, Padovani et al., 2003 | Acute infectious complication leading to death | | | 2 | 8
Skin | 560, Biagioli et al., 2007 | RTOG Grade 3–4 | 14 | | 2
Skin | 580, Dirix et al., 2007 | NCI CTC (v 3.0) dermatitis 0,1,2,34 RTOG/EORTC 0,1,2,3,4,5 | Acute 6 | | 3, 17, 5, 0, 0 21, 3, 1, 0, 0 | 12, 68, 20, 0, 0 84, 12, 4, 0,0
Skin | 1010, Urbano et al., 2007 | NCI CTC (v.2.0) Grade 2–3 RTOG Grade 1 LENT SOM | 12/6 12/6 12/6 | DL1 DL1 DL1 | 15 11 11 | 67/20 18 27 | DL2 DL2 DL2 | 15 10 10 | 47/20 20 40
Skin | 1500, Lee et al., 2007 | NCI CTC (v.3.0) Grade 0, 1, 2, 3 | 12 Acute | | 1 4, 20, 6, 1 | 3 13, 64, 19, 3
Skin | 2430, Vosmik et al., 2006 | RTOG Grade 0, 1, 2, 3, 4 | Acute | | 0, 24, 12, 2, 0 | 0, 63, 32, 5, 0
Skin | 3340, Studer et al., 2006 | “mild to moderate” (no number provided)
Skin | 4430, Kwong et al., 2006 | Grade 3 | | | 23 | 46
Skin | 3790, Ozsahin et al., 2006 | RTOG Grade 0, 1, 2, 3, 4 | Acute | | 0, 9, 10, 14, 0 | 0, 27, 30, 43, 0
Skin | 4290, Lau et al., 2006 | RTOG Grade 0, 1, 2, 3, 4 | Acute | | 0, 15, 24, 16, 1 | 0, 27, 43, 29, 2
Skin | 5210, Duthoy et al., 2005 | Radiodermatitis G1,2,3 | 31 | | | 64, 31, 5%
Skin | 5310, Zheng et al., 2005 | RTOG Grade 1, 2, 3 | Acute | | 40, 2 | 47, 2
Skin | 5330, Lu et al., 2005 | RTOG Grade 1, 2, 3, 4 | <90 days >90 days | | 4, 12, 6, 0 5, 1, 0, 0 | 16, 48, 24, 0 20, 4, 0, 0
Skin | 5740, Thorstad et al., 2004 | Grade 1/2; 3/4 | Acute | | 22, 5 8, 2 | 82, 18 29, 7
Skin | 7090, Chao et al., 2004 | Acute toxicity G1, G2, G3, G4 Late toxicity G1,2 | | IMRT IMRT | | 42,35, 15, 5% 3, 1%
Skin | 7370, Lu et al., 2004 | RTOG Grade 0, 1, 2, 3 | 9 mos | | 29, 19, 1, 0 | 59, 39, 2, 0
Skin | 8250, Munter et al., 2003 | RTOG 0, 1, 2, 3 | Acute | | 0, 25, 21, 2 | 0, 52, 44, 4
Skin | 9290, The et al., 2002 | 18 of 28 (64%) grade 1 10 of 28 (36%) grade 2
Skin | 9330, Kovacs et al., 2002 | 0 1 1–2 2 2–3 3 3–4 4 | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49. | 5 9 0 31 0 3 0 1 | 10 18 63 6 2
Skin | 10740, Pommier et al, 2000
Skin | 11650, Kuppersmith et al., 1999 | RTOG (not defined) | Acute | | 3 | 11
Skin | 13270, Lawson et al., 2008 | Acute 1 2 3 4 Late 1 2 3 4 | | | 16 11 0 0 3 0 0 0
Skin | 13340 Ikushima et al, 2008 | Dermatitis G 0, 8, 4 | 36 mo | CRT | 28, 8, 4 | 70, 20, 10
Skin | 16840, Wu et al, 2006 | Grade 0, 1, 2, 3, 4 | 36 mo | IMRT | 35, 31, 6, 3, 0 | 46.7, 41.3, 8, 4, 0%
Skin | 24330, Pfreunder et al., 2003 | RTOG 1, 2, 3 4 | | ICHT | 16, 29, 3, 0 | 32, 58, 6, 0%
Skin | 37660, Wendt et al, 2006 | Dermatitis G 1, 2 | 21 | IMRT | | ~38, ~62
Skin | 38290, Anand et al., 2008 | NCI CTC (v.3.0) Grade 1, 2, 3 | 3 mos | | 0, 8, 2 | 0, 13, 3
Skin | 38840, Seung et al., 2008 | 0 1 2 3 4 | | All | 0 32 32 5 0 | 0 46.4 46.4 7.2 0
Skin | 39020, Rosenthal et al., 2008 | NCI’s common toxicity criteria (v3.0) | | IMRT alone | | 28 | IMRT + CT | | 35
Skin | 39300, Hoppe et al., 2008 | RTOG Grade 0, 1, 2, 3, 4 | <3 mos >3 mos | | 4, 23, 7, 3, 0 33, 2, 1 | 11, 62, 19, 8, 0 92, 6, 3
Subcutaneous Tissue | 6530, Zheng et al., 2004 | Neck fibrosis | | | 1 | 1.9
Subcutaneous Tissue | 7750, Liu et al., 2003 | RTOG grade 1, 2, 3, 4 | > 90 days | | 0, 0, 0, 0 | 0, 0, 0, 0
Subcutaneous Tissue | 13270, Lawson et al., 2008 | Late 1 2 3 4 | | | 3 5 0 0
Subcutaneous Tissue | 16840, Wu et al, 2006 | Fibrosis G 1, 2, 3, 4 | 36 | IMRT | 14,1,0,0 | 18.6, 1.3,0,0
Subcutaneous Tissue | 24330, Pfreunder et al., 2003
Subcutaneous Tissue | 37660, Wendt et al, 2006
Mucous Membrane | 560, Biagioli et al., 2007 | RTOG Grade 3-4 | 14 | | 2 | 5%
Mucous Membrane | 580, Dirix et al., 2007 | NCI CTC (v. 3.0) Grade 0, 1, 2, 3, 4 RTOG/EORTC 0, 1, 2, 3, 4 | Acute 6 | | 7, 12, 6, 0, 0 17, 7, 1, 0, 0 | 28, 48, 24, 0, 0 68, 28, 4, 0, 0
Mucous Membrane | 1010, Urbano et al., 2007 | NCI CTC (v.2.0) Grade 2/3 RTOG Grade 1 LENT SOM Grade 1 | 12/6 12/6 12/6 | DL1 DL1 DL1 | 15 11 11 | 33/67 9 36 | DL2 DL2 DL2 | 15 10 10 | 47/40 60 30
Mucous Membrane | 1420, Feng et al., 2007 | NCI CTC Grade 0- 4 | 1 | Highest score | Med 3(rng 2-3), mean 2.6 + or – 0.5
Mucous Membrane | 1500, Lee et al., 2007 | NCI CTC (v.3.0) Grade 0, 1, 2, 3 | Acute | | 3, 13, 8, 7 | 10, 42, 26, 23
Mucous Membrane | 2180, Daly et al., 2007 | RTOG/EORTC Grade 1, 2, 3 | Acute | | 19, 11, 6 | 53, 30, 17
Mucous Membrane | 2430, Vosmik et al., 2006 | RTOG Grade 0, 1, 2, 3, 4 | Acute | | 0, 4, 23, 11, 0
Mucous Membrane | 3340, Studer et al., 2006 | Grade 2 (n=13) Grade 3 (n=6)
Mucous Membrane | 3570, Saarilathti et al., 2006 | Grade 1: 3 Grade 2: 11 Grade 3: 19 Grade 4: 3
Mucous Membrane | 3790, Ozsahin et al., 2006 | RTOG Grade 0, 1, 2, 3, 4 | Acute | | 0, 5, 14, 14, 0 | 0, 16, 42, 42, 0
Mucous Membrane | 4290, Lau et al., 2006 | RTOG Grade 0, 1, 2, 3, 4 | Acute | | 0, 16, 23, 16, 1 | 0, 29, 41, 29, 2
Mucous Membrane | 4430, Kwong et al., 2996 | Grade 3 | | | 39 | 78
Mucous Membrane | 5210, Duthoy et al., 2005 | Mucositis G1,2,3 | 31 | | | 54, 28, 18%
Mucous Membrane | 5310, Zheng et al., 2005 | RTOG Grade 1, 2,3 | Acute | | 34, 24, 5 | 40, 28, 6
Mucous Membrane | 5330, Lu et al., 2005 | RTOG Grade 1, 2, 3, 4 | <90 days > 90 days | | 1, 17, 5, 2 0, 2, 0, 0 | 4, 68, 20, 8 0, 8, 0, 0
Mucous Membrane | 5740, Thorstad et al., 2004 | Grade 1/2, 3/4 | Acute | | 19, 8 | 70, 30
Mucous Membrane | 7090, Chao et al., 2004 | Acute mucosal toxicity G1, G2, G3, G4 Late mucositis G1 | | IMRT IMRT | | 12, 46, 38, 3% 4%
Mucous Membrane | 7370, Lu et al., 2004 | RTOG Grade 0, 1, 2, 3 | 9 mos | | 16, 10, 21, 2 | 33, 20, 43, 4
Mucous Membrane | 7750, Liu et al., 2003 | RTOG Grade 1, 2, 3,4 | <90 days | | 26, 39, 7, 0 | 31, 47, 9, 0
Mucous Membrane | 8250, Munter et al., 2003 | RTOG 0, 1,2, 3 | Acute | | 8, 10, 21, 9 | 16, 21, 44, 19
Mucous Membrane | 9290, The et al., 2002 | 1 of 28 (3%) grade 1 5 of 28 (18%) grade 2 22 of 28 (79%) grade 3
Mucous Membrane | 9330, Kovacs et al., 2002 | 0 1 1-2 2 2-3 3 3-4 4 | | n=49 I’m not clear which population this is- in the text they report that 42 pts who rec’d RT got concomitant CT, but the table (4) adds up to 49. | 4 6 2 12 7 16 1 1 | 8 12 4 24.5 14 33 2 2
Mucous Membrane | 9510, Jian et al., 2002 | 1 3 4 1 2 3 4 | | concomitant CDDP Adjuvant CDDP | | 0.0 22.6 67.7 9.7 25.0 32.1 21.4 10.7 | CDDP/5-FU CDDP/5-FU | | 0.0 11.8 82.4 5.9 31.3 25.0 18.8 12.5
Mucous Membrane | 10740, Pommier et al, 2000 | NCI CTC (v.2.0) Grade 2, 3, 4, 5
Mucous Membrane | 11650, Kuppersmith et al., 1999 | RTOG (not defined) | Acute | | 7 | 25
Mucous Membrane | 13270, Lawson et al., 2008 | Acute 1 2 3 4 Late 1 2 3 4 | | | 12 19 3 0 4 0 0 0
Mucous Membrane | 13340 Ikushima et al, 2008 | Mucositis G I, II, III | 36 mo | CRT | 14,22, 4 | 35, 55, 10
Mucous Membrane | 16840, Wu et al, 2006 | Mucositis G 0, 1, 2, 3, 4 | 35mo | IMRT | 7, 31, 30, 7 | 9.3, 41.4, 40, 9.3
Mucous Membrane | 24330, Pfreunder et al., 2003 | Mucositis G 1, 2, 3, 4 | | ICHT | 10, 23, 16, 0 | 20, 47, 33, 0
Mucous Membrane | 26140, Scorsetti et al., 2001 | “transient” | | | NR
Mucous Membrane | 37660, Wendt et al, 2006 | Mucositis G, 1, 2, 3 | 21mo | IMRT | | ~28, ~60, ~12
Mucous Membrane | 38290, Anand et al., 2008 | NCI CTC (v.3.0) Grade 0, 1, 2, 3 | 3 mos | | 2, 27, 33 | 3, 44, 53
Mucous Membrane | 38840, Seung et al., 2008 | 0 1 2 3 4 | Acute | All | 0 8 33 28 0 | 0 11.6 47.8 40.6 0
Mucous Membrane | 38850, Caglar et al., 2008 | 0 1 2 3 4 | | IMRT | 3 7 34 50 2 | 3 7 36 52 2
Mucous Membrane | 39020, Rosenthal et al., 2008 | NCI’s common toxicity criteria | | IMRT alone | | 9 | IMRT + CT | 22
Mucous Membrane | 39300, Hoppe et al., 2008 | RTOG Grade 0, 1, 2, 3, 4 | < 3 mos >3 mos | | 2, 18, 12, 5, 0 36, 0,0,0, 0 | 5, 49, 32, 14, 0 100,0, 0, 0, 0
Mucous Membrane | 39390, Worden et al., 2008 | | acute | | 21, 42, 3 | 32, 64, 4
Hematologic | 560, Biagioli et al., 2007 | RTOG Grade 3-4 | 14 | | 5 | 12
Hematologic | 4290, Lau et al., 2006 | CTC 0, 1,2, 3, 4 Hb WB Neutrophils Platelets Creatine | Acute | | 25, 25, 2, 1, 1 36, 9, 8, 1, 0 42, 8, 2, 1, 1 49, 4, 1, 0, 0 49,2, 1, 0, 0 | 45, 45, 4, 2, 2 64, 16, 14, 2 75, 14, 4, 2, 2 88, 7, 2, 0, 0 88, 4, 2, 0, 0
Hematologic | 38290, Anand et al., 2008 | NCI CTC (v.3.0) Grade 1, 2, 3 Anemia Neutropenia thrombocytopenia | 3 mos | | 3, 2, 0 5, 4, 4 2, 1, 1 | 5, 3, 0 8, 6, 6 3, 2, 2
Hematologic | 39390, Worden et al., 2008 | NCI CTC (v.2.0) Grade 2, 3, 4, 5 Anemia Leukopenia Neutropenia Thrombocytopenia Febrile neutropenia | Acute Late Acute Late Acute Late Acute Late Acute Late | | 5, 0, 0, 0 5, 1, 0, 0 44, 0, 0, 0 6, 0, 1, 0 1, 9, 1, 0 12, 4, 2, 0 6, 1, 0, 0 1, 1, 0, 0 0,0,2, 0 0,0,1,0 | 8,0, 0, 0 7, 1, 0, 0 66, 0, 0, 0 9, 0, 1, 0 1, 14, 1, 0 18, 6, 3, 0 9, 1, 0, 0 1, 1, 0, 0 0, 0, 3, 0 0, 0, 1, 0
Nausea/Vomiting | 560, Biagioli et al., 2007 | RTOG Grade 3-4 | 14 | | 3 | 7
Nausea/Vomiting | 5330, Lu et al., 2005 | RTOG grade 1, 2, 3, 4 | <90 days | | 0, 1, 3, 0 | 0, 4, 12, 0
Nausea/Vomiting | 5740, Thorstad et al., 2004 | Grade ½, ¾ | Acute | | 23, 0 12, 0 | 85, 0 44, 0
Nausea/Vomiting | 39390, Worden et al., 2008 | NCI CTC (v 2.0) grade 2, 3, 4, 5 | Acute | | 8, 2, 0, 0 5, 3, 0, 0 | 12, 3, 0, 0 8, 4, 0, 0
Brain | 580, Dirix et al., 2007 | NCI CTC (v. 3.0) Grade 0, 1, 2, 3, 4 RTOG/EORTC Grade 0,1, 2, 3, 4 (headache, other braine) | Acute 6 | | 10, 11, 4, 0, 0 11, 11, 3, 0, 0 | 40, 44, 16, 0,0 44, 44, 12, 0, 0
Brain | 5210, Duthoy et al., 2005 | Brain necrosis | 31 | | | 5%9
Brain | 5310, Zheng et al., 2005 | RTOG Grade 3, 4 Temporal lobe necrosis | 39 mos | | 11, 2 | 13, 2
Spinal Cord | 5310, Zheng et al., 2005 | Tog grade 3 or higher, cranial neuropathy | 39 mos | | 25 | 29
Spinal Cord | 5330, Lu et al., 2005 | RTOG 1, 2, 3, 4 L’hermitt’s syndrome | >90 days | | 1, 0,0,0 | 4,0,0,0
Spinal Cord | 8370, Padovani et al., 2003 | Acute purulent keratoconjunctivitis Uveitis Retinopathy | 17 mos 23 mos | | 2 1 1
Spinal Cord | 13340 Ikushima et al, 2008 | Neurology G 0, II | 36 | CRT | 39, 1 | 97.5, 2.5
Spinal Cord | 16840, Wu et al, 2006 | Neuropathy G 1, 2, 3, 4 | 36mo | IMRT | 0,2,1,0 | 0, 2.6, 1.3, 0 %
Spinal Cord | 24330, Pfreunder et al., 2003 | Vertigo CTC 1, 2, 3, 4 Headache CTC 1, 2, 3, 4 Sensorial disorder CTC 1,2,3,4 Motoric Disorder CTC 1,2,3,4 | | ICHT | 17, 1, 0, 0 1, 5, 0, 0 10, 1, 0,0 23, 0,0,0 | 34, 2,0,0 % 2,10, 0, 0% 20, 2, 0, 0% 46, 0, 0,0%
Spinal Cord | 39390, Worden et al., 2008 | NCI CTC (v 2.0) Grade 2, 3, 4, 5 | Acute Late | | 8,2, 0, 0 2, 7, 0, 0 | 12, 3, 0, 0 3, 14, 0, 0
Eye | 580, Dirix et al., 2007 | NCI CTC (v. 3.0) Grade 0, 1, 2, 3, 4 : conjunctivitis NCI CTC (v. 3.0) Grade 0, 1, 2, 3, 4: tearing RTOG/EORTC Grade 0, 1, 2, 3, 4: tearing | Acute Acute 6 | | 5, 10, 10, 0 7, 11, 7, 0,0 14, 11, 0,0,0 | 20, 40, 40, 0 28, 44, 28, 0, 0 56, 44, 0, 0, 0
Eye | 2180, Daly et al., 2007 | RTOG/EORTC Grade 1,2,3 Xeropthalmia Lacrimal stenosis Gyru rectus necrosis | Acute Chronic Chronic | | 18, 10, 1 1 1 | 50, 28, 3 3 3
Eye | 5210, Duthoy et al., 2005 | Keratitis G2 Photophobia G2, 3 Blurred Vision G2,3 Tearing G0, 1,2,3 Dry Eye G1,2,3 Conjunctivitis G1,2,3 | 31 | | | 8% 8, 3% 10, 3% 13, 62,23,3% 92, 8,0 % 59, 38, 3%
Eye | 11650, Kuppersmith et al., 1999 | RTOG (not defined) Irritation | Acute | | 1 | 4
Eye | 39300, Hoppe et al., 2008 | RTOG grade 0,1,2, 3, 4 Ipsilateral contralateral | <3 mos >3 mos <3mos >3mos | | 27, 3, 2, 0, 0 32, 0,0,0, 0 36, 1, 0, 0, 0 36, 0, 0, 0, 0 | 73, 8, 5, 0, 0 100, 0, 0, 0, 0 97, 3, 0, 0, 0 100, 0, 0, 0, 0
Visual Acuity | 2180, Daly et al., 2007 | | Chronic | 30 pts | 0 | 0
Ear | 2180, Daly et al., 2007 | Vestibular symptoms | Chronic | 30 pts | 3 | 10
Ear | 5330, Lu et al., 2005 | RTOG Grade 1,2, 3, 4 Ottis media | <90 days >90 days | | 1, 2, 0, 0 0, 0, 3, 0 | 4, 8, 0, 0 0, 0, 12, 0
Ear | 6530, Zheng et al., 2004 | Hearing loss | | | 3 | 5.6
Ear | 9510, Jian et al., 2002 | 1 2 3 | | | 12 26 2
Ear | 16840, Wu et al, 2006 | Hearing Loss Grade 1, 2, 3 | 36 | IMRT | 5, 2, 1 | 6.6, 2.6, 1.3
Ear | 38290, Anand et al., 2008 | Otitis media | 3 mos | | 3 | 5
Ear | 39300, Hoppe et al., 2008 | NCI CTC v 2.0 grade 2, 3, 4, 5 Otitis medius | < 2 wks of RT Post RT | | 4 3 | 11 8
Ear | 39390, Worden et al., 2008 | tinnitus | Acute | | 5, 2, 0, 0, 0 | 8, 3, 0, 0, 0
Auditory Acuity | 5310, Zheng et al., 2005 | RTOG Grade 3: hearing loss | Med 39mo
Auditory Acuity | 5330, Lu et al., 2005 | RTOG Grade 1, 2, 3, 4 hearing loss | <90days >90days
Auditory Acuity | 5420, Pan et al., 2005 | hearing loss > or = 10 Db | 1 mo 6 mo 12 mo 24 mo 36 mo 1 mo 6 mos 12 mos 24 mos 36 mos | 8000 H z 4000 Hz | 19 16 14 10 2 23 20 14 12 3 0, 2, 1, 0 | 47 44 46 29 6 14 14 20 34 9 0, 2, 1, 0
Auditory Acuity | 7750, Liu et al., 2003 | RTOG 1, 2, 3, 4 hearing impairment | < 90days | | 0, 2, 1, 0 | 0, 2, 1, 0
Auditory Acuity | 38290, Anand et al., 2008 | hearing impairment | 3 mos | | 1 | 2
Auditory Acuity | 39300, Hoppe et al., 2008 | hearing impairment | 6 mos 4 yrs | | 1 1 | 3 3
Larynx | 1010, Urbano et al., 2007 | RTOG Grade 1-2 LENT SOM Grade 1-2 | 12/6 12/6 | DL1 DL1 | 11 11 | 27 27 | DL2 Dl2 | 10 10 | 20 20
Larynx | 1500, Lee et al., 2007 | NCI CTC (v.3.0) | 12 | | 3 | 10
Larynx | 3340, Studer et al., 2006 | Grade 4 laryngeal fibrosis (n=1) “Laryngeal preservation maintained in all 23 locally controlled patients who underwent definitive IMRT, ultimate organ preservation in 96% (26/27).
Larynx | 5740, Thorstad et al., 2004 | Grade 1/2, ¾ | Acute | | 11, 2 | 41, 7
Larynx | 13270, Lawson et al., 2008 | Acute 1 2 3 4 Late 1 2 3 4 | | | 3 1 0 0 6 0 0 0
Larynx | 38840, Seung et al., 2008 | 0 1 2 3 4 | | all | 12 51 6 0 0 | 17.4 73.9 8.7 0 0
Lung
Heart
Esophagus | 560, Biagioli et al., 2007 | Late | 14 | | 1 | 2
Esophagus | 1010, Urbano et al., 2007 | RTOG Grade 2–3 LENT SOM | 12/6 12/6 | DL1 DL1 | 11 11 | 9 18 | DL2 DL2 | 10 10 | 10 10
Esophagus | 1420, Feng et al., 2007 | NCI CTC RTOG/EORTC | 1 3 (late) | Highest score Highest score | Med2 (rng 2–3) Med 1 (rng 0–3) | Mean 2.3 + or −.5 Mean 1.0 + or −1.1
Esophagus | 2290, Yao et al., 2006 | Stenosis (not defined) | | | 3 | 4
Esophagus | 5740, Thorstad et al., 2004 | Grade 1/2, 3/4 | Acute | | 23, 2 | 85, 7
Esophagus | 8250, Munter et al., 2003 | RTOG Grade 0, 1, 2, 3 | Acute Late | | 6, 8, 26, 8 0, 0, 1, 1 | 12, 17, 54, 17 0, 0, 0, 2, 2
Esophagus | 13270, Lawson et al., 2008 | Acute Grade 1 Grade 2 Grade 3 Grade 4 Late Grade 1 Grade 2 Grade 3 Grade 4 | | | 13 19 1 0 13 3 6 (*note # different than text) 0
Esophagus | 38850, Caglar et al., 2008 | Stricture (doses significantly associated with stricture development = 54 Gy to mean inferior constrictor muscle [p=.02]; dose to LAR NS). Minimal dose rec’d by 60% of inf constrictor and % volume receiving ≥50 Gy correlated with stricture development [p=.03 and .02, respectively]. NS for larynx. | | IMRT | 36 | 37
Bone | 8250, Munter et al., 2003 | RTOG Grade 0, 1, 2, 3 | late | | 1 | 2
Bone | 39390, Worden et al., 2008 | NCI CTC (v.2.0) Mandibular necrosis | Late | | 3 | 5
Joint | 5310, Zheng et al., 2005 | RTOG Grade 3, 4 trismus | Med 39 mos | | 12, 4 | 14, 5
Joint | 5330, Lu et al., 2005 | RTOG Grade 1,2, 3, 4 Trismus | >90days | | 10, 3, 0, 0 | 40, 12, 0,0
Joint | 7750, Liu et al., 2003 | RTOG Grade 1,2, 3, 4 trismus | >90days | | 0, 1, 0, 0 | 0, 1, 0, 0
Teeth | 1900, Ben- David et al., 2007 | NCI CTC (v.3.0) Grade 1–4 Osteoradionecrosis | Med 35(rng 6–129) | | 0 | 0
Teeth | 2290, Yao et al., 2006 | Mild (not define) Osteoradionecrosis | | | 4 | 6
Teeth | 2370, Garden et al., 2007 | Not defined Osteoradionecrosis | | | 1 | 2
Pain | 560, Biagioli et al., 2007 | RTOG Grade 3 – 4 | 14 | | 4 | 10
Pain | 1010, Urbano et al., 2007 | NCI CTC (v 2.0) grade 2–3 | 12/6 | DL1 | 15 | 47/27 | DL2 | 15 | 53/40
Other | 560, Biagioli et al., 2007 | Late: fistula carotid hemorrhage persistent PEG tube | 14 | | 2 1 2 | 5 2 5
Other | 580, Dirix et al., 2007 | NCI CTC (v. 3.0) Grade 0, 1, 2 sense of smell taste disturbance NCI CTC (v. 3.0) Grade 0, 1, 2, 3, 4 fatigue | Acute | | 10, 5, 10 8, 8, 15 4, 10, 11, 0, 0 | 40, 20, 40 32, 32, 60 15, 40, 44, 0, 0
Other | 1420, Feng et al., 2007 | PEG insertion | Pre-RT During Tx | | 2 11
Other | 1500, Lee et al., 2007 | NCI CTC (v.3.0) Grade 2, 3: pharyngitis PEG dependence | Acute 12 | | 27, 4 6, 19 | 87, 13
Other | 2180, Daly et al., 2007 | keratitis cellulitis dacryocystitis parotiditis | ACUTE | | 1 1 1 1 | 3 3 3 3
Other | 2290, Yao et al., 2006 | PEG dependence Tracheotomy | Chronic | | 10 3 | 15 4
Other | 2370, Garden et al., 2007 | RTOG/EORTC Grade 0, 1, 2, 3, 4: PEG insertion Fibrosis | <1yr Late | | 21 7, 23, 2, 0, 0 | 40 21, 70, 3, 0,0
Other | 3790, Ozsahin et al., 2006 | PEG insertion nasogastric tube wt loss | | | 18 8 Med 4.5kg (rng 0– 13kg) | 55 24
Other | 4290, Lau et al., 2006 | PEG insertion NG tube | Overall/chronic | | 13/7 10/2 | 23/12 18/4
Other | 5120, Wolden et al., 2006 | | | | | | | | No cases of temporal lobe necrosis, osteoradionecrosis or clinical hypopituitarism
Other | 5330, Lu et al., 2005 | RTOG Grade 1,2, 3, 4 taste disturbance olfactory disturbance | <90 days >90 days > 90 days | | 1, 4, 0, 4 1, 3, 1, 0 1, 1, 1, 0 | 4, 16, 0, 16 4, 12, 4, 0 4, 4, 4, 0
Other | 5740, Thorstad et al., 2004 | Grade 1/2, ¾ asthenia fever hypotension salivary weight loss | Acute | | 12, 0 2, 0 0,0 27, 0 15, 0 | 44, 0 7, 0 0,0 100, 0 56, 0
Other | 6530, Zheng et al., 2004 | Soft tissue necrosis of NPH Cranial neuropathy Trismus Temporal lobe necrosis Endocrine dysfxn | | 3DC | 1 4 2 1 3 | 1.9 7.4 3.7 1.9 5.6
Other | 8250, Munter et al., 2003 | PEG insertion | Acute | | 6 | 13
Other | 8370, Padovani et al., 2003 | Nasal cartilage necrosis- limited | | | 1
Other | 9290, The et al., 2002 | 6 of 28 (21) grade 1 pharyngitis 10 of 28 (36) grade2 pharyngitis 12 of 28 (43%) grade 3 pharyngitis
Other | 9510, Jian et al., 2002 | 1 Pharyngitis 2 3 4 | | Concomitant CDDP | | 9.7 35.5 48.4 3.2 | Concomitant CDDP/5-FU | | 23.5 47.1 29.4 0
Other | 9510, Jian et al., 2002 | 1 neurologic deficits | | | 3 | 6
Other | 13270, Lawson et al., 2008 | Grade 1 salivary gland toxicity Grade 2 salivary gland toxicity WBC 1 2 3 4 Hct/Hb 1 2 3 4 Upper GI 1 2 3 4 | | | 18 10 4 10 6 2 13 6 0 0 3 18 2 0 | 53 29
Other | 13340 Ikushima et al, 2008 | Hematoxicity Grade 0, I, II, III, IV Renal dysfunction G 0, I, II, III, IV | 36 mo | CRT | 16,13,10,1 | 40,32.5,25, 2.5, 0 92.5, 2.5, 5, 0, 0
Other | 16840, Wu et al, 2006 | Trismus | 36 | IMRT | 0 | 0
Other | 24330, Pfreunder et al., 2003 | Weight loss RTOG G 1, 2 CTC GRADED: Hypotension G 1, 2 Hypertension G1 Alopecia G 3 Fever G 1, G2, Myalgia, Arthralgia G1, 2 Nausea G1,2 Vomiting, G1, 2 Gastritis G1, Diarrhea G1 Constipation G2 Creatine G 1, 2, 3 Urea nitrogen G, 1, 2, 3 Bilirubin G 2, 3 Transaminases G 1, 2, 3 Hemoglobin G1, 2, 3 Leucocytes G1, 2, 3 Thrombocytes G 1, 2, 3 | 75 | ICHT | 19, 4 6, 8 3 50 3, 1 13, 1 7, 19 4, 12 8 7 2 17, 6, 1 18, 9, 2 17, 1 14, 6, 1 9, 7, 2 17, 7, 2 4, 2, 2 | 39, 8 12, 16 6 100 6, 2 26, 2 14, 28 8, 24 16 14 4 34,12, 2 36, 28, 4 34, 2 28, 12, 2 18, 14, 4 34, 14, 4 8, 4, 4
Other | 38290, Anand et al., 2008 | enteral tube feeding iv fluids | 3 mos | | 22 27 | 35 44
Other | 39020, Rosenthal et al., 2008 | NCI’s common toxicity criteria Nausea Grade 0 1 2 3 4 (p value for IMRT alone vs. with CT for grades 0–4 <.004) Vomiting Grade 0 1 2 3 4 (p value for IMRT alone vs. with CT for grades 0–4 <.04) Occipital scalp epilation Headache | | IMRT alone | | 76 24 33 38 5 0 38 63 16 18 3 0 40 10 | IMRT + CT | 98 2 22 58 18 0 68 32 18 38 12 0 25 30
Other | 39390, Worden et al., 2008 | elevated creatinine enteral tube feeding | NCI CTC (v.2.0) Grade 2, 3, 4, 5 | Acute Acute | 3, 0, 0, 0, 0 21 | 4, 0, 0, 0, 0 32

Table E-O Case series/single arm trial study quality ratings

Study | Clearly Defined Question | Well- Described Study Population | Well- Described Intervention | Use of Validated Outcome Measures (Independently Assessed) | Appropriate Statistical Analysis | Well- Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
580, Dirix et al., 2007 | Y | Y | Y | Y/N | Y | Y | Y | N
1010, Urbano et al., 2007 | Y | Y | Y | Y/N | Y | Y | Y | N
3080 Meirovitz 2006 | Y | N | N | U | Y | Y | Y | Y
3340 Studer 2006 | Y | Y | Y | U | Y | Y | Y | Y
3400 Studer 2005 | Y | Y | Y | U | Y | Y | Y | N
1420 Feng et al, 2007 | Y | Y | N | Y | Y | Y | Y | Y
1430, Scrimger et al., 2007 | Y | Y | Y | Y/N | ? | Y | ? | N
1500, Lee et al., 2007 | Y | Y | Y | Y/N | Y | Y | Y | N
3570 Saarilahti 2006 | Y | Y | Y | U | Y | Y | Y | N
1770, Yao et al., 2007 | Y | Y | N | Y | Y | Y | N | N
1780, Lee et al., 2007 | Y | Y | N | Y | Y | N | U | N
3820 McMillan 2006 | Y | Y | Y | U | Y | Y | Y | Y
1900, Ben-David et al., 2007 | Y | Y | N | Y | U | Y | Y | Y
1990, Yao et al., 2007 | Y | Y | N | Y | Y | Y | Y | N
2180, Daly et al., 2007 | Y | Y | Y | Y | Y | Y | Y | N
2290, Yao et al., 2006 | N | Y | N | Y | Y | N | Y | N
2370, Garden et al., 2007 | Y | Y | N | Y | Y | Y | N | Y
4430 Kwong | Y | Y | Y | Y | Y | Y | Y | Y
2430, Vosmik et al., 2006 | Y | Y | Y | Y | U | N | N | N
4630 Yao 2005 | Y | Y | Y | U | Y | Y | Y | N
2770, Cheng et al., 2006 | Y | Y | N | Y | Y | Y | Y | Y
3320, Portaluri et al., 2006 | Y | Y | Y | Y | U | N | U | N
3790, Ozsahin et al., 2006 | N | Y | N | Y | Y | N | U | N
4290, Lau et al., 2006 | Y | Y | Y | Y | Y | Y | Y | N
6530 Zheng 2004 | Y | Y | Y | Y | Y | Y | Y | N
5020, Nishimura et al., 2005 | Y | Y | Y | Y | Y | N | Y | Y
5210, Duthoy et al., 2005 | Y | Y | Y | Y | Y | Y | Y | Y
5310, Zheng et al., 2005 | Y | Y | Y | Y | Y | Y | Y | N
5330, Lu et al., 2005 | Y | Y | N | Y | Y | Y | U | N
5420, Pan et al., 2005 | Y | Y | N | Y | U | Y | U | N
5740, Thorstad et al., 2004 | Y | N | N | U | N | N | U | Y
8270 Braaksma 2003 | Y | Y | Y | U | Y | Y | Y | N
8370 Padovani 2003 | Y | N | Y | U | Y | Y | Y | N
8400 Amosson 2003 | Y | Y | N | U | Y | Y | Y | N
6430, Kwong et al, 2004 | Y | Y | Y | Y | Y | Y | Y | N
7090, Chao et al., 2004 | Y | Y | Y | Y | Y | Y | Y | N
7110, Sze et al., 2004 | Y | N | Y | Y | Y | N | U | N
9290 Teh 2002 | Y | N | Y | U | U | Y | Y | N
9330 Kovacs 2002 | Y | Y | Y | U | Y | N | Y | N
7370, Lu et al., 2004 | Y | Y | Y | U | U | N | U | N
9510 Jian 2002 | Y | Y | Y | U | Y | Y | Y | Y
7570, Levendag et al., 2004 | N | N | N | Y | U | N | U | N
7750, Liu et al., 2003 | Y | Y | Y | Y | Y | Y | Y | N
8250, Munter et al., 2003 | Y | Y | Y | Y | U | N | U | N
10740, Pommier et al, 2000 | Y | Y | Y | Y | Y | Y | Y | N
13270 Lawson 2008 | Y | Y | Y | U | Y | Y | Y | Y
11650, Kuppersmith et al., 1999 | N | N | N | U | U | N | U | N
13340 Ikushima et al, 2008 | N | N | Y | Y | Y | Y | Y | N
16840, Wu et al, 2006 | Y | N | Y | Y | Y | Y | Y | N
26140 Scorsetti 2001 | Y | N | Y | U | Y | Y | Y | N
24330, Pfreunder et al., 2003 | Y | N | Y | Y | Y | Y | Y | N
38840 Seung 2008 | Y | Y | Y | U | Y | Y | Y | N
38850 Caglar 2008 | Y | Y | Y | U | Y | Y | Y | N
39000 Sanguineti 2008 | Y | N | Y | U | U | Y | Y | N
39020 Rosenthal 2008 | Y | Y | Y | U | Y | Y | Y | Y
37660, Wendt et al, 2006 | Y | N | Y | Y | Y | Y | Y | N
38290, Anand et al., 2008 | Y | Y | Y | Y | Y | Y | Y | N
38530, Studer et al., 2008 | Y | N | N | U | U | N | U | N
38640, Studer et al., 2008 | Y | Y | N | Y | Y | N | U | N
39300, Hoppe et al., 2008 | Y | Y | Y | Y | Y | Y | Y | N
39390, Worden et al., 2008 | Y | Y | N | Y | Y | N | U | Y