# Comparative Studies: Full Evidence/Data Abstraction Tables

Table D1a Nasopharyngeal cancer, outcomes by study

Study | Rec# | No. Pts | Setting | QOL/Adverse Events | | | | | | | Tumor Control | | | Patient Survival
Study | Rec# | No. Pts | Setting | QOL | XST | SF | DYS | MUC | SKN | ORN or BON | LC | LRC | DFS | DSS | OS
1º RT
3DCRT vs 2DRT
Jen, 2005 | 5240 | 180 | 1º RT | | X
IMRT vs 2DRT
Pow, 2006 (RCT) | 2340 | 45 | 1º RT | X | | X
Wu, 2005 | 4520 | 380 | 1º RT | | X | X
1º RT + split CTx
3DCRT vs 2DRT
Wu, 2005 (RCT) | 4360 | 96 | 1º RT + split CTx | | | | | X | | | X | | | | X
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1º RT + split CTx | | X | | X | X | X | | | X | X | | X
Mixed Settings
IMRT vs 3DCRT
Fang, 2007 | 2250 | 85 | 1º RT ± CTx (timing?) | X | X
Fang, 2008 | 39090 | 203 | 1º RT ± CCTx | X | | | | | | | | X | | | X
3DCRT vs 2DRT
Fang, 2007 | 2250 | 94 | 1º RT ± CTx (timing?) | X | X
IMRT vs 2DRT
Kam, 2007 (RCT) | 530 | 56 | 1º RT ± ICBRT | | X | X
Fang, 2007 | 2250 | 113 | 1º RT ± CTx (timing?) | X | X
Hsiung, 2006 | 3070 | 32 | 1º RT± CCTx | | X
Comparisons | 11 | | | 5 | 8 | 3 | 1 | 2 | 1 | 0 | 1 | 2 | 1 | 0 | 3
Studies | 9 | | | 3 | 6 | 3 | 1 | 2 | 1 | 0 | 1 | 2 | 1 | 0 | 3
Total n | 1174

Table D1b Nasopharyngeal cancer, participants and treatments

Study | Rec# | No. Pts | Setting | Tx Group | % Female | Median Age (rng, yrs) | % Stage III/IV | Prescribed RT Dose to Primary Tumor (Gy) | Median Follow-up (rng, mos) | Completed RT (%)
1º RT
3DCRT vs 2DRT
Jen, 2005 | 5240 | 180 | 1º RT | 3DCRT 2DR | 15 18 | 43 (19–80) 44 (18–84) | 59.7 58.3 | 70 (all) | 26 | 100 (all)
IMRT vs 2DRT
Pow, 2006 (RCT) | 2340 | 45 | 1º RT | IMRT 2DR | 25 19 | 46 (26–69) 50 (37–75) | 0 (all) | 68 68–72 | NR | NR
Wu, 2005 | 4520 | 380 | 1º RT | IMRT 2DR | 32 (all) | 38 (15–64) (all) | 85.8 (all) | 75 70 | NR | NR
1º RT + split CTx
3DCRT vs 2DRT
Wu, 2005 (RCT) | 4360 | 96 | 1º RT + split CTx | 3DCRT 2DR | 35 34 | 45 (16–68) 44 (18–67) | 100 (all) | 66–86 (all) | NR | NR
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1º RT + split CTx | IMRT 2DR | 26 18 | 14 (5–18) (all) | 84.2 94.1 | 70 (all) | 27 (4–42) | 100 88
Mixed Settings
IMRT vs 3DCRT
Fang, 2007 | 2250 | 85 | 1º RT ± CTx (timing?) | IMRT 3DCRT | 33 24 | 49 51 | 48.1 48.5 | 65–76 (all) | NR | NR
Fang, 2008 | 39090 | 203 | 1º RT ± CCTx | IMRT 3DCRT | 22 17 | NR | 52.8 55.9 | 65–76 (all) | 40 (5–57) 46 (10–59) | NR
3DCRT vs 2DRT
Fang, 2007 | 2250 | 94 | 1º RT ± CTx (timing?) | 3DCRT 2DR | 24 28 | 51 51 | 48.1 50.8 | 65–76 (all) | 46 (10–59) | NR
IMRT vs 2DRT
Kam, 2007 (RCT) | 530 | 56 | 1º RT ± ICBRT | IMRT 2DR | 25 32 | 46 50 | 0 (all) | 66 + 18 Gy ICB 66 + 12 Gy ICB | NR | 100 (all)
Fang, 2007 | 2250 | 113 | 1º RT ± CTx (timing?) | IMRT 2DR | 29 28 | 49 51 | 48.5 50.8 | 60–70 (all) | NR | NR
Hsiung, 2006 | 3070 | 32 | 1º RT± CCTx | IMRT 2DR | 31 25 | NR | 50 37.5 | 67–70 68–76 | 24 (14–34) | NR

Table D1c Nasopharyngeal cancer, comparative study quality items

Study | Rec# | No. Pts | Select Pro/Retro | Incl/Excl Clear | Rep Select | Initl Grps Comp | Bal by Design (Mtch) | BL Chars Clr Comp | Txs Same Time Per | Unbiased Alloc | Other Txs Equal | Maint Comp Grps | Overall Attr <20% | Non-diffl Attr <15% | Out-comes Val, Rel, = | Assessors Blind | Txs Clr | Adequate F/U | Analysis: Adj for Confs | USPSTF
1º RT
3DCRT vs 2DRT
Jen, 2005 | 5240 | 180 | R | N | N | ? | N | Y | ? | E | NA | NA | NA | NA | Y | N | Y | md 26 | Y/? | Poor
IMRT vs 2DRT
Pow, 2006 (RCT) | 2340 | 45 | P | Y | Y | Y | Y | Y | Y | ? | NA | Y | Y | Y | Y | Y | Y | ? | N | Poor
Wu, 2005 | 4520 | 380 | R | Y | Y | ? | N | ? | ? | ? | NA | NA | NA | NA | Y | N | Y | ? | N | Poor
1º RT + split CTx
3DCRT vs 2DRT
Wu, 2005 (RCT) | 4360 | 96 | P | Y | Y | ? | Y | Y | Y | ? | Y | ? | Y | Y | Y | N | Y | ? | N | Poor
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | P | Y | Y | Y | N | Y | Y | A/P | Y | ? | Y | Y | Y | ? | Y | md 27 | Y/? | Poor
Mixed Settings
IMRT vs 3DCRT
Fang, 2007 | 2250 | 85 | R | Y | N | Y | N | Y | N | E | ? | NA | NA | NA | Y | N | Y | ? | N | Poor
Fang, 2008 | 39090 | 203 | P | Y | Y | Y | N | Y | Y | A/P | Y | ? | Y | Y | Y | ? | Y | md 40,46 | Y/? | Poor
3DCRT vs 2DRT
Fang, 2007 | 2250 | 94 | R | Y | N | Y | N | Y | N | E | ? | NA | NA | NA | Y | N | Y | ? | N | Poor
IMRT vs 2DRT
Kam, 2007 (RCT) | 530 | 56 | P | Y | Y | Y | Y | Y | Y | Y | N | ? | Y | Y | Y | ? | Y | ? | Y | Fair
Fang, 2007 | 2250 | 113 | R | Y | N | Y | N | Y | N | E | ? | NA | NA | NA | Y | N | Y | ? | N | Poor
Hsiung, 2006 | 3070 | 32 | R | Y | ? | N | N | Y | N | E | N | NA | NA | NA | Y | N | Y | md 24 | N | Poor

Table D1d Nasopharyngeal cancer, multivariate adjustment for confounders quality items

Study | Rec# | Pro design | Prespec hypoths | Lrg, well-defd, rep study pop | Pred factor meths well-descrd | Blinded assess pred factor | Homog txs, rand/unbiased alloc | Low rate of missing data (<15%) | Sufficiently long F/U | Clear cand var select | Clear appr model bldg GLs | Asmpt tested | Stand progn vars incld | Cont vars well hndld | Validation
1º RT
3DCRT vs 2DRT
Jen, 2005 | 5240 | N | N | Y | Y | NA | Y | ? | md 26 | Y | N | ? | ? | ? | N
1º RT + split CTx
IMRT vs 2DRT
Laskar, 2008 | 39050 | Y | N | N | Y | NA | Y | Y | md 27 | N | ? | ? | ? | ? | N
Mixed Settings
IMRT vs 3DCRT
Fang, 2008 | 39090 | Y | N | Y | Y | NA | N | Y | md 40, 46 | N | ? | ? | ? | ? | N

Table D1e Nasopharyngeal cancer, quality of life

EORTC QLQ-C30
| Pow, 2006; Rec # 2340 | | | | Fang, 2008; Rec # 39090 | | | | Fang, 2007; Rec # 2250
Item | Mean IMRT n=24 | Mean 2DRT n=21 | Mo F/U | p Value | Mean IMRT n≥79 | Mean 3DCRT n≥66 | Mo F/U | p Value | Mean IMRT n=52 | Mean 3DCRT n=33 | Mean 2DRT n=61 | Mo F/U | IMRT vs 3DCRT p value
Global health | 54.9 63.2 63.9 | 52.8 61.9 63.5 | 2 6 12 all | | 41 44 58 61 | 46 56 63 64 | 0 3 12 24 | <0.05 | 49 | 61 | 64 | 24–36 | NS
Global health-revised | 53.8 61.5 62.2 | 53.6 60.3 62.3 | 2 6 12 all | | | | | | | | | | NS
Physical function | 84.4 86.9 91.1 | 83.8 88.3 90.5 | 2 6 12 all | | 84 79 86 87 | 87 86 90 91 | 0 3 12 24 | | 80 | 87 | 91 | 24–36 | NS
Role function | 94.4 96.5 97.2 | 94.4 97.6 96.0 | 2 6 12 all | | 86 84 90 90 | 86 88 92 92 | 0 3 12 24 | | 82 | 90 | 92 | 24–36 | NS
Role function- revised | 81.9 92.4 100.0 | 84.9 96.8 95.2 | 2 6 12 all | <0.05 | | | | | | | | | NS
Emotional function | 87.8 91.3 91.7 | 83.7 89.7 88.9 | 2 6 12 all | | | | | | 76 | 84 | 85 | 24–36 | NS
Cognitive function | 86.1 86.8 89.6 | 85.7 86.5 84.1 | 2 6 12 all | | | | | | 77 | 85 | 85 | 24–36 | NS
Social function | 81.3 91.0 93.1 | 83.3 91.3 92.9 | 2 6 12 all | | 72 71 82 82 | 71 77 81 83 | 0 3 12 24 | | 75 | 82 | 83 | 24–36 | NS
Fatigue | 20.4 16.7 13.0 | 20.1 14.8 13.8 | 2 6 12 all | | 36 39 25 24 | 34 29 24 25 | 0 3 12 24 | <0.05 | 35 | 24 | 25 | 24–36 | NS
Nausea/vomiting | 7.6 0.0 0.7 | 3.2 0.0 2.4 | 2 6 12 all | | 26 15 8 4 | 22 11 8 4 | 0 3 12 24 | | 9 | 4 | 4 | 24–36 | NS
Pain | 7.6 6.3 2.8 | 7.9 7.1 9.5 | 2 6 12 all | | 35 26 10 11 | 28 18 14 12 | 0 3 12 24 | | 25 | 11 | 12 | 24–36 | NS
Dyspnea | 13.9 8.3 4.2 | 12.7 9.5 3.2 | 2 6 12 all | | 11 16 6 6 | 13 11 7 6 | 0 3 12 24 | | 17 | 6 | 6 | 24–36 | NS
Insomnia | 15.3 6.9 6.9 | 14.3 12.7 11.1 | 2 6 12 all | | 27 30 22 19 | 23 25 22 21 | 0 3 12 24 | | 27 | 19 | 21 | 24–36 | NS
Appetite loss | 23.6 8.3 8.3 | 15.9 7.9 7.9 | 2 6 12 all | | 43 32 10 9 | 41 21 11 8 | 0 3 12 24 | | 19 | 9 | 8 | 24–36 | NS
Constipation | 11.1 6.9 5.6 | 15.9 7.9 11.1 | 2 6 12 all | | 16 20 17 15 | 17 11 13 13 | 0 3 12 24 | | 17 | 15 | 13 | 24–36 | NS
Diarrhea | 0.0 4.2 1.4 | 11.1 7.9 4.8 | 2 6 12 all | <0.05 0.009 | 19 16 10 10 | 14 11 10 11 | 0 3 12 24 | | 12 | 10 | 11 | 24–36 | NS
Financial difficulties | 15.3 11.1 5.6 | 11.1 14.3 11.1 | 2 6 12 all | | 25 30 20 22 | 23 22 22 23 | 0 3 12 24 | | 26 | 22 | 23 | 24–36 | NS

SF-36
| Pow, 2006, Rec# 2340
Domain | Mean IMRT n=24 | Mean 2DRT n=21 | Mo F/U | p Value
Physical function | 89.4 92.5 94.4 | 88.3 92.6 93.8 | 2 6 12 all
Role-physical | 33.3 60.4 86.5 | 27.4 48.8 58.3 | 2 6 12 all | <0.05
Bodily pain | 78.0 85.4 89.8 | 76.2 82.5 75.6 | 2 6 12 all | <0.05
General health | 51.8 55.8 65.7 | 47.9 52.9 58.7 | 2 6 12 all
Vitality | 58.1 65.2 70.6 | 57.6 61.2 63.1 | 2 6 12 all
Social functioning | 71.4 92.2 91.7 | 70.2 86.9 92.3 | 2 6 12 all
Role-emotional | 50.0 77.8 86.1 | 47.6 55.6 73.0 | 2 6 12 all
Mental health | 76.5 80.8 84.5 | 74.5 76.8 80.8 | 2 6 12 all

EORTC QLQ-H&N35
| Pow, 2006; Rec # 2340 | | | | Fang, 2008; Rec # 39090 | | | | Fang, 2007; Rec # 2250
Item | Mean IMRT n=24 | Mean 2DRT n=21 | Mo F/U | p Value | Mean IMRT n≥79 | Mean 3DCRT n≥66 | Mo F/U | p Value | Mean IMRT n=52 | Mean 3DCRT n=33 | Mean 2DRT n=61 | Mo F/U | IMRT vs 3DCRT p value
Pain | 15.6 9.4 7.3 | 16.7 15.1 12.7 | 2 6 12 all | | 37 27 15 13 | 34 20 11 10 | 0 3* 12 24 | | 18 | 13 | 10 | 24–36 | NS
Swallowing | 9.0 8.7 6.6 | 13.5 10.7 10.7 | 2 6 12 all | <0.05 0.022 | 38 26 23 22 | 35 21 17 16 | 0 3* 12 24 | | 30 | 22 | 16 | 24–36 | NS
Taste/smell | 42.4 27.1 20.1 | 28.6 17.5 18.3 | 2 6 12 all | <0.05 | 36 35 23 22 | 40 22 21 19 | 0 3 12 24 | <0.05 | 29 | 22 | 19 | 24–36 | NS
Speech | 12.5 7.4 3.2 | 13.2 15.9 10.1 | 2 6 12 All | <0.05 <0.05 0.053 | 18 26 14 12 | 19 17 14 12 | 0 3 12 24 | | 25 | 12 | 12 | 24–36 | NS
Social eating | 22.2 11.1 7.3 | 22.5 13.6 11.5 | 2 6 12 all | | 35 27 17 16 | 37 22 14 13 | 0 3 12 24 | | 30 | 16 | 13 | 24–36 | NS
Social contact | 6.4 3.3 0.8 | 7.6 2.5 2.2 | 2 6 12 all | | 15 18 9 9 | 20 15 10 8 | 0 3 12 24 | | 18 | 9 | 8 | 24–36 | NS
Sexuality | 31.1 24.2 22.0 | 35.6 26.7 25.6 | 2 6 12 all | | 27 33 24 24 | 30 25 19 19 | 0 3 12 24 | | 27 | 24 | 19 | 24–36 | NS
Teeth | 8.3 5.6 6.9 | 5.0 5.0 5.0 | 2 6 12 all | | 23 24 23 21 | 21 20 22 21 | 0 3 12 24 | | 40 | 21 | 21 | 24–36 | NS
Opening mouth | 8.3 15.3 12.5 | 14.3 23.8 19.0 | 2 6 12 all | | 24 21 16 15 | 21 15 15 14 | 0 3* 12 24 | | 33 | 15 | 14 | 24–36 | NS
Dry mouth | 72.2 59.7 47.2 | 81.0 69.8 60.3 | 2 6 12 all | 0.021 | 54 59 45 44 | 50 49 41 41 | 0 3 12 24 | <0.05 | 53 | 44 | 41 | 24–36 | NS
Sticky saliva | 62.5 44.4 40.3 | 87.3 79.3 66.7 | 2 6 12 all | <0.05 <0.05 <0.05 <0.001 | 46 45 34 35 | 46 44 34 34 | 0 3 12 24 | | 47 | 35 | 34 | 24–36 | NS
Coughing | 12.5 6.9 4.2 | 11.1 19.0 12.7 | 2 6 12 all | <0.05 | 31 30 20 19 | 27 25 20 20 | 0 3 12 24 | | 27 | 19 | 20 | 24–36 | NS
Feeling ill | 4.2 4.2 4.2 | 6.3 9.5 6.3 | 2 6 12 all | | 38 36 24 23 | 34 25 20 20 | 0 3 12 24 | <0.05 | 34 | 23 | 20 | 24–36 | NS
Pain killers | 4.2 4.2 12.5 | 14.3 4.8 9.5 | 2 6 12 all
Nutrition supplement | 33.3 20.8 20.8 | 9.5 23.8 28.6 | 2 6 12 all
Feeding tube | 4.2 0.0 0.0 | 0.0 0.0 0.0 | 2 6 12 all
Weight loss | 25.0 8.3 4.2 | 9.5 19.0 0.0 | 2 6 12 all
Weight gain | 16.7 25.0 37.5 | 47.6 23.8 28.6 | 2 6 12 all | <0.05

Table D1f Nasopharyngeal cancer, xerostomia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
1° RT
3DCRT vs 2DRT
Jen, 2005 | 5240 | 180 | 1° RT | 3DCRT 2DRT | 59.7 58.3 | RTOG | 2–3 | | | OR: 0.55 | 0.0053 | MVA: GEE method
IMRT vs 2DRT
Wu, 2005 | 4520 | 380 | 1° RT | IMRT 2DRT | 85.8 (all) | ? | ? | 20.4 23.4 | NR
1° RT + split CTx
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1° RT + split CTx | IMRT 2DRT | 84.2 94.1 | RTOG | > 2 | 31.6 88.2 | 0.002
Mixed Settings
IMRT vs 2DRT
Kam, 2007 (RCT) | 530 | 56 | 1° RT ± ICBRT | IMRT 2DRT | 0 0 | RTOG EORTC 6 wk, 6 mo, 1 yr | 2–4 | 45.4 85.7 | 0.002 | 75 92.9 39.3 82.1 | 0.001
Hsiung, 2006 | 3070 | 32 | 1° RT± CCTx | IMRT 2DRT | 50 37.5 | RTOG | 2–3 | | | 50 100 | <0.001

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Scale | Item | Mean | F/U | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Fang, 2007 | 2250 | 85 | 1° RT ± CTx (timing?) | IMRT 3DCRT | 48.1 48.5 | QLQ-H&N35 item | Dry mouth | 41 44 | 2–3 yr | NR | MVA combined IMRT+3DCRT
3DCRT vs 2DRT
Fang, 2007 | 2250 | 94 | 1° RT ± CTx (timing?) | 3DCRT 2DRT | 48.5 50.8 | QLQ-H&N35 item | Dry mouth | 44 53 | 2–3 yr | <0.05 | MVA combined IMRT+3DCRT
IMRT vs 2DRT
Kam, 2007 (RCT) | 530 | 56 | 1° RT ± ICBRT | IMRT 2DRT | 0 0 | 6-item XST scale | Total (follow-up minus baseline) | −38.4 −37.2 −30.7 −31.8 −24.3 −33.1 | 6 wk 6 mo 1 yr | 0.99 0.86 0.32
Fang, 2007 | 2250 | 113 | 1° RT ± CTx (timing?) | IMRT 2DRT | 48.1 50.8 | QLQ-H&N35 item | Dry mouth | 41 53 | 2–3 yr | <0.05 | MVA combined IMRT+3DCRT

Table D1g Nasopharyngeal cancer, salivary flow

Study | Rec# | No. Pts | Setting | Group | % Stage 0/I/II | % Stage III/IV | Mos Post-RT | Stimulated Flow Ratio % of Baseline | Unstimulated Flow Ratio % of Baseline | Comments
1° RT
IMRT vs 2DRT
Pow, 2006 (RCT) | 2340 | 45 | 1° RT | IMRT 2DRT IMRT 2DRT IMRT 2DRT IMRT 2DRT IMRT 2DRT IMRT 2DRT | 100 100 | 0 0 | SWS 2 2 6 6 12 12 SPS 2 2 6 6 12 12 | (calculated) 0.14 0.08 0.19 0.04 0.26 0.06 0.28 0 0.57 0 1.28 0 | NR | Saliva stimulated by chewing on sterile rubber tubing. SWS collected 5 min in cup; SPS collected 15 min w/Lashley cup & suction over parotid duct on one side. SWS: 2DRT vs IMRT, p < 0.003 at 2, 6, 12 mos (ANOVA) SPS: 2DRT vs IMRT, p < 0.002 at 2, 6, 12 mos (ANOVA) SEE IF INFO ON DOSE-SLOW FOR THIS AND PREVIOUS ARTICLE
Wu, 2005 | 4520 | 380 | 1° RT | 2DRT IMRT | 14.2 (all) | 85.8 (all) | | | % w/↓ in parotid 82 70 | For static secretion function (rated as a decrease if flow < 0.3 mL/min, i.e., no baseline measure), p < 0.05 CF, LCAF vs IMRT for percentage pts decreased post-RT. Measured 3 hrs after last food or mouthwash, then removed from parotid gland w/catheter for 15 min.
Mixed Settings
IMRT vs 2DRT
Kam, 2007 (RCT) | 530 | 56 | 1° RT ± ICBRT | IMRT 2DRT IMRT 2DRT IMRT 2DRT IMRT 2DRT IMRT 2DRT IMRT 2DRT | 100 100 | 0 0 | 1.5 1.5 6 6 12 12 1.5 1.5 6 6 12 12 | Fractional SWSFR 0.32 0.28 0.30 0.20 0.41 0.20 Fractional SPFR 0.39 0.09 0.70 0.04 0.90 0.05 | NR | Measured amount spit out for 5 minutes after stimulated using gum for 1 min: 2DRT vs IMRT p < 0.01 at 12 mos (paired t-test). Measured amt collected with suction cup from orifice of each parotid duct for 15 min after stimulated w/lemon candy w/fixed citric acid content: 2DRT vs IMRT p < 0.001 at 1.5, 6, 12 mos (paired t-test)

Table D1h Nasopharyngeal cancer, dysphagia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
1° RT + split CTx
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1° RT + split CTx | IMRT 2DRT | 84.2 94.1 | RTOG | ≥ 2 ≥ 3 | 42.0 94.1 10.5 41.2 | 0.01 0.035

Table D1i Nasopharyngeal cancer, mucositis

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
1° RT + split CTx
3DCRT vs 2DRT
Wu, 2005 (RCT) | 4360 | 96 | 1° RT + split CTx | 3DCRT 2DRT | 100 100 | ? | 1–2 3–4 | 69.6 64.0 30.4 36.0 | 0.563
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1° RT + split CTx | IMRT 2DRT | 84.2 94.1 | RTOG | ≥ 2 ≥ 3 | 78.9 100 15.8 52.9 | 0.066 0.033

Table D1j Nasopharyngeal cancer, skin

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
1° RT + split CTx
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1° RT + split CTx | IMRT 2DRT | 84.2 94.1 | RTOG | ≥ 2 ≥ > 3 | 84.2 100 5.3 47.1 | 0.136 0.006

Table D1k Nasopharyngeal cancer, oteoradionecrosis/bone

No studies.

Table D1l Nasopharyngeal cancer, tumor control

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
1° RT + split CTx
3DCRT vs 2DRT
Wu, 2005 (RCT) | 4360 | 96 | 1° RT + split CTx | 3DCRT 2DRT | 100 100 | LC | 97.8 78.0 | | | | | 0.003
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1° RT + split CTx | IMRT 2DRT | 84.2 94.1 | LRC | | 84.2 68.3 | | | | 0.201 | RT tech not entered in MVA
| | | | | | DFS | | 67.5 55.8 | | | | 0.477 | RT tech not entered in MVA
Mixed Settings
IMRT vs 3DCRT
Fang, 2008 | 39090 | 203 | 1° RT ± CCTx | IMRT 3DCRT | 52.8 55.9 | LRC | ~95 ~98 | 84.2 ~90 | 84.2 84.8 | 84.2 ~83 | | 0.85 (3 yr) | RT tech NS in MVA

Table D1m Nasopharyngeal cancer, patient survival

Overall Survival
Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
1° RT + split CTx
3DCRT vs 2DRT
Wu, 2005 (RCT) | 4360 | 96 | 1° RT + split CTx | 3DCRT 2DRT | 100 100 | OS | 100 96 | | | | | 0.17
IMRT vs 2DRT
Laskar, 2008 | 39050 | 36 | 1° RT + split CTx | IMRT 2DRT | 84.2 94.1 | OS | | 80.8 66.7 | | | | 0.641 | RT tech not entered in MVA
Mixed Settings
IMRT vs 3DCRT
Fang, 2008 | 39090 | 203 | 1° RT ± CCTx | IMRT 3DCRT | 52.8 55.9 | OS | ~96 ~98 | ~90 ~92 | 85.4 81.7 | ~79 ~78 | | 0.58 (3 yr) | RT tech NS in MVA

Table D2a Oropharyngeal cancer, outcomes by study

Study | Rec# | No. Pts | Setting | QOL/Adverse Events | | | | | | | Tumor Control | | | Patient Survival
Study | Rec# | No. Pts | Setting | QOL | XST | SF | DYS | MUC | SKN | ORN or BON | All LC | LRC | DFS | DSS | OS
1° RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | 87 | 1° RT + CCTx | | X | | | X | X | | | X | X | | X
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | 1° RT + CCTx | | X | | | X | X | | X | | X | | X
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | 195 | 1° RT ± CCTx | | X | | | X | | | | X | | X | X
Rades, 2007 | 2710 | 44 | postop RT ± CCTx | | X | | | X | X | | X | | | | X
Nutting, 2009 (RCT) | 41220 | 84 | 1° RT/postop ± pre RT CTx | | X | | X | X | X | X | | X | | | X
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | postop RT ± CCTx | | X | | | X | X | | X | | | | X
IMRT vs 2DRT
Yao, 2007 | 1120 | 53 | 1° RT ± CTx (timing?) | X
Rades, 2007 | 2710 | 122 | postop RT ± CCTx | | X | | | X | X | | X | | | | X
Chao, 2001 | 9940 | 430 | 1°/preop/postop RT ± CCTx | | X | | X | X | X | X | | X | X | | X
Comparisons | 9 | | | 1 | 8 | 0 | 2 | 8 | 7 | 2 | 4 | 4 | 3 | 1 | 8
Studies | 7 | | | 1 | 6 | 0 | 2 | 6 | 5 | 2 | 2 | 4 | 3 | 1 | 6
Total n | 1109

Table D2b Oropharyngeal cancer, participants and treatments

Study | Rec# | No. Pts | Setting | Tx Group | % Female | Median Age (rng, yrs) | % Stage III/IV | Prescribed RT Dose to Primary Tumor (Gy) | Median Follow-up (rng, mos) | Completed RT (%)
1° RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | 87 | 1° RT + CCTx | IMRT 3DCRT | 12 9 | NR | 100 (all) | 70–72 66–70 | 24 (3–103) | 100 97
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | 1° RT + CCTx | IMRT 2DR | 12 17 | 55 (28–78) 56 (33–80) | 100 98.6 | 66–70 70–72 | 46 (3–93) | 100 99
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | 195 | 1° RT ± CCTx | IMRT 3DCRT 3DCRTpre | 27 5 29 | NR | 86 100 78 | 65–70 60–78 | 31 (3–166) (all) | NR
Rades, 2007 | 2710 | 44 | postop RT ± CCTx | IMRT 3DCRT | NR | NR | ≤ 50 ≤ 65 balance? | 60–70 (all) | NR | NR
Nutting, 2009 | 41220 | 84 | 1° RT/postop ± preRT CTx | IMRT 3DCRT | 28% (all) | 58.4 (mn all) | 77 (all) | 65, 61 64, 61 (1°, postop) | 31.9 (23.5–38.8, all) | NR
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | postop RT ± CCTx | 3DCRT 2DR | NR | NR | ≥65 ≥54 | 60–70 (all) | NR | NR
IMRT vs 2DRT
Yao, 2007 | 1120 | 53 | 1° RT ± CTx (timing?) | IMRT 2DR | 19.2 18.5 | 58 53 | 96.2 85.2 | 70 (all) | NR | NR
Rades, 2007 | 2710 | 122 | postop RT ± CCTx | IMRT 2DR | NR | NR | ≥50 ≥54 | 60–70 (all) | NR | NR
Chao, 2001 | 9940 | 430 | 1°/preop/postop RT ± CCTx | defIMRT def2DRT postopIMRT postop2DRT preop2DRT | 8 25 14 26 27 | 56 (50–71) 61 (43–86) 49 (42–76) 60 (30–81) 58 (33–83) | 91.7 63.7 85.7 86.7 71.6 | 70.3 (70.2–72) 70 (60–76) 63.6 (55.1–66.5) 64.8 (50–72) 30 (28–70) | 47 (12–276) | NR

Table D2c Oropharyngeal cancer, comparative study quality items

Study | Rec# | No.Pts | Select Pro/Retro | Incl/Excl Clear | Rep Select | Initial Grps Comp | Bal by Design (Mtch) | BL Chars Clear Comp | Txs Same Time Per | Unbiased Alloc | Other Txs Equal | Maint Comp Grps | Overall Attr <20% | Non-diffl Attr <15% | Outcomes Val, Rel, = | Assessors Blind | Txs Clear | Adequate F/U | Analysis: Adj for Confs | USPSTF
1° RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | 87 | R | Y | Y | N | N | N | ? | ? | N | NA | NA | NA | Y | N | Y | md 24 | Y/? | Poor
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | R | Y | Y | ? | N | Y | ? | ? | Y | NA | NA | NA | Y | N | Y | md 46 | N | Poor
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | 195 | R | Y | Y | Y | N | Y | Y+N | Y/E | Y | NA | NA | NA | Y | N | Y | md 31 | Y/? | Poor
Rades, 2007 | 2710 | 44 | R | Y | Y | Y | N | Y | ? | WL | Y | NA | NA | NA | Y | N | Y | ? | Y/? | Poor
Nutting, 2009 (RCT) | 41220 | 84 | P | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | ? | Y | md 32 | Y | Good
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | R | Y | Y | Y | N | Y | ? | WL | Y | NA | NA | NA | Y | N | Y | ? | Y/? | Poor
IMRT vs 2DRT
Yao, 2007 | 1120 | 53 | P | Y | Y | N | N | N | N | E | N | NA | Y | Y | Y | ? | Y | ? | N | Poor
Rades, 2007 | 2710 | 122 | R | Y | Y | Y | N | Y | ? | WL | Y | NA | NA | NA | Y | N | Y | ? | Y/? | Poor
Chao, 2001 | 9940 | 430 | R | Y | Y | N | N | Y | N | E | N | NA | NA | NA | Y | N | Y | ? | Y/? | Poor

?: unclear; Adj for Conf: adjustment for confounders; Alloc: allocation; Attr: attrition; B: both concurrent and nonconcurrent control groups; Bal: balanced; BL chars: baseline characteristics; comp: comparable; CR: consecutive retrospective; E: era; F/U: followup; Grps: groups; M: mostly; md: median; Maint: maintenance; Mtch: matched design; N: no; NA: not applicable; Non-diffl: nondifferential; NR: not reported; P/pro: prospective; R/retro: retrospective; Rep: representative; Select: selection; Txs: treatments; W: waiting list; Y: yes; Y/?: multivariate analysis performed of uncertain quality

Table D2d Oropharyngeal cancer, multivariate adjustment for confounders quality items

Study | Rec# | Pro design | Prespec hypoths | Large, well-defd, rep study pop | Pred factor meths well-descrd | Blinded assess pred factor | Homog txs, rand/unbiased alloc | Low rate of missing data (<15%) | Sufficiently long F/U | Clear cand var select | Clear, appr model bldg GLs | Asmpt tested | Stand progn vars incld | Cont vars well hndld | Validation
1° RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | N | N | N | Y | NA | Y | NA | md 24 | Y | ? | ? | ? | Y | N
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | N | N | Y | Y | NA | N | NA | md 31 | N | ? | ? | ? | ? | N
Rades, 2007 | 2710 | N | N | Y | Y | NA | N | NA | ? | Y | N | ? | N | ? | N
3DCRT vs 2DRT
Rades, 2007 | 2710 | N | N | Y | Y | NA | N | NA | ? | Y | N | ? | N | ? | N
IMRT vs 2DRT
Rades, 2007 | 2710 | N | N | Y | Y | NA | N | NA | ? | Y | N | ? | N | ? | N
Chao, 2001 | 9940 | N | N | Y | Y | NA | N | NA | ? | N | ? | ? | ? | ? | N

Assmpt test: model assumptions tested; Blinded assess pred factor: blinded assessment of predictive factor; Clear, appr model bldg GLs: clear, appropriate model-buliding guidelines followed; Clear cand var select: clear candidate variable selection for multivariate analysis; Cont vars well hndld: continuous variable well-handled; Homog txs, rand/unbiased alloc: homogeneous treatments, randomized or otherwise unbiased allocation to treatment group; Prespec hypoths: prespecified hypotheses relating predicting factor to outcome; well-defd, rep study pop: well-defined, representative study population; pred factor study meths well-descrd: predictive factor study methods well-described; Stand prong vars incld: standard prognostic variables included

Table D2e Oropharyngeal cancer, quality of life

Head and Neck Cancer Inventory (HNCI)
Mixed Settings | Yao, 2007, Rec # 1120
IMRT vs 2DRT | Yao, 2007, Rec # 1120
Domain | Mean IMRT n=26 | Mean 2DRT n=27 | Mo F/U | p Value | Difference | Magnitude of Clinically Difference Important
Eating | 34.5 42.1 55.4 | 34.9 31.7 39.0 | 3 6 12 | 0.007 | 0.4 10.2 16.4 | Small Medium
Speech | 83.2 | 74.3 | | 0.059 | 8.9 | Small
Aesthetics | 90.4 | 79.3 | | 0.069 | 11.1 | Small
Social Disruption | 86.1 | 78.8 | | 0.115 | 7.3 | Small

Table D2f Oropharyngeal cancer, xerostomia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
1º RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | 87 | 1º RT + CCTx | IMRT 3DCRT | 100 100 | RTOG | ≥ 2 | | | 62 100 15 94 6 93 | <0.001 <0.001 <0.001 | 6 mo 12 mo 18 mo
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | 1º RT + CCTx | IMRT 2DRT | 100 98.6 | RTOG/EORTC | ≥ 2 | | | 12 67 | 0.002
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | 195 | 1º RT ± CCTx | IMRT 3DCRT 3DCRT pre | 86 100 78 | RTOG | mod | | | 56 63 67 | 0.3
Rades, 2007 | 2710 | 44 | postop RT ± CCTx | IMRT 3DCRT | ≥50 ≥65 | RTOG | 2–3 | | | 17 73 | 0.037
Nutting, 2009 | 41220 | 84 | 1º RT/postop ± preRT CTx | IMRT 3DCRT | 77 (all) | LENT SOM | ≥ 2 | 71 91 | 0.02 | 62 83 60 86 39 74 29 71 | 0.04 0.01 0.004 0.003 | late = 3 mo 6 mo 12 mo 18 mo
| | | | IMRT 3DCRT | | RTOG | ≥ 2 | | | 56 78 47 83 41 64 20 81 | 0.03 0.001 0.05 0.001 | late = 3 mo 6 mo 12 mo 18 mo
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | postop RT ± CCTx | 3DCRT 2DRT | ≥65 ≥54 | RTOG | 2–3 | | | 73 63
IMRT vs 2DRT
Rades, 2007 | 2710 | 122 | postop RT ± CCTx | IMRT 2DRT | ≥50 ≥54 | RTOG | 2–3 | | | 17 63 | 0.037
Chao, 2001 | 9940 | 430 | 1º/preop/p ostop RT ± CCTx | defIMR T def2DR T postopI MRT postop2 DRT preop2 DRT | 91.7 63.7 85.7 86.7 71.6 | RTOG | > 2 | 75 69.3 64.3 63.4 18.3 | NR | 30 83.9 16.7 79.1 31.7 | <0.0001

Table D2g Oropharyngeal cancer, salivary flow

No studies.

Table D2h Oropharyngeal cancer, dysphagia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Nutting, 2009 | 41220 | 84 | 1º RT/postop ± preRT CTx | IMRT 3DCRT | 77 (all) | CTCAE v3 (acute) LENT SOM (late) | ≥ 2 | 87 98 | 0.05 | 13 6 | 0.44
IMRT vs 2DRT
Chao, 2001 | 9940 | 430 | 1º/preop/postop RT ± CCTx | defIMRT def2DRT postopIMRT postop2DRT preop2DRT | 91.7 63.7 85.7 86.7 71.6 | RTOG | 2–3 | 50 66 28.6 50.7 32.1 | NR

Table D2i Oropharyngeal cancer, mucositis

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
1º RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | 87 | 1º RT + CCTx | IMRT 3DCRT | 100 100 | CTC | ≥ 3 | 81 78 | NR
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | 1º RT + CCTx | IMRT 2DRT | 100 98.6 | RTOG/EORTC | 3–4 | 66 72 | NR
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | 195 | 1º RT ± CCTx | IMRT 3DCRT 3DCRTpre | 86 100 78 | RTOG | 3 | 58 75 65 | 0.2 1.0 | | | pre=preIMRT era
Rades, 2007 | 2710 | 44 | postop RT ± CCTx | IMRT 3DCRT | ≥50 ≥65 | CTC | 2–3 | ~89 ~93 | NR
Nutting, 2009 | 41220 | 84 | 1º RT/postop ± preRT CTx | IMRT 3DCRT | 77 (all) | CTCAE v3 (acute) LENT SOM (late) | ≥ 2 | 91 98 | 0.18 | 23 15 | 0.55
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | postop RT ± CCTx | 3DCRT 2DRT | ≥65 ≥54 | CTC | 2–3 | ~93 ~90 | NR
IMRT vs 2DRT
Rades, 2007 | 2710 | 122 | postop RT ± CCTx | IMRT 2DRT | ≥50 ≥54 | CTC | 2–3 | ~89 ~90 | NR
Chao, 2001 | 9940 | 430 | 1º/preop/postop RT ± CCTx | defIMRT def2DRT postopIMRT postop2DRT preop2DRT | 91.7 63.7 85.7 86.7 71.6 | RTOG | 2–3 | 100 91.5 92.9 79.6 36.8 | NR | 10 11.9 0 17.3 2 | NR

Table D2j Oropharyngeal cancer, skin

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
1º RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | 87 | 1º RT + CCTx | IMRT 3DCRT | 100 100 | CTC | ≥ 3 | 34 52 | 0.002
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | 1º RT + CCTx | IMRT 2DRT | 100 98.6 | RTOG/EORTC | 3–4 | 10 14 | NR
Mixed Settings
IMRT vs 3DCRT
Rades, 2007 | 2710 | 44 | postop RT ± CCTx | IMRT 3DCRT | ≥50 ≥65 | Acute-CTC; Late-RTOG | 2–3 | ~95 ~90 | NR | ~7 ~12 | NR
Nutting, 2009 | 41220 | 84 | 1º RT/postop ± preRT CTx | IMRT 3DCRT | 77 (all) | CTCAE v3 (acute) LENT SOM (late) | ≥ 2 | 76 93 | 0.02 | 8 15 | 0.46
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | postop RT ± CCTx | 3DCRT 2DRT | ≥65 ≥54 | Acute-CTC; Late-RTOG | 2–3 | ~90 ~93 | NR | ~12 ~14 | NR
IMRT vs 2DRT
Rades, 2007 | 2710 | 122 | postop RT ± CCTx | IMRT 2DRT | ≥50 ≥54 | Acute-CTC; Late-RTOG | 2–3 | ~95 ~93 | NR | ~7 ~14 | NR
Chao, 2001 | 9940 | 430 | 1º/preop/postop RT ± CCTx | defIMRT def2DRT postopIMRT postop2DRT preop2DRT | 91.7 63.7 85.7 86.7 71.6 | RTOG | 2–3 | 58.3 72.5 57.1 57.7 27.5 | NR | 10 16.8 8.3 15.8 5.0 | NR

Table D2k Oropharyngeal cancer, oteoradionecrosis/bone

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Nutting, 2009 | 41220 | 84 | 1º RT/postop ± preRT CTx | IMRT 3DCRT | 77 (all) | LENT SOM | ≥ 2 | | | 13 12 | 1.00
IMRT vs 2DRT
Chao, 2001 | 9940 | 430 | 1º/preop/postop RT ± CCTx | defIMRT def2DRT postopIMRT postop2DRT preop2DRT | 91.7 63.7 85.7 86.7 71.6 | RTOG | 2–3 | | | 0 6.3 0 2.9 5.9 | NR

Table D2l Oropharyngeal cancer, tumor control

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
1º RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 1320 0 | 87 | 1º RT + CCTx | IMRT 3DCRT | 100 100 | LRC | ~100 ~87 | 96 81 | 96 81 | 96 81 | | 0.21 | MVA IMRT vs 3DCRT+AFxC B HR 5.20 p=0.075
| | | | IMRT 3DCRT | | DFS | ~90 ~63 | 79 56 | ~68 56 | ~68 ~50 | | 0.18 | RT tech NS in MVA
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | 1º RT + CCTx | IMRT 2DRT | 100 98.6 | LC | ~100 ~90 | 95 ~90 | 95 85 | 95 85 | 95 85 | 0.17
| | | | IMRT 2DRT | | LRC | ~100 ~90 | ~95 ~92 | 92 82 | 92 82 | 92 ~75 | 0.18
| | | | IMRT 2DRT | | DFS | ~92 ~86 | ~86 ~86 | 82 76 | 82 76 | 82 ~70 | 0.57
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | 195 | 1º RT ± CCTx | IMRT 3DCRT 3DCRTpre | 86 100 78 | LRC | 96.1 ~87 ~84 | 96.1 78.1 82.3 | 96.1 78.1 81.1 | 96.1 78.1 78.5 | 78.5 | | pre=preIMRT era
Rades, 2007 | 2710 | 44 | postop RT ± CCTx | IMRT 3DCRT | ≥ 50 ≥ 65 | LC | | 89 79 | | | | 0.34 | RT tech NS in MVA
Nutting, 2009 | 4122 0 | 84 | 1º RT/post op ± preRT CTx | IMRT 3DCRT | 77 (all) | LRC | 87.3 88.0 | | | | | NS | IMRT:3DCRT HR=1.59 (0.67, 3.80)
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | postop RT ± CCTx | 3DCRT 2DRT | ≥65 ≥54 | LC | | 79 78 | | | | 0.34 | RT tech NS in MVA
IMRT vs 2DRT
Rades, 2007 | 2710 | 122 | postop RT ± CCTx | IMRT 2DRT | ≥50 ≥54 | LC | | 89 78 | | | | 0.34 | RT tech NS in MVA
Chao, 2001 | 9940 | 430 | 1º/preo p/posto p RT ± CCTx | defIMRT def2DRT postopIMRT postop2DRT preop2DRT | 91.7 63.7 85.7 86.7 71.6 | LRC | | 88 68 100 76 78 | | | | NS NS
| | | | defIMRT def2DRT postopIMRT postop2DRT preop2DRT | | DFS | | 80 58 92 74 68 | | | | 0.002 0.008

Table D2m Oropharyngeal cancer, patient survival

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
1º RT + CCTx
IMRT vs 3DCRT
Rusthoven, 2008 | 13200 | 87 | 1º RT + CCTx | IMRT 3DCRT | 100 100 | OS | ~90 ~80 | 86 73 | ~72 ~70 | ~72 ~55 | | 0.48 | RT tech NS in MVA
IMRT vs 2DRT
Lee, 2006 | 2350 | 112 | 1º RT + CCTx | IMRT 2DRT | 100 98.6 | OS | ~100 ~88 | ~96 ~88 | 91 81 | 91 ~70 | 91 ~70 | 0.10
Mixed Settings
IMRT vs 3DCRT
Hodge, 2007 | 570 | 195 | 1º RT ± CCTx | IMRT 3DCRT 3DCRTpre | 86 100 78 | DSS | ~99 ~98 ~93 | 97.7 83.5 87.7 | 97.7 83.5 79.7 | 97.7 83.5 ~76 | 73.5 | NR
| | | | IMRT 3DCRT 3DCRTpre | | OS | ~98 ~95 ~90 | 94.5 81.1 87.7 | 88.2 81.1 79.7 | 88.2 81.1 ~56 | 54.6 | 0.02 | pre=preIMRT era RT tech NS in MVA (w/T stage)
Rades, 2007 | 2710 | 44 | postop RT ± CCTx | IMRT 3DCRT | ≥50 ≥65 | OS | | 86 80 | | | | 0.30 | RT tech NS in MVA
Nutting, 2009 | 41220 | 84 | 1º RT/postop ± preRT CTx | IMRT 3DCRT | 77 (all) | OS | 93.6 90.8 | | | | | NS | IMRT:3DCRT HR=1.05 (0.38, 2.90)
3DCRT vs 2DRT
Rades, 2007 | 2710 | 130 | postop RT ± CCTx | 3DCRT 2DRT | ≥65 ≥54 | OS | | 80 74 | | | | 0.30 | RT tech NS in MVA
IMRT vs 2DRT
Rades, 2007 | 2710 | 122 | postop RT ± CCTx | IMRT 2DRT | ≥50 ≥54 | OS | | 86 74 | | | | 0.30 | RT tech NS in MVA
Chao, 2001 | 9940 | 430 | 1º/preop/postop RT ± CCTx | defIMRT def2DRT postopIM RT postop2D RT preop2DR T | 91.7 63.7 85.7 86.7 71.6 | OS | | 100 57 100 71 67 | | | | 0.001 0.003

Table D3a Nasal cavity and paranasal sinus cancer, outcomes by study

Study | Rec# | No. Pts | Setting | QOL/Adverse Events | | | | | | | Tumor Control | | | Patient Survival
Study | Rec# | No. Pts | Setting | QOL | XST | SF | DYS | MUC | SKN | ORN or BON | LC | LRC | DFS | DSS | OS
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | 1°/preop/postop RT± postRT CTx/CCTx | | | | | X | X | X | X | | X | | X
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | 1°/preop/postop RT | | X | | | X | | X | X | | X | X | X
Chen, 2007 | 1560 | 104 | 1°/preop/postop RT± postRT CTx/CCTx | | | | | X | X | X | X | | X | | X
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | 1°/preop/postop RT± postRT CTx/CCTx | | | | | X | X | X | X | | X | | X
Comparisons | 4 | | | 0 | 1 | 0 | 0 | 4 | 3 | 4 | 4 | 0 | 4 | 1 | 4
Studies | 2 | | | 0 | 1 | 0 | 0 | 2 | 1 | 2 | 2 | 0 | 2 | 1 | 2
Total n | 254

Table D3b Nasal cavity and paranasal sinus cancer, participants and treatments

Study | Rec# | No. Pts | Setting | Tx Group | % Female | Median Age (rng, yrs) | % Stage III/IV | Prescribed RT Dose to Primary Tumor (Gy) | Median Follow-up (rng, mos) | Completed RT (%)
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 3DCRT | 40 (all) | 61 (27–92) (all) | ≥87.4 (all) | 66–72 50–73 | 49 (3–151) | NR
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | 1°/preop/postop RT | 3DCRT 2DR | 16 (all) | 58 (27–85) (all) | ≥93.7 (all) | 50–80 (all) | 67 (3–307) | 100 (all)
Chen, 2007 | 1560 | 104 | 1°/preop/postop RT± postRT CTx/CCTx | 3DCRT 2DR | 40 (all) | 61 (27–92) (all) | ≥87.4 (all) | 50–73 50–74 | 49 (3–151) | NR
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 2DR | 40 (all) | 61 (27–92) (all) | ≥87.4 (all) | 66–72 50–74 | 49 (3–151) | NR

Table D3c Nasal cavity and paranasal sinus cancer, comparative study quality items

Study | Rec# | No. Pts | Select Pro/Retro | Incl/Excl Clear | Rep Select | Initl Grps Comp | Bal by Design (Mtch) | BL Chars Clr Comp | Txs Same Time Per | Unbiased Alloc | Other Txs Equal | Maint Comp Grps | Overall Attr <20% | Non-diffl Attr <15% | Outcomes Val, Rel, = | Assessors Blind | Txs Clr | Adequate F/U | Analysis: Adj for Confs | USPSTF
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | R | Y | Y | ? | N | ? | N | E | ? | NA | NA | NA | Y | N | Y | md 49 | N | Poor
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | R | Y | Y | ? | N | ? | N | E | ? | NA | NA | NA | Y | N | Y | md 67 | Y/N | Poor
Chen, 2007 | 1560 | 104 | R | Y | Y | ? | N | ? | N | E | ? | NA | NA | NA | Y | N | Y | md 49 | N | Poor
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | R | Y | Y | ? | N | ? | N | E | ? | NA | NA | NA | Y | N | Y | md 49 | N | Poor

Table D3d Nasal cavity and paranasal sinus cancer, multivariate adjustment for confounders quality items

Study | Rec# | Pro design | Prespec hypoths | Lrg, well-defd, rep study pop | Pred factor meths well-descrd | Blinded assess pred factor | Homog txs, rand/unbiased alloc | Low rate of missing data (<15%) | Sufficiently long F/U | Clear cand var select | Clear appr model bldg GLs | Asmpt tested | Stand progn vars incld | Cont vars well hndld | Validation
Mixed Settings
3DCRT vs 2DRT
Dirix, 2007 | 1360 | N | N | Y | Y | NA | N | ? | md 67 | Y | N | ? | N | ? | N

Table D3e Nasal cavity and paranasal sinus cancer, quality of life

No studies.

Table D3f Nasal cavity and paranasal sinus cancer, xerostomia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | 1°/preop/postop RT | 3DCRT 2DRT | ≥93.7 (all) | ? | Permanent | | | 10.0 29.9 | 0.08

Table D3g Nasal cavity and paranasal sinus cancer, salivary flow

No studies.

Table D3h Nasal cavity and paranasal sinus cancer, dysphagia

No studies.

Table D3i Nasal cavity and paranasal sinus cancer, mucositis

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 3DCRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 13 16 | NR
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | 1°/preop/postop RT | 3DCRT 2DRT | ≥93.7 (all) | ? | ? | | | | NS
Chen, 2007 | 1560 | 104 | 1°/preop/postop RT± postRT CTx/CCTx | 3DCRT 2DRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 16 17 | NR
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 2DRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 13 17 | NR

Table D3j Nasal cavity and paranasal sinus cancer, skin

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 3DCRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 13 18 | NR
3DCRT vs 2DRT
Chen, 2007 | 1560 | 104 | 1°/preop/postop RT± postRT CTx/CCTx | 3DCRT 2DRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 18 27 | NR
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 2DRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 13 27 | NR

Table D3k Nasal cavity and paranasal sinus cancer, osteoradionecrosis/bone

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 3DCRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 9 16 | NR
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | 1°/preop/postop RT | 3DCRT 2DRT | ≥93.7 (all) | ? | ? | | | 0 0 | | ≥2 yr
Chen, 2007 | 1560 | 104 | 1°/preop/postop RT± postRT CTx/CCTx | 3DCRT 2DRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 16 15 | NR
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 2DRT | ≥87.4 (all) | RTOG/EORTC | ≥3 | | | 9 15 | NR

Table D3l Nasal cavity and paranasal sinus cancer, tumor control

Local Control
Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | 1°/preop/postop RT ± postRT CTx/CCTx | IMRT 3DCRT | ≥87.4 (all) | LC | ~85 ~79 | ~77 ~72 | ~71 ~66 | ~65 ~66 | 65 62 | >0.05
| | | | | | DFS | | | | | | 0.89
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | 1°/preop/postop RT | 3DCRT 2DRT | ≥93.7 (all) | LC | | | | | | NS
Chen, 2007 | 1560 | 104 | 1°/preop/postop RT± postRT CTx/CCTx | 3DCRT 2DRT | ≥87.4 (all) | LC | ~79 ~83 | ~72 ~62 | ~66 59 | ~66 59 | 62 59 | >0.05
| | | | | | DFS | | | | | | 0.89
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 2DRT | ≥87.4 (all) | LC | ~85 ~83 | ~77 ~62 | ~71 59 | ~65 59 | 65 59 | >0.05
| | | | | | DFS | | | | | | 0.89

Table D3m Nasal cavity and paranasal sinus cancer, patient survival

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Chen, 2007 | 1560 | 68 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 3DCRT | ≥87.4 (all) | OS | | | | | 47 57 | 0.60
3DCRT vs 2DRT
Dirix, 2007 | 1360 | 127 | 1°/preop/postop RT | 3DCRT 2DRT | ≥93.7 (all) | OS | | | | | | NS
| | | | | | DSS | | | | | | NS
Chen, 2007 | 1560 | 104 | 1°/preop/postop RT±postRT CTx/CCTx | 3DCRT 2DRT | ≥87.4 (all) | OS | | | | | 57 51 | 0.60
IMRT vs 2DRT
Chen, 2007 | 1560 | 82 | 1°/preop/postop RT± postRT CTx/CCTx | IMRT 2DRT | ≥87.4 (all) | OS | | | | | 47 51 | 0.60

Table D4a Unknown primary cancer, outcomes by study

Study | Rec# | No. Pts | Setting | QOL/Adverse Events | | | | | | | Tumor Control | | | Patient Survival
Study | Rec# | No. Pts | Setting | QOL | XST | SF | DYS | MUC | SKN | ORN or BON | LC | LRC | DFS | DSS | OS
Mixed Settings
3DCRT vs 2DRT
Beldi, 2007 | 990 | 87 | 1°/postop RT± preRT CTx/CCTx | | | | | | | | | | X | | X
IMRT vs 2DRT
Madani, 2008 | 37700 | 41 | 1°/postop RT ± CTx (timing?) | | | | X | X | X | | | | | | X
Comparisons | 2 | | | 0 | 0 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 0 | 2
Studies | 2 | | | 0 | 0 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 0 | 2
Total n | 128

Table D4b Unknown primary cancer, participants and treatments

Study | Rec# | No. Pts | Setting | Tx Group | % Female | Median Age (rng, yrs) | % Stage III/IV | Prescribed RT Dose to Primary Tumor (Gy) | Median Follow-up (rng, mos) | Completed RT (%)
Mixed Settings
3DCRT vs 2DRT
Beldi, 2007 | 990 | 87 | 1°/postop RT± preRT CTx/CCTx | 3DCRT 2DR | 18 (all) | 59 (23–88) (all) | 100 (all) | 45–70 (all) | 32 | NR
IMRT vs 2DRT
Madani, 2008 | 37700 | 41 | 1°/postop RT ± CTx (timing?) | IMRT 2DR | 26 22 | 61 (47–85) 58 (38–75) | 100 (all) | 56–69 66 | 17 (2–39) | 87 100

Table D4c Unknown primary cancer, comparative study quality items

Study | Rec# | No. Pts | Select Pro/ Retro | Incl/ Excl Clear | Rep Select | Initl Grps Comp | Bal by Design (Mtch) | BL Chars Clr Comp | Txs Same Time Per | Unbiased Alloc | Other Txs Equal | Maint Comp Grps | Overall Attr <20% | Non-diffl Attr <15% | Out-comes Val, Rel, = | Assessors Blind | Txs Clr | Adequate F/U | Analysis: Adj for Confs | USPSTF
Mixed Settings
3DCRT vs 2DRT
Beldi, 2007 2007 | 990 | 87 | R | Y | Y | ? | N | ? | N | E | ? | NA | NA | NA | Y | N | Y | md 32 | Y/N | Poor
IMRT vs 2DRT
Madani, 2008 | 37700 | 41 | R | N | ? | N | N | Y | N | E | ? | NA | NA | NA | Y | N | Y | md 17 | N | Poor

Table D4d Unknown primary cancer, multivariate adjustment for confounders quality items

Study | Rec# | Pro design | Prespec hypoths | Lrg, well-defd, rep study pop | Pred factor meths well-descrd | Blinded assess pred factor | Homog txs, rand/unbiased alloc | Low rate of missing data (<15%) | Sufficiently long F/U | Clear cand var select | Clear appr model bldg GLs | Asmpt tested | Stand progn vars incld | Cont vars well hndld | Validation
Mixed Settings
3DCRT vs 2DRT
Beldi, 2007 2007 | 990 | N | N | Y | Y | NA | N | Y | md 32 | Y | N | ? | N | ? | N

Table D4e Unknown primary cancer, quality of life

No studies.

Table D4f Unknown primary cancer, xerostomia

No studies.

Table D4g Unknown primary cancer, salivary flow

No studies.

Table D4h Unknown primary cancer, dysphagia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 2DRT
Madani, 2008 | 37700 | 41 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | Acute-RTOG Late-LENT/SOMA | ≤ 2 3 | 95.5 50 4.5 50 | 0.003 | 100 72.3 0 26.7 | 0.01

Table D4i Unknown primary cancer, mucositis

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 2DRT
Madani, 2008 | 37700 | 41 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | RTOG | ≤ 2 3 | 50 41.2 50 58.8 | 0.82

Table D4j Unknown primary cancer, skin

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 2DRT
Madani, 2008 | 37700 | 41 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | Acute-RTOG Late-LENT/SOMA | ≤ 2 3 | 68.2 33.3 31.7 66.7 | 0.08 | 100 73.3 0 26.7 | 0.03

Table D4k Unknown primary cancer, osteoradionecrosis/bone

No studies.

Table D4l Unknown primary cancer, tumor control

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
Mixed Settings
3DCRT vs 2DRT
Beldi, 2007 2007 | 990 | 87 | 1°/postop RT± preRT CTx/CCTx | 3DCRT 2DRT | 100 100 | DFS | | | | | 48.3 15.2 | <0.01 | RT tech NS in MVA

Table D4m Unknown primary cancer, patient survival

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
Mixed Settings
3DCRT vs 2DRT
Beldi, 2007 2007 | 990 | 87 | 1°/postop RT± preRT CTx/CCTx | 3DCRT 2DRT SCC only | 100 100 | OS | | | | | 69.1 26.3 69.1 30.8 | <0.01 <0.05 | RT tech NS in MVA
IMRT vs 2DRT
Madani, 2008 | 37700 | 41 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | OS | 74.8 61.1 | | | | | 0.97

Table D5a Laryngeal cancer, outcomes by study

| | | | QOL/Adverse Events | | | | | | | Tumor Control | | | Patient Survival
Study | Rec# | No. Pts | Setting | QOL | XST | SF | DYS | MUC | SKN | ORN or BON | LC | LRC | DFS | DSS | OS
1° RT
3DCRT vs 2DRT
Zouhair, 2004 | 7400 | 122 | 1° RT | | | | | | | | X
Comparisons | 1 | | | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Studies | 1 | | | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Total n | 122

Table D5b Laryngeal cancer, participants and treatments

Study | Rec# | No. Pts | Setting | Tx Group | % Female | Median Age (rng, yrs) | % Stage III/IV | Prescribed RT Dose to Primary Tumor (Gy) | Median Follow-up (rng, mos) | Completed RT (%)
1° RT
3DCRT vs 2DRT
Zouhair, 2004 | 7400 | 122 | 1° RT | 3DCRT 2DR | 13 (all) | 62 (35–92) (all) | 0 (all) | 60–74 (all) | 85 (12–178) | NR

Table D5c Laryngeal cancer, comparative study quality items

Study | Rec# | No. Pts | Select Pro/ Retro | Incl/ Excl Clear | Rep Select | Initl Grps Comp | Bal by Design (Mtch) | BL Chars Clr Comp | Txs Same Time Per | Unbiased Alloc | Other Txs Equal | Maint Comp Grps | Overall Attr <20% | Non-diffl Attr <15% | Out-comes Val, Rel, = | Assessors Blind | Txs Clr | Adequate F/U | Analysis: Adj for Confs | USPSTF
1° RT
3DCRT vs 2DRT
Zouhair, 2004 | 7400 | 122 | R | Y | Y | N | N | ? | N | E | Y | NA | NA | NA | Y | N | Y | md 85 | Y/? | Poor

Table D5d Laryngeal cancer, multivariate adjustment for confounders quality items

Study | Rec# | Pro design | Prespec hypoths | Lrg, well-defd, rep study pop | Pred factor meths well-descrd | Blinded assess pred factor | Homog txs, rand/unbiased alloc | Low rate of missing data (<15%) | Sufficiently long F/U | Clear cand var select | Clear appr model bldg GLs | Asmpt tested | Stand progn vars incld | Cont vars well hndld | Validation
1° RT
3DCRT vs 2DRT
Zouhair, 2004 | 7400 | N | N | Y | Y | NA | Y | NA | md 85 | N | ? | ? | ? | ? | N

Table D5e Laryngeal cancer, quality of life

No studies.

Table D5f Laryngeal cancer, xerostomia

No studies.

Table D5g Laryngeal cancer, salivary flow

No studies.

Table D5h Laryngeal cancer, dysphagia

No studies.

Table D5i Laryngeal cancer, mucositis

No studies.

Table D5j Laryngeal cancer, skin

No studies.

Table D5k Laryngeal cancer, osteoradionecrosis/bone

No studies.

Table D5l Laryngeal cancer, tumor control

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
1° RT
3DCRT vs 2DRT
Zouhair, 2004 | 7400 | 122 | 1 setting: 1° RT | 3DCRT 2DRT | 0 (all) | LC | | | | | 86 81 | 0.55 | RT tech NS in MVA

Table D5m Laryngeal cancer, patient survival

No studies.

Table D6a Mixed head and neck cancer, outcomes by study

Study | Rec# | No. Pts | Setting | QOL/Adverse Events | | | | | | | Tumor Control | | | Patient Survival
Study | Rec# | No. Pts | Setting | QOL | XST | SF | DYS | MUC | SKN | ORN or BON | LC | LRC | DFS | DSS | OS
1° RT
IMRT vs 3DCRT
Golen, 2007 | 14200 | 40 | 1° RT | | X
Mixed Settings
IMRT vs 3DCRT
Marchal, 2004 | 5580 | 87 | 1°/postop/repeat RT ± pre/post RT CTx/CCTx | | X | | | | | | | | X | | X
Chao, 2001 | 10470 | 41 | 1°/postop RT ± postRT CTx/CCTx | | | X
Gomez, 2008 | 13390 | 32 | 1°/postop RT± CTx (timing?) | | | | | | | | | | X | | X
Palazzi, 2008 | 13850 | 116 | 1°/postop RT ± CCTx/CCTx + preRT CTx | | X | | X | X | X
Langendijk, 2009 | 39950 | 529 | 1°/postop RT± CTx (timing?) | | | | X
Vergeer, 2008 | 38540 | 141 | 1°/postop RT ± CCTx | X | X | | | X | X
3DCRT vs 2DRT
Kuhnt, 2005 | 4840 | 33 | 1°/postop RT | | | X
Rades, 2008 | 13180 | 345 | 1°/postop RT± CCTx | | X | | | X | X | | | X | | | X
Gomez, 2008 | 13390 | 42 | 1°/postop RT± CTx (timing?) | | | | | | | | | | X | | X
Palazzi, 2008 | 13850 | 137 | 1°/postop RT ± CCTx/CCTx + preRT CTx | | X | | X | X | X
IMRT vs 2DRT
Sanguineti, 2007 | 1740 | 66 | 1° RT ± CTx (timing?)
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | | X
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | X | X
Pacholke, 2005 | 4830 | 210 | 1°/postop RT ± CTx (timing?) | | X
Kent, 2008 | 13300 | 40 | 1°/postop RT ± CTx (timing?)
Gomez, 2008 | 13390 | 44 | 1°/postop RT± CTx (timing?) | | | | | | | | | | X | | X
Palazzi, 2008 | 13850 | 45 | 1°/postop RT ± CCTx/CCTx + preRT CTx | | X | | X | X | X
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | | X
Caudell, 2009 | 39420 | 122 | 1° RT ± preRT CTX and/or CCTx | | | | X
Murphy, 2009 | 40430 | 75 | 1°/postop RT± CTx (timing?) | | | | | X
Comparisons | 21 | | | 2 | 11 | 2 | 5 | 6 | 5 | 0 | 0 | 1 | 4 | 0 | 5
Studies | 17 | | | 2 | 9 | 2 | 3 | 4 | 3 | 0 | 0 | 1 | 2 | 0 | 3
Total n | 2274

Table D6b Mixed head and neck cancer, participants and treatments

Study | Rec# | No. Pts | Setting | Tx Group | % Female | Median Age (rng, yrs) | % Stage III/IV | Prescribed RT Dose to Primary Tumor (Gy) | Median Follow-up (rng, mos) | Completed RT (%)
1° RT
IMRT vs 3DCRT
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 28 (all) | NR | 40 (all) | 62–72 (all) | NR | NR
Mixed Settings
IMRT vs 3DCRT
Marchal, 2004 | 5580 | 87 | 1°/postop/repeat RT ± pre/post RT CTx/CCTx | IMRT 3DCRT | | | ≥19.5 ≥21.7
Chao, 2001 | 10470 | 41 | 1°/postop RT ± postRT CTx/CCTx | IMRT 3DCRT | 29 (all) | 58 (36–75) (all) | 82.9 (all) | 50–70 (all) | NR | 100 (all)
Gomez, 2008 | 13390 | 32 | 1°/postop RT± CTx (timing?) | IMRT 3DCRT | 59 (all) | 52 (15–85) (all) | ≥47.4 (all) | 52–70 (all) | 71 (6–180) | 100 (all)
Palazzi, 2008 | 13850 | 116 | 1°/postop RT ± CCTx/CCTx + preRT CTx | IMRT 3DCRT | 22 (all) | 57 (27–94) (all) | 87 (all) | 60–70 (all) | NR | NR
Vergeer, 2008 | 38540 | 141 | 1°/postop RT ± CCTx | IMRT 3DCRT | 44 31 | NR | 77 62 | 54–70 46–70 | NR | NR
Langendijk, 2009 | 39950 | 529 | 1°/postop RT± CTx (timing?) | IMRT 3DCRT | 25 (all) | 60 (all) | | 70 (all) | ≥6 mo | NR
3DCRT vs 2DRT
Kuhnt, 2005 | 4840 | 33 | 1°/postop RT | 3DCRT 2DR | 23 20 | 56 (44–68) 60 (41–74) | NR | ? | ? | ?
Rades, 2008 | 13180 | 345 | 1°/postop RT± CCTx | 3DCRT 2DR | 25 29 | NR | 100 (All) | 60–72 60–70 | NR | NR
Gomez, 2008 | 13390 | 42 | 1°/postop RT± CTx (timing?) | 3DCRT 2DR | 59 (all) | 52 (15–85) (all) | ≥47.4 (all) | 52–70 (all) | 71 (6–180) | 100 (all)
Palazzi, 2008 | 13850 | 137 | 1°/postop RT ± CCTx/CCTx + preRT CTx | 3DCRT 2DR | 22 (all) | 57 (27–94) (all) | 87 (all) | 60–70 (all) | NR | NR
IMRT vs 2DRT
Sanguineti, 2007 | 1740 | 66 | 1° RT ± CTx (timing?) | IMRT 2DR | 18 (all) | 54 (35–85) (all) | ≥75.8 (all) | 60–78 60–72 | 17 (0.4–50) | NR
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DR | 10 13 | 58 (39–73) 58 (35–80) | 96.6 96 | 66 NR | 25 (10–60) | NR
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DR | 23 30 | 53 (29–85) 53 (28–81) | 100 (all) | 60–78 63–77 | NR | NR
Pacholke, 2005 | 4830 | 210 | 1°/postop RT ± CTx (timing?) | IMRT 2DR | NR | NR | NR | > 50 (all) | NR | NR
Kent, 2008 | 13300 | 40 | 1°/postop RT ± CTx (timing?) | IMRT 2DR | NR | NR | NR | NR | NR | 100 (all)
Gomez, 2008 | 13390 | 44 | 1°/postop RT ± CTx (timing?) | IMRT 2DR | 59 (all) | 52 (15–85) (all) | ≥47.4 (all) | 52–70 (all) | 71 (6–180) | 100 (all)
Palazzi, 2008 | 13850 | 45 | 1°/postop RT ± CCTx/CCTx + preRT CTx | IMRT 2DR | 22 (all) | 57 (27–94) (all) | 87 (all) | 60–70 (all) | NR | NR
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DR | 28 36 | 59 (all) | 100 (all) | ≥ 60 (all) | NR | NR
Caudell, 2009 | 39420 | 122 | 1° RT ± preRT CTX and/or CCTx | IMRT 2DR | 24 (all) | 55 (18–83) (all) | 100 (all) | 65–79 (all) | 32 (12–73) | NR
Murphy, 2009 | 40430 | 75 | 1°/postop RT± CTx (timing?) | IMRT 2DR | 19 (all) | mn 59 (40–86) (all) | 84 (all) | NR | 1.4

Table D6c Mixed head and neck cancer, comparative study quality items

Study | Rec# | No. Pts | Select Pro/Retro | Incl/Excl Clear | Rep Select | Initl Grps Comp | Bal by Design (Mtch) | BL Chars Clr Comp | Txs Same Time Per | Unbiased Alloc | Other Txs Equal | Maint Comp Grps | Overall Attr <20% | Non-diffl Attr <15% | Outcomes Val, Rel, = | Assessors Blind | Txs Clr | Adequate F/U | Analysis: Adj for Confs | USPSTF
1° RT
IMRT vs 3DCRT
Golen, 2007 | 14200 | 40 | R | N | ? | ? | N | ? | Y | R | Y | NA | NA | NA | Y | N | Y | ? | N | Poor
Mixed Settings
IMRT vs 3DCRT
Marchal, 2004 | 5580 | 87 | P | N | ? | ? | N | ? | Y | ? | ? | ? | ? | ? | Y | ? | N | ? | N | Poor
Chao, 2001 | 10470 | 41 | P | N | ? | ? | N | ? | Y | ? | ? | Y | Y | Y | Y | ? | Y | ? | Y/? | Poor
Gomez, 2008 | 13390 | 32 | R | Y | Y | ? | N | ? | N | ? | ? | NA | NA | NA | Y | N | Y | md 71 | Y/? | Poor
Palazzi, 2008 | 13850 | 116 | P | Y | ? | ? | N | ? | N | E | ? | ? | ? | ? | Y | ? | Y | ? | Y/? | Poor
Vergeer, 2008 | 38540 | 141 | P | Y | Y | N | N | N | N | E | N | NA | ? | ? | Y | ? | Y | ? | Y/? | Poor
Langendijk, 2009 | 39950 | 529 | P | Y | N | ? | N | ? | ? | ? | ? | ? | ? | ? | Y | ? | Y | 6 | Y/N | Poor
3DCRT vs 2DRT
Kuhnt, 2005 | 4840 | 33 | P | Y | Y | ? | N | ? | Y | ? | ? | ? | Y | Y | Y | ? | Y | ? | N | Poor
Rades, 2008 | 13180 | 345 | R | Y | Y | Y | N | Y | Y | ? | Y | NA | NA | NA | Y | N | Y | ? | Y/N | Poor
Gomez, 2008 | 13390 | 42 | R | Y | Y | ? | N | ? | N | ? | ? | NA | NA | NA | Y | N | Y | md 71 | Y/? | Poor
Palazzi, 2008 | 13850 | 137 | P | Y | ? | ? | N | ? | N | E | ? | ? | ? | ? | Y | ? | Y | ? | Y/? | Poor
IMRT vs 2DRT
Sanguineti, 2007 | 1740 | 66 | R | Y | N | ? | N | ? | ? | ? | ? | NA | NA | NA | Y | N | Y | md 17 | Y/N | Poor
Daly, 2007 | 2470 | 69 | R | N | ? | Y | N | Y | ? | ? | Y | NA | NA | NA | Y | N | Y | md 25 | N | Poor
Jabbari, 2005 | 4480 | 106 | P | N | ? | ? | Y | Y | Y | Risk | Y | N | N | ? | Y | ? | N | ? | N | Poor
Pacholke, 2005 | 4830 | 210 | R | Y | Y | ? | N | ? | ? | ? | ? | NA | NA | NA | Y | N | N | ? | Y/? | Poor
Kent, 2008 | 13300 | 40 | R | Y | N | ? | N | ? | ? | ? | ? | NA | NA | NA | Y | N | N | ? | N | Poor
Gomez, 2008 | 13390 | 44 | R | Y | Y | ? | N | ? | N | ? | ? | NA | NA | NA | Y | N | Y | md 71 | Y/? | Poor
Palazzi, 2008 | 13850 | 45 | P | Y | ? | ? | N | ? | N | E | ? | ? | ? | ? | Y | ? | Y | ? | Y/? | Poor
van Rij, 2008 | 38520 | 162 | R | Y | Y | ? | N | N | N | ? | N | NA | NA | NA | Y | N | N | md 31 | Y/? | Poor
Caudell, 2009 | 39420 | 122 | R | Y | Y | ? | N | ? | ? | ? | ? | NA | NA | NA | Y | N | Y | md 32 | Y/N | Poor
Murphy, 2009 | 40430 | 75 | P | Y | Y | ? | N | ? | Y | ? | ? | ? | ? | ? | Y | ? | N | 1.4 | N | Poor

Table D6d Mixed head and neck cancer, multivariate adjustment for confounders quality items

Study | Rec# | Pro design | Prespec hypoths | Lrg, well-defd, rep study pop | Pred factor meths well-descrd | Blinded assess pred factor | Homog txs, rand/unbiased alloc | Low rate of missing data (<15%) | Sufficiently long F/U | Clear cand var select | Clear appr model bldg GLs | Asmpt tested | Stand progn vars incld | Cont vars well hndld | Validation
Mixed Settings
IMRT vs 3DCRT
Gomez, 2008 | 13390 | N | N | Y | Y | NA | N | NA | md 71 | Y | ? | ? | ? | ? | N
Palazzi, 2008 | 13850 | Y | N | Y | Y | NA | N | N | ? | N | ? | ? | ? | ? | N
Vergeer, 2008 | 38540 | Y | N | Y | Y | NA | N | ? | ? | N | ? | ? | ? | ? | N
3DCRT vs 2DRT
Rades, 2008 | 13180 | N | N | Y | Y | NA | N | NA | ? | N | N | ? | N | ? | N
Gomez, 2008 | 13390 | N | N | N | Y | NA | N | NA | md 71 | Y | ? | ? | ? | ? | N
Palazzi, 2008 | 13850 | Y | N | Y | Y | NA | N | N | ? | N | ? | ? | ? | ? | N
IMRT vs 2DRT
Sanguineti, 2007 | 1740 | N | N | N | Y | NA | N | NA | md 17 | N | N | ? | N | ? | N
Pacholke, 2005 | 4830 | N | N | N | Y | NA | ? | NA | ? | N | ? | ? | ? | ? | N
Gomez, 2008 | 13390 | N | N | N | Y | NA | N | NA | md 71 | Y | ? | ? | ? | ? | N
Palazzi, 2008 | 13850 | Y | N | Y | Y | NA | N | N | ? | N | ? | ? | ? | ? | N
van Rij, 2008 | 38520 | N | N | Y | Y | NA | N | NA | ? | N | ? | ? | ? | ? | N
Caudell, 2009 | 39420 | N | N | Y | Y | NA | N | NA | md 32 | N | N | ? | N | ? | N

Table D6e Mixed head and neck cancer, quality of life: head and neck cancer-related quality of life (HNQOL)

EORTC QLQ-C30
| Vergeer, 2008, Rec # 38540
Item | Mean IMRT n=91 | Mean 3DCRT n=150 | Mo F/U | p Value Linear-l Quadratic-q
Global health | 76.0 79.2 | 64.9 65.6 | 1.5 6 all | <0.004-l
Physical function | 77.4 80.7 | 73.3 74.4 | 1.5 6 all
Role function | 81.5 82.1 | 65.6 70.8 | 1.5 6 all | 0.042-l
Emotional function | 78.2 85.3 | 73.5 73.2 | 1.5 6 all
Cognitive function | 87.8 93.6 | 83.9 84.6 | 1.5 6 all | 0.033-l
Social function | 82.7 92.0 | 76.1 76.5 | 1.5 6 all | <0.001-l
Fatigue | 30.9 24.2 | 40.5 40.4 | 1.5 6 all | 0.026-l
Nausea/vomiting | 12.8 6.4 | 13.6 8.4 | 1.5 6 all
Pain | 14.1 19.2 | 25.2 23.3 | 1.5 6 all | 0.042-q
Dyspnea | 11.9 10.7 | 19.1 22.4 | 1.5 6 all
Insomnia | 27.4 16.7 | 26.3 30.1 | 1.5 6 all | 0.021-l
Appetite loss | 19.8 12.3 | 32.5 24.2 | 1.5 6 all | 0.018-l
Constipation | 10.7 10.7 | 17.1 12.1 | 1.5 6 all
Diarrhea | 11.5 2.6 | 7.8 8.5 | 1.5 6 all
Financial difficulties | 16.7 15.4 | 12.6 14.8 | 1.5 6 all
EORTC QLQ-H&N35
Pain | 19.9 18.9 | 33.0 28.3 | 1.5 6 all | 0.030-l 0.046-q
Swallowing | 35.5 21.1 | 36.1 33.7 | 1.5 6 all | 0.042-l
Taste/smell | 32.7 16.7 | 34.0 26.8 | 1.5 6 all
Speech | 23.0 19.8 | 31.2 29.9 | 1.5 6 all
Social eating | 23.0 15.9 | 35.7 30.9 | 1.5 6 all | 0.011-l
Sexuality | 30.7 13.3 | 45.5 38.1 | 1.5 6 all | 0.003-l
Teeth | 4.3 7.2 | 19.6 24.3 | 1.5 6 all | 0.015-l
Opening mouth | 8.6 17.3 | 27.1 30.2 | 1.5 6 all | 0.026-q
Dry mouth | 43.2 48.1 | 62.2 68.6 | 1.5 6 all | <0.001-l
Sticky saliva | 41.3 32.0 | 61.3 56.9 | 1.5 6 all | 0.001-l
Coughing | 35.8 27.2 | 33.3 35.4 | 1.5 6 all
Feeling ill | 21.0 6.2 | 1.1 19.1 | 1.5 6 all | 0.011-l

| Jabbari, 2005, Rec # 4480
Domain | Median IMRT n=30 | IMRT Trend for Improvement p Value | Median2DRT n=10 | 2DRT Trend for Improvement p Value | F/U | Difference Adjusted for Baseline | p Value
Total | ~31 ~31 ~20 17 ~13 ~7 | 0.04 | ~31 ~32 ~58 68 ~4 ~47 | 0.97 | 1 3 6 12 18 24 all | 19.2 | NS
Communication | | 0.11 | | 0.56 | all
Eating | | 0.07 | | 0.78 | all
Emotion | | 0.04 | | 0.11 | all
Pain | | 0.05 | | 0.38 | all

Table D6f Mixed head and neck cancer, xerostomia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Marchal, 2004 | 5580 | 87 | 1°/postop/repeat RT ± pre/post RT CTx/CCTx | IMRT 3DCRT | ≥21.7 ≥19.5 | RTOG | ≥ 2 | 23 24 | | 42
Marchal, 2004 | 5580 | 87 | 1°/postop/repeat RT ± pre/post RT CTx/CCTx | IMRT 3DCRT | ≥21.7 ≥19.5 | RTOG | ≥ 2 | 23 24 | | 50
Marchal, 2004 | 5580 | 87 | 1°/postop/repeat RT ± pre/post RT CTx/CCTx | IMRT 3DCRT | ≥21.7 ≥19.5 | RTOG | ≥ 3 | 23 24 | | 7 | 0.06
Marchal, 2004 | 5580 | 87 | 1°/postop/repeat RT ± pre/post RT CTx/CCTx | IMRT 3DCRT | ≥21.7 ≥19.5 | RTOG | ≥ 3 | 23 24 | | 18
Palazzi, 2008 | 13850 | 116 | 1°/postop RT ± CCTx/CCTx + preRT CTx | IMRT 3DCRT | 87 (all) | CTC | ≥ 2 | | | | | RT tech NS in MVA, acute
Vergeer, 2008 | 38540 | 141 | 1°/postop RT ± CCTx | IMRT 3DCRT | 77 62 | RTOG | 2 12 wk | ~25 ~42 | 0.014 | | <0.001 | p<0.02 at 3, 4, 5 wk; NS at 0, 1, 2, 6, 7, 8 wk; 6 mo MV ORa (95% CI): 0.27 (0.13, 0.54); IMRT<3DCRT at end RT, 6 wk, 6mo, 12 mo MV ORa (95% CI): 0.24 (0.12, 0.51)
Vergeer, 2008 | 38540 | 141 | 1°/postop RT ± CCTx | IMRT 3DCRT | 77 62 | ? | 6 mo mod- sev | ~25 ~42 | 0.014 | 41 67 | <0.01 | p<0.02 at 3, 4, 5 wk; NS at 0, 1, 2, 6, 7, 8 wk; 6 mo MV ORa (95% CI): 0.27 (0.13, 0.54); IMRT<3DCRT at end RT, 6 wk, 6mo, 12 mo MV ORa (95% CI): 0.24 (0.12, 0.51)
Vergeer, 2008 | 38540 | 141 | 1°/postop RT ± CCTx | IMRT 3DCRT | 77 62 | mn QLQ- H&N35 XST item RTOG | ≥ 2 6 mo | ~25 ~42 | 0.014 | 32 56 | 0.002 | p<0.02 at 3, 4, 5 wk; NS at 0, 1, 2, 6, 7, 8 wk; 6 mo MV ORa (95% CI): 0.27 (0.13, 0.54); IMRT<3DCRT at end RT, 6 wk, 6mo, 12 mo MV ORa (95% CI): 0.24 (0.12, 0.51)
3DCRT vs 2DRT
Rades, 2008 | 13180 | 345 | 1°/postop RT± CCTx | 3DCRT 2DRT | 100 100 | RTOG | 2–3 | | | 43 58 | 0.06
Palazzi, 2008 | 13850 | 137 | 1°/postop RT ± CCTx/CCTx + preRT CTx | 3DCRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
IMRT vs 2DRT
Palazzi, 2008 | 13850 | 45 | 1°/postop RT ± CCTx/CCTx + preRT CTx | IMRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Scale | Item | Mean | F/U | p value | Comments
1° RT
IMRT vs 3DCRT
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.75 | 3 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | 2.4 | 3 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.4 | 6 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.6 | 6 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.25 | 12 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.5 | 12 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.25 | 18 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.25 | 18 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.25 | 24 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.2 | 24 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.5 | 30 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | CTC | Mean grade by group | ~2.0 | 30 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~5.0 | 3 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~5.4 | 3 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~4.3 | 6 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~5.2 | 6 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~4.3 | 12 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~5.0 | 12 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~3.9 | 18 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~4.8 | 18 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~3.6 | 24 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~3.8 | 24 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~2.5 | 30 mo | NR
Golen, 2007 | 14200 | 40 | 1 setting: 1° RT | IMRT 3DCRT | 40 (all) | SOMA-LENT | Mean grade by group | ~4.1 | 30 mo | NR
Mixed Settings
IMRT vs 2DRT
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Talking difficult | 3.0 | > 6 mo | 0.003
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Talking difficult | 4.8 | > 6 mo | 0.003
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Chewing difficult | 3.9 | > 6 mo | 0.03
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Chewing difficult | 5.3 | > 6 mo | 0.03
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Swallow difficult | 5.2 | > 6 mo | 0.16
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Swallow difficult | 6.0 | > 6 mo | 0.16
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Sleeping problems | 3.0 | > 6 mo | 0.76
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Sleeping problems | 2.8 | > 6 mo | 0.76
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Dry w/eating | 4.7 | > 6 mo | 0.02
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Dry w/eating | 6.0 | > 6 mo | 0.02
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Dry w/o eating | 3.8 | > 6 mo | 0.03
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Dry w/o eating | 5.0 | > 6 mo | 0.03
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Freq sipping w/eat | 5.5 | > 6 mo | 0.002
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Freq sipping w/eat | 7.8 | > 6 mo | 0.002
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Freq sipping w/o eat | 3.8 | > 6 mo | 0.0006
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Freq sipping w/o eat | 5.9 | > 6 mo | 0.0006
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Total | 33.0 | > 6 mo | 0.006
Daly, 2007 | 2470 | 69 | 1°/postop RT ± CCTx/CTx (timing?) | IMRT 2DRT | 96.6 96.0 | XQ | Total | 43.7 | > 6 mo | 0.006
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~3 | Pre | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~7 | Pre | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~39 | 1 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~58 | 1 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~53 | 3 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~68 | 3 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~43 | 6 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~58 | 6 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | 32 | 12 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | 67 | 12 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~35 | 18 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~23 | 18 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~28 | 24 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Jabbari, 2005 | 4480 | 106 | 1°/postop RT ± CTx (timing?) | IMRT 2DRT | 100 100 | XQ | Total | ~88 | 24 mo | 0.7 | at 12 mo, adjusting for baseline, IMRT-2DRT difference NS (p=0.2)
Pacholke, 2005 | 4830 | 210 | 1°/postop RT ± CTx (timing?) | IMRT | | XQ | Total above or below median | 6 | > 1 yr | | RT tech p<0.001 on MVA
Pacholke, 2005 | 4830 | 210 | 1°/postop RT ± CTx (timing?) | IMRT>26Gy | | XQ | Total above or below median | 50 | > 1 yr | | RT tech p<0.001 on MVA
Pacholke, 2005 | 4830 | 210 | 1°/postop RT ± CTx (timing?) | IMRT≤26Gy | | XQ | Total above or below median | 34 | > 1 yr | | RT tech p<0.001 on MVA
Pacholke, 2005 | 4830 | 210 | 1°/postop RT ± CTx (timing?) | 2DRTbilat-tot | | XQ | Total above or below median | 64 | > 1 yr | | RT tech p<0.001 on MVA
Pacholke, 2005 | 4830 | 210 | 1°/postop RT ± CTx (timing?) | 2DRTbilat-par | | XQ | Total above or below median | 53 | > 1 yr | | RT tech p<0.001 on MVA
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Mean in rest | 7.6 | med 2.6 yrs | UVA | MVA p value
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Mean in rest | 10.3 | med 2.6 yrs | UVA | MVA p value
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | ↓/much ↓ saliva | 78 | med 2.6 yrs | 0.07 | 0.008
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | ↓/much ↓ saliva | 85 | med 2.6 yrs | 0.07 | 0.008
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | ↓/much ↓ Δ saliva | 22 | med 2.6 yrs | 1.0 | 0.7
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | ↓/much ↓ Δ saliva | 27 | med 2.6 yrs | 1.0 | 0.7
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A dry not eating | 36 | med 2.6 yrs | 0.004 | 0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A dry not eating | 61 | med 2.6 yrs | 0.004 | 0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs gumbs | 13 | med 2.6 yrs | 0.3 | 0.2
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs gumbs | 13 | med 2.6 yrs | 0.3 | 0.2
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs speaking | 29 | med 2.6 yrs | <0.0001 | <0.0001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs speaking | 57 | med 2.6 yrs | <0.0001 | <0.0001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A drink H_2_O day | 55 | med 2.6 yrs | 0.001 | 0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A drink H_2_O day | 79 | med 2.6 yrs | 0.001 | 0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A trouble sleeping | 20 | med 2.6 yrs | 0.5 | 0.2
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A trouble sleeping | 25 | med 2.6 yrs | 0.5 | 0.2
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A drink H_2_O night | 28 | med 2.6 yrs | 0.05 | 0.03
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A drink H_2_O night | 47 | med 2.6 yrs | 0.05 | 0.03
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Mean during meals | 7.2 | med 2.6 yrs
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Mean during meals | 11.5 | med 2.6 yrs
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs solid food | 29 | med 2.6 yrs | <0.001 | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs solid food | 62 | med 2.6 yrs | <0.001 | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs grnd food | 14 | med 2.6 yrs | <0.001 | 0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A probs grnd food | 34 | med 2.6 yrs | <0.001 | 0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A swallow solid | 30 | med 2.6 yrs | <0.001 | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A swallow solid | 61 | med 2.6 yrs | <0.001 | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A swallow grnd | 19 | med 2.6 yrs | 0.007 | 0.02
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A swallow grnd | 36 | med 2.6 yrs | 0.007 | 0.02
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A dry meals | 25 | med 2.6 yrs | <0.001 | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A dry meals | 55 | med 2.6 yrs | <0.001 | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A H_2_O to swallow | 38 | med 2.6 yrs | <0.001 | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A H_2_O to swallow | 71 | med 2.6 yrs | | <0.001
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A eat w/others | 19 | med 2.6 yrs | 0.006 | 0.02
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | F/A eat w/others | 34 | med 2.6 yrs | 0.006 | 0.02
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Grnd/liquid diet | 9 | med 2.6 yrs | 0.03 | 0.3
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Grnd/liquid diet | 22 | med 2.6 yrs | 0.03 | 0.3
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Swallow more freq | 34 | med 2.6 yrs | 0.2 | 0.2
van Rij, 2008 | 38520 | 162 | 1°/postop RT ± CCTx | IMRT 2DRT | 100 100 | Blend of EORTC H&N35 & XQ XST in rest XST during meals | Swallow more freq | 21 | med 2.6 yrs | 0.2 | 0.2

Table D6g Mixed head and neck cancer, salivary flow

Study | Rec# | No. Pts | Setting | Group | % Stage 0/I/II | % Stage III/IV | Mos Post-RT | Stimulated Flow Ratio % of Baseline | Unstimulated Flow Ratio % of Baseline | Comments
Mixed Settings
IMRT vs 3DCRT
Chao, 2001 | 10470 | 41 | 1º/postop RT ± postRT CTx/CCTx | IMRT post op IMRT definitive 3DCRT post op 3DCRT definitive | 14.6 (all) | 82.9 (all) | 6 | 0.70±.35 0.61±.30 0.38±.28 0.67±.25 | 0.50±.40 0.39±.21 0.22±.20 0.38±.10 | UWS: After swallowing let saliva drip into cup for 5 min. SWS: Chewed on paraffin strip for 2 min, then collected saliva for 5 min in cup while still chewing. RT technique did not independently influence stimulated whole salivary flow.
3DCRT vs 2DRT
Kuhnt, 2005 | 4840 | 33 | 1º/postop RT | 3DCRT 2DRT 3DCRT 2DRT 3DCRT 2DRT 3DCRT 2DRT 3DCRT 2DRT | | | 0.7 1.4 2.3 6 12 | ~0.69 ~0.55 ~0.42 ~0.19 ~0.43 ~0.19 ~0.64 ~0.21 ~0.50 ~0.25 | | P<0.1 for difference between treatment groups in salivary flow rate at 10 wks.

Table D6h Mixed head and neck cancer, dysphagia

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Palazzi, 2008 | 13850 | 116 | 1º/postop RT ± CCTx/CCTx + preRT CTx | IMRT 3DCRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
Langendijk, 2009 | 39950 | 529 | 1º/postop RT± CTx (timing?) | IMRT 3DCRT | | RTOG | 2–4 | | | 31.5 19.5 | 0.043
3DCRT vs 2DRT
Palazzi, 2008 | 13850 | 137 | 1º/postop RT ± CCTx/CCTx + preRT CTx | 3DCRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
IMRT vs 2DRT
Palazzi, 2008 | 13850 | 45 | 1º/postop RT ± CCTx/CCTx + preRT CTx | IMRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
Caudell, 2009 | 39420 | 122 | 1º RT ± preRT CTX and/or CCTx | IMRT 2DRT | 100 100 | Long-term PEG dependence/aspiration pneumonia/pharyngeal- esophogeal stricture/stenosis | any (composite) | | | 38.3 38.7 | 0.97 | RT tech NS in MVA (p=0.68)

Table D6i Mixed head and neck cancer, mucositis

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Palazzi, 2008 | 13850 | 116 | 1º/postop RT ± CCTx/CCTx + preRT CTx | IMRT 3DCRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
Vergeer, 2008 | 38540 | 141 | 1º/postop RT ± CCTx | IMRT 3DCRT | 77 62 | RTOG | ≥ 3 12 wk | ~0 ~4 | NS | | | p<0.05 at 3, 4, 5, 6, 7 wk; NS at 0, 1, 2, 8 wk
3DCRT vs 2DRT
Rades, 2008 | 13180 | 345 | 1º/postop RT± CCTx | 3DCRT 2DRT | 100 100 | CTC | 2–3 | ~87 ~92 | NR
Palazzi, 2008 | 13850 | 137 | 1º/postop RT ± CCTx/CCTx + preRT CTx | 3DCRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
IMRT vs 2DRT
Palazzi, 2008 | 13850 | 45 | 1º/postop RT ± CCTx/CCTx + preRT CTx | IMRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
Murphy, 2009 | 40430 | 75 | 1º/postop RT± CTx (timing?) | IMRT 2DRT | 84 (all) | MTS | > mod | 58 83 | 0.175

Table D6j Mixed head and neck cancer, skin

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Rating System | Grade | Acute % | p value | Late % | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Palazzi, 2008 | 13850 | 116 | 1º/postop RT ± CCTx/CCTx + preRT CTx | IMRT 3DCRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
Vergeer, 2008 | 38540 | 141 | 1º/postop RT ± CCTx | IMRT 3DCRT | 77 62 | RTOG | 2 7 wk | 86 74 | 0.03
3DCRT vs 2DRT
Rades, 2008 | 13180 | 345 | 1º/postop RT± CCTx | 3DCRT 2DRT | 100 100 | Acute-CTC; Late-RTOG | 2–3 | ~84 ~88 | NR | ~19 ~19 | NR
Palazzi, 2008 | 13850 | 137 | 1º/postop RT ± CCTx/CCTx + preRT CTx | 3DCRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute
IMRT vs 2DRT
Palazzi, 2008 | 13850 | 45 | 1º/postop RT ± CCTx/CCTx + preRT CTx | IMRT 2DRT | 87 (all) | CTC | > 2 | | | | | RT tech NS in MVA, acute

Table D6k Mixed head and neck cancer, oteoradionecrosis/bone

No studies.

Table D6l Mixed head and neck cancer, tumor control

Local Control
Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Marchal, 2004 | 5580 | 87 | 1º/postop/repeat RT ± pre/post RT CTx/CCTx | IMRT 3DCRT | ≥21.7 ≥19.5 | DFS | 88 85 | | | | | NS
Gomez, 2008 | 13390 | 32 | 1º/postop RT± CTx (timing?) | IMRT 3DCRT | ≥47.4 (all) | DFS | | | | | | NS | RT tech not entered in MVA
3DCRT vs 2DRT
Rades, 2008 | 13180 | 345 | 1º/postop RT± CCTx | 3DCRT 2DRT | 100 100 | LRC | 76 82 | 71 72 | 68 65 | | | 0.71
Gomez, 2008 | 13390 | 42 | 1º/postop RT± CTx (timing?) | 3DCRT 2DRT | ≥47.4 (all) | DFS | | | | | | NS | RT tech not entered in MVA
IMRT vs 2DRT
Gomez, 2008 | 13390 | 44 | 1º/postop RT± CTx (timing?) | IMRT 2DRT | ≥47.4 (all) | DFS | | | | | | NS | RT tech not entered in MVA

Table D6m Mixed head and neck cancer, patient survival

Study | Rec# | No. Pts | Setting | Group | % Stage III/IV | Outcome | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | p value | Comments
Mixed Settings
IMRT vs 3DCRT
Marchal, 2004 | 5580 | 87 | 1º/postop/repeat RT ± pre/post RT CTx/CCTx | IMRT 3DCRT | ≥21.7 ≥19.5 | OS | 90 87 | | | | | NS
Gomez, 2008 | 13390 | 42 | 1º/postop RT± CTx (timing?) | IMRT 3DCRT | ≥47.4 (all) | OS | | | | | | NS | RT tech not entered in MVA
3DCRT vs 2DRT
Rades, 2008 | 13180 | 345 | 1º/postop RT± CCTx | 3DCRT 2DRT | 100 100 | OS | 75 84 | 62 66 | 57 62 | | | 0.15
Gomez, 2008 | 13390 | 32 | 1º/postop RT± CTx (timing?) | 3DCRT 2DRT | ≥47.4 (all) | OS | | | | | | NS | RT tech not entered in MVA
IMRT vs 2DRT
Gomez, 2008 | 13390 | 44 | 1º/postop RT± CTx (timing?) | IMRT 2DRT | ≥47.4 (all) | OS | | | | | | NS | RT tech not entered in MVA