# Summary Tables and Figures

Appendix Table C1 Numbers of comparative studies and participants by single setting and site

| All | One Setting | One Site | NPC | OPH | PNS | UNP | LAR | MIX
IMRT vs. 3DCRT
Comparisons | 14 | 2 | 7 | 2 | 4 | 1 | 0 | 0 | 7
Total n | 1752 | 127 | 766 | 288 | 410 | 68 | 0 | 0 | 986
3DCRT vs. 2DRT
Comparisons | 12 | 3 | 8 | 3 | 1 | 2 | 1 | 1 | 4
Total n | 1497 | 398 | 940 | 373 | 130 | 231 | 87 | 122 | 526
IMRT vs. 2DRT
Comparisons | 22 | 4 | 12 | 6 | 4 | 1 | 1 | 0 | 10
Total n | 2441 | 573 | 1502 | 662 | 717 | 82 | 41 | 0 | 939
All comparisons
Total comparisons | 48 | 9 | 27 | 11 | 9 | 4 | 2 | 1 | 21
Total studies | 38 | 9 | 21 | 9 | 7 | 2 | 2 | 1 | 17
Grand total n | 5061 | 1098 | 2787 | 1174 | 1109 | 254 | 128 | 122 | 2274

Appendix Table C2 Numbers of comparisons, studies and participants by outcome

| | QOL/Adverse Events | | | | | | | Tumor Control | | | Patient Survival
| | QOL | XST | SF | DYS | MUC | SKN | ORH or BON | LC | LRC | DFS | DSS | OS
IMRT vs. 3DCRT
Comparisons | 14 | 3 | 9 | 1 | 3 | 7 | 6 | 2 | 2 | 4 | 4 | 1 | 8
Total n | 1752 | 429 | 879 | 41 | 729 | 735 | 540 | 152 | 112 | 569 | 274 | 195 | 800
3DCRT vs. 2DRT
Comparisons | 12 | 1 | 6 | 1 | 1 | 6 | 4 | 2 | 5 | 1 | 4 | 1 | 7
Total n | 1497 | 94 | 1013 | 33 | 137 | 939 | 716 | 231 | 579 | 345 | 360 | 127 | 931
IMRT vs. 2DRT
Comparisons | 22 | 4 | 13 | 3 | 5 | 8 | 7 | 2 | 3 | 2 | 5 | 0 | 7
Total n | 2441 | 317 | 1873 | 481 | 674 | 943 | 868 | 512 | 316 | 466 | 704 | 0 | 867
All comparisons
Total comparisons | 48 | 8 | 28 | 5 | 9 | 21 | 17 | 6 | 10 | 7 | 13 | 2 | 22
Total studies | 38 | 6 | 22 | 5 | 7 | 15 | 11 | 4 | 6 | 7 | 9 | 2 | 16
Grand total n | 5061 | 694 | 3322 | 555 | 1391 | 2193 | 1700 | 768 | 732 | 1380 | 1152 | 322 | 2264

Appendix Table C3 Summary of study quality characteristics: comparative studies

Selection Prospective/Retrospective | Inclusion/Exclusion Criteria Clear | Representative Selection | Initial Groups Comparable | Balanced by Design (Random/Matched) | Baseline Characteristics Clearly Comparable
Pro 15 | Yes 31 | Yes 25 | Yes 10 | Yes 5 | Yes 17
Retro 23 | No 7 | Unclear 8 | Unclear 21 | No 33 | Unclear 7
| | No 5 | No 7 | | No 4

Treatments Given During Same Time Period | Unbiased Treatment Allocation | Other Treatments Equal | Maintenance of Comparable Groups
Yes 13 | Clearly Random 2 | NA 3 | NA 25
Unclear 11 | Unclear 18 | Yes 12 | Yes 3
Yes and No 1 | Unclear/Era 1 | Unclear 16 | Unclear 9
No 13 | Era 12 | No 7 | No 1
| Availability/Preference 2
| Waiting List 1
| Risk to Sensitive Areas 2

Outcomes Valid, Reliable, Equal | Outcome Assessors Blind | Treatments Clearly Described | Multivariable Analysis (MVA) Conducted? | Well-done MVA or Intention-to-Treat Analysis (ITT) | USPSTF
Yes 38 | Yes 1 | Yes 32 | NA 2 | 2 ITT | Good 1
Unclear 0 | Unclear 13 | No 6 | Yes 20 | 1 unclear if ITT 13 unclear if well-done MVA | Fair 1
No 0 | No 24 | | No 16 | 1 not ITT 21 not well-done MVA | Poor 36

Appendix Table C4 Summary of results for tumor control outcomes

Comparison | Tumor Site | Setting | Study | n | Outcome | UV p | MV p | Pro/Retro | USPSTF
IMRT:3DCRT | OPH | 1° RT + CCTx | Rustoven, 2008 | 87 | LRC DFS | 4yr ↑ NS 4yr ↑ NS | 0.075 NS | Retro | Poor
| NPH | MIX: 1° RT ± CCTx | Fang, 2008 | 203 | LRC | 3yr, ≈NS | NS | Pro | Poor
| OPH | MIX: Postop RT ± CCTx | Rades, 2007 | 44 | LC | 2yr ↑ NS | NS | Retro | Poor
| OPH | MIX: 1° RT ± CCTx | Hodge, 2005 | 195 | LRC | 4yr ↑ p NR | | Retro | Poor
| OPH | MIX: 1°/postop RT ± preRT CTx | Nutting, 2009 (RCT) | 84 | LRC | 1yr ≈NS | | Pro | Good
| NC/PNS | MIX: Primary/preop/postop RT with or without postRT CTx or concurrent CTx (1o/preop/postop RT ± postRT CTx/CCTx) | Chen, 2007 | 68 | LC DFS | 5yr, ≈NS NS | | Retro | Poor
| MIX | MIX: 1°/postop/repeat RT ± pre/post RT CTx/CCTx | Marchal, 2004 | 87 | DFS | 1yr, ↑NS | | Pro | Poor
| MIX | MIX: 1°/postop RT ± CTx (t?) | Gomez, 2008 | 42 | DFS | NS | RT not in MVA | Retro | Poor
3DCRT:2DRT | NPH | 1° RT + split CTx | Wu, 2005 (RCT) | 96 | LC | 1yr, ↑ 0.003 | | Pro | Poor
| LAR | 1° RT | Zouhair, 2004 | 122 | LC | 5yr, ≈NS | NS | Retro | Poor
| OPH | MIX: Postop RT ± CCTx | Rades, 2007 | 130 | LC | 2yr ≈NS | NS | Retro | Poor
| NC/PNS | MIX: Primary/preop/postop RT with or without postRT CTx or concurrent CTx (1o/preop/postop RT ± postRT CTx/CCTx) | Chen, 2007 | 104 | LC DFS | 5yr, ≈NS NS | | Retro | Poor
| NC/PNS | 1°/preop/postop RT | Dirix, 2007 | 127 | LC DFS | NS NS | | Retro | Poor
| UNK | 1°/postop RT± preRT CTx/CCTx | Beldi, 2007 | 87 | DFS | 5yr, ↑ <0.01 | NS | Retro | Poor
| MIX | MIX: 1°/postop RT ± CTx (t?) | Gomez, 2008 | 32 | DFS | NS | RT not in MVA | Retro | Poor
| MIX | MIX: 1°/postop RT± CCTx | Rades, 2008 | 345 | LRC | 3yr, ≈NS | | Retro | Poor
IMRT:2DRT | NPH | 1° RT + split CTx | Laskar, 2008 | 36 | LRC DFS | 2yr ↑ NS 2yr ↑ NS | RT not in MVA | Pro | Poor
| OPH | 1° RT + CCTx | Lee, 2006 | 112 | LC LRC DFS | 5yr, ↑ NS 5yr, ↑ NS 5yr, ↑ NS | | Retro | Poor
| OPH | MIX: Postop RT ± CCTx | Rades, 2007 | 122 | LC | 2yr, ↑ NS | | Retro | Poor
| OPH | MIX: 1°/pre/postop RT ± CCTx | Chao, 2001 | 430 | LRC DFS | 2yr, def, ↑ NS; postop, ↑ NS 2yr, def, ↑ 0.002; postop, ↑ 0.008 | | Retro | Poor
| NC/PNS | MIX: Primary/preop/postop RT with or without postRT CTx or concurrent CTx (1o/preop/postop RT ± postRT CTx/CCTx) | Chen, 2007 | 82 | LC DFS | 5yr, ≈NS NS | | Retro | Poor
| MIX | MIX: 1°/postop RT ± CTx (t?) | Gomez, 2008 | 44 | DFS | NS | RT not in MVA | Retro | Poor

Appendix Table C5 Summary of results for patient survival outcomes

Study | Tumor Site | Setting | Study | n | Outcome | UV p | MV p | Pro/Retro | USPSTF
IMRT:3DCRT | OPH | 1° RT + CCTx | Rustoven, 2008 | 87 | OS | 4yr ↑ NS | NS | Retro | Poor
| NPH | MIX: 1° RT ± CCTx | Fang, 2008 | 203 | OS | 3yr, ≈ NS | NS | Pro | Poor
| OPH | MIX: Postop RT ± CCTx | Rades, 2007 | 44 | OS | 2yr ~↑ NS | NS | Retro | Poor
| OPH | MIX: 1° RT ± CCTx | Hodge, 2005 | 195 | DSS OS | 4yr ↑ p NR 4yr ↑ 0.02 | NS | Retro | Poor
| OPH | MIX: 1°/postop RT ± preRT CTx | Nutting, 2009 (RCT) | 84 | OS | 1yr, ≈ NS | | Pro | Good
| NC/PNS | MIX: Primary/preop/postop RT with or without postRT CTx or concurrent CTx (1o/preop/postop RT ± postRT CTx/CCTx) | Chen, 2007 | 68 | OS | 5yr, ↓ NS | | Retro | Poor
| MIX | MIX: 1°/postop/repeat RT ± pre/post RT CTx/CCTx | Marchal, 2004 | 87 | OS | 1yr, ≈ NS | | Pro | Poor
| MIX | MIX: 1°/postop RT ± CTx (t?) | Gomez, 2008 | 42 | OS | NS | RT not in MVA | Retro | Poor
3DCRT:2DRT | NPH | MIX: 1° RT ± CTx (t?) | Wu, 2005 (RCT) | 96 | OS | 1yr, ≈NS | | Pro | Poor
| OPH | MIX: Postop RT ± CCTx | Rades, 2007 | 130 | OS | 2yr ~↑ NS | NS | Retro | Poor
| NC/PNS | MIX: Primary/preop/postop RT with or without postRT CTx or concurrent CTx (1o/preop/postop RT ± postRT CTx/CCTx) | Chen, 2007 | 104 | OS | 5yr, ~↑ NS | | Retro | Poor
| NC/PNS | 1°/preop/postop RT | Dirix, 2007 | 127 | OS DSS | NS NS | | Retro | Poor
| UNK | 1°/postop RT± preRT CTx/CCTx | Beldi, 2007 | 87 | OS | 5yr, ↑ <0.01 | NS | Retro | Poor
| MIX | MIX: 1°/postop RT ± CTx (t?) | Gomez, 2008 | 32 | OS | NS | RT not in MVA | Retro | Poor
| MIX | MIX: 1°/postop RT± CCTx | Rades, 2008 | 345 | OS | 3yr, ≈ NS | | Retro | Poor
IMRT:2DRT | NPH | 1° RT + split CTx | Laskar, 2008 | 36 | OS | 2yr ↑ NS | RT not in MVA | Pro | Poor
| OPH | 1° RT + CCTx | Lee, 2006 | 112 | OS | 5yr, ↑ NS | | Retro | Poor
| OPH | MIX: Postop RT ± CCTx | Rades, 2007 | 122 | OS | 2yr, ↑ NS | | Retro | Poor
| OPH | MIX: 1°/pre/postop RT ± CCTx | Chao, 2001 | 430 | OS | 2yr, def, ↑ 0.001; postop, ↑ 0.003 | | Retro | Poor
| NC/PNS | MIX: Primary/preop/postop RT with or without postRT CTx or concurrent CTx (1°/preop/postop RT ± postRT CTx/CCTx) | Chen, 2007 | 82 | OS | 5yr, ≈ NS | | Retro | Poor
| UNK | 1°/postop RT ± CTx (t?) | Madani, 2008 | 41 | OS | 1yr, ↑ NS | | Retro | Poor
| MIX | MIX: 1°/postop RT ± CTx (t?) | Gomez, 2008 | 44 | OS | NS | RT not in MVA | Retro | Poor

Figure C1 Acute xerostomia, IMRT vs. 3DRCT

Figure C2 Late xerostomia, IMRT vs. 3DCRT

Figure C3 Acute mucositis, IMRT vs. 3DCRT

Figure C4 Late mucositis, IMRT vs. 3DCRT

Figure C5 Acute dysphagia, IMRT vs. 3DCRT

Figure C6 Late dysphagia, IMRT vs. 3DCRT

Figure C7 Acute skin toxicity, IMRT vs. 3DCRT

Figure C8 Late skin toxicity, IMRT vs. 3DCRT

Figure C9 Late osteoradionecrosis/bone toxicity, IMRT vs. 3DCRT

Figure C10 Late xerostomia, 3DCRT vs. 2DRT

Figure C11 Acute mucositis, 3DCRT vs. 2DRT

Figure C12 Late mucositis, 3DCRT vs. 2DRT

Figure C13 Acute skin toxicity, 3DCRT vs. 2DRT

Figure C14 Late skin toxicity, 3DCRT vs. 2DRT

Figure C15 Late osteoradionecrosis/bone toxicity, 3DCRT vs. 2DRT

Figure C16 Acute xerostomia, IMRT vs. 2DRT

Figure C17 Late xerostomia, IMRT vs. 2DRT

Figure C18 Acute mucositis, IMRT vs. 2DRT

Figure C19 Late mucositis, IMRT vs. 3DRT

Figure C20 Acute dysphagia, IMRT vs. 2DRT

Figure C21 Late dysphagia, IMRT vs. 2DRT

Figure C22 Acute skin toxicity, IMRT vs. 2DRT

Figure C23 Late skin toxicity, IMRT vs. 2DRT

Figure C24 Late osteoradionecrosis/bone toxicity, IMRT vs. 2DRT