# Exact Search Strings

- MEDLINE^®^(January 1, 1990, through September 28, 2009)
- EMBASE^®^ (January 1, 1990, through September 28, 2009)
- Cochrane Controlled Trials Register (no date restriction)

Single-arm studies, which are not a main focus of this review, were selected from studies identified through the January 13, 2009 search result update. Comparative studies were identified through the latest search updates.

In addition to electronic databases, abstracts for the past 5 years of meetings of the American Society of Therapeutic Radiation Oncology (ASTRO) and American Society of Clinical Oncology (ASCO) were searched.

Database Search Strategy:

(head and neck neoplasms [MH] OR ((larynx [TIAB] OR laryngeal [TIAB] OR supraglottic [TIAB] OR glottic [TIAB] OR subglottic [TIAB] OR pharynx [TIAB] OR pharyngeal [TIAB] OR hypopharynx [TIAB] OR hypopharyngeal [TIAB] OR hypo-pharynx [TIAB] OR hypo-pharyngeal [TIAB] OR oropharynx [TIAB] OR oropharyngeal [TIAB] OR oro-pharynx [TIAB] OR oro-pharyngeal [TIAB] OR nasopharynx [TIAB] OR nasopharyngeal [TIAB] OR naso-pharynx [TIAB] OR naso-pharyngeal [TIAB] OR lip [TIAB] OR lips [TIAB] OR oral [TIAB] OR paranasal [TIAB] OR para-nasal [TIAB] OR nasal [TIAB] OR sinus [TIAB] OR salivary [TIAB] OR parotid [TIAB])

AND

(neoplasm [TIAB] OR neoplasms [TIAB] OR tumor [TIAB] OR tumors [TIAB] OR tumour [TIAB] OR tumours [TIAB] OR cancer [TIAB] OR cancers [TIAB] OR adenocarcinoma [TIAB] OR carcinoma [TIAB])

OR

“occult primary” [TIAB] OR “unknown primary” [TIAB]

AND

(radiotherapy, conformal [MH] OR IMRT [TIAB] OR 3dcrt [TIAB] OR “3D-CRT” [TIAB] OR “3-D CRT” [TIAB] OR “3D CRT” [TIAB] OR (intensity [TIAB] AND modulated [TIAB]) OR conformal [TIAB] OR proton [TIAB] OR protons [TIAB] OR protons [MH]))

AND

humans [MH]