# Appendixes

Appendix A Exact Search Strings

Appendix B Excluded Studies

Appendix C Summary Tables and Figures

Appendix D Comparative Studies: Full Evidence/Data Abstraction Tables

Appendix E Single-Arm Studies