# Acknowledgments

The research team would like to acknowledge the efforts of Maxine A. Gere, M.S., for government program management and general editorial support; Elizabeth De La Garza for administrative support; Ariel Katz, M.D., M.P.H., and Ryan Chopra, B.S., M.P.H., for data abstraction and fact-checking; and William F. Lawrence, M.D., M.S., of the Agency for Healthcare Research and Quality for advice as our Task Order Officer.

## Technical Expert Panel

- Avraham Eisbruch, M.D.
- Professor, Department of Radiation Oncology
- University of Michigan Comprehensive Cancer Center
- Ann Arbor, MI

- Arlene A. Forastiere, M.D.
- Professor of Oncology, and Professor of Otolaryngology, Head and Neck Surgery, and Radiation Oncology
- Johns Hopkins University School of Medicine
- Baltimore, MD

- Martin Fuss, M.D.
- Professor, Department of Radiation Medicine
- Division of Radiation Oncology
- Oregon Health & Science University
- Portland, OR

- Quynh-Thu Le, M.D.
- Professor, Radiation Oncology/Radiation Therapy and Professor, Otolaryngology (Head and Neck)
- Stanford School of Medicine
- Stanford, CA

- William M. Mendenhall, M.D.
- Resident Alumni Professorship in Radiation Oncology
- University of Florida Health Science Center and Shands Hospital
- Gainesville, FL

- David G. Pfister, M.D.
- Chief, Head and Neck Oncology Service
- Memorial Sloan-Kettering Cancer Center
- New York, NY

- Andy M. Trotti, M.D.
- Director, Radiation Oncology Clinical Research
- H. Lee Moffitt Cancer Center & Research Institute
- Tampa, FL

## AHRQ Contacts

- Beth Collins-Sharp, Ph.D., R.N.
- Director, EPC Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- William F. Lawrence, M.D., M.S.
- EPC Program Task Order Officer
- Agency for Healthcare Research and Quality
- Rockville, MD