# Abbreviations

Δ: change
~: approximately
1^o^: primary
2.5D: 2 ½ D RT
2D: two-dimensional
2DRT: 2D conventional RT
3D: three dimensional
3DC: 3D conformal RT
3DCRT: 3D conformal radiotherapy
ACC: accelerated fractionation
AdjCtx: adjuvant chemoradiotherapy
AHRQ: Agency for Healthcare Research and Quality
ASCO: American Society of Clinical Oncology
ASTRO: American Society of Therapeutic Radiation Oncology
AUD: auditory acuity
BON: bone
BOT: base of tongue
BRA: brachytherapy
BRN: brain AEs
BST: boost dose
CCRTx: concurrent chemoradiotherapy
CER: comparative effectiveness review
CHT: chemotherapy only
CNT: central nervous system tumor (including spine)
CRN: cranial nerve tumors
CRT: chemoradiotherapy
CT: computed tomography
CTP: cytoprotective agent
CTV: clinical target volume
CUT: cutaneous tumors (melanoma, etc.)
def: definitive
DFR: definitive RT
DFS: disease-free survival
DNT: dental AEs
DS?: disease unclear
DSS: (cancer) disease-specific survival
DYS: dysphagia
Dx: diagnosis
EAR: ear tumors
EORTC: European Organization for Research and Treatment of Cancer
EPC: Evidence-based Practice Center
EPICOT: Evidence, Population, Intervention, Comparators, Outcome, Time stamp
ESO: esophagus AEs
EST: esophageal or precursors
ETH: ethmoid sinus
EYE: eye tumors
F/U: followup
F/U?: followup uncertain
freq: frequency
Gr: grade
grnd: ground
GTV: gross tumor volume
Gy: Gray
Hb: hemoglobin
HEM: hematologic tumor (including lymphoma
HN: head and neck
HNCI: Head and Neck Cancer Inventory
HNQOL: Head and Neck Cancer-Specific Quality of Life
HNU: head & neck unspecified
HPV: human papillomavirus
HRT: heart AEs
HYF: hyperfractionation
HYP: hypopharyngeal
ICBT: intracavitary brachytherapy
IMM: with immobilization
IMR: IMRT
IMRT: intensity modulated radiotherapy
ITT: intention to treat
LAR: laryngeal
LC: local control
LDH: lactate dehydrogenase
LFF: local failure free
LFFR: local freedom from recurrence
LN: lymph node
LNG: lung AEs
LR: locoregional
LRC: locoregional control
LRPFS: locoregional progression-free survival
LRRFS: locoregional recurrence-free survival
LX: larynx AEs
MAX: maxillary sinus
MET: metastatic
mets: metastases
MFS: (distant) metastasis-free survival
MIX: mixed head and neck
MLT: major late toxicities
mod: moderate
mo(s).: month(s)
MUC: mucous membrane AEs
MVA: multivariable analysis
NA: not applicable
NBT: neutron beam therapy
NCCN: National Comprehensive Cancer Network
NCI CTC: National Cancer Institute’s Common Toxicity Criteria
NeoadjCtx: neoadjuvant chemoradiotherapy
NPC: nasopharyngeal cancer
NPH: nasopharyngeal
NR: not reported
NRD: not relevant disease
NRO: not relevant outcome (or no follow-up)
NRT: not relevant treatment
NS: not significant
NV: nausea/vomiting
O?: outcome unclear
OAE: other AE
OCL: oral cavity/lip
OCU: ocular AEs
OHN: other head and neck tumor
OLF: olfactory AEs
OPH: oropharyngeal
ORN: osteoradionecrosis
OS: overall survival
OST: other non-head and neck solid tumor
OTE: other time-to-event outcome
OTO: otologic/auditory AEs
PAL: palliative
PAR: paraganglioma
PBT: proton beam therapy
PCR: postoperative CRT
pctg: percentage
PDQ: Physician Data Query
PFS: progression-free survival
PHR: pharyngeal
PHX: pharynx
PNS: paranasal sinus/nasal cavity
postop: postoperative
postopRT: postoperative radiotherapy
postRT: after radiotherapy
PRE: preoperative (neoadjuvant)
preop: preoperative
preopRT: preoperative radiotherapy
preRT: before radiotherapy
Pro: prospective
prob(s): probability(ies)
PS: performance status
PST: postoperative (adjuvant)
PTH: parathyroid
PTV: planning target volume
Q#?: unclear if relevant to any key question
QLQ: Quality of Life Questionnaire
QOL: quality of life
RCT: randomized, controlled trial
REC: recurrent (reirradiation)
ReRT: reirradiation
Retro: retrospective
RSE: radiosensitizing agent
RSP: tumor response
RT: radiotherapy
RTOG: Radiation Therapy Oncology Group
SAL: salivary gland, including parotid
SB: skull base tumors
SCC: small cell cancer
sev: severity
SF-36: Short Form-36
SIN: sinus unspecified
SKN: skin AEs
SLF: salivary flow
SOMA: Subjective, Objective, Management, Analytic
SPN: spinal cord AEs
SRS: stereotactic radiosurgery
SRT: stereotactic radiotherapy
SUB: subcutaneous tissue AEs
SUR: surgery only
Sx: symptoms
T?: treatment unclear
TAE: toxicity/adverse events (not specified)
TEP: Technical Expert Panel
THY: thyroid
TR: tracheal tumors
TRD: treatment-related death
TTR: time-to-recurrence
Tx: treatment
UA: univariate analysis
UCF: unspecified conformal RT
UNP: unknown/occult primary
URT: unspecified radiotherapy
USPSTF: U.S. Preventive Services Task Force
UWQOL: University of Washington Quality of Life
VAS: visual analog scale
VSA: visual acuity
XQ: xerostomia questionnaire
XST: xerostomia
yr(s): years