# References

1 American Cancer Society (ACS). Cancer facts and figures 2003. Atlanta (GA): American Cancer Society (ACS); 2003. 48 p. Also available: http://www.cancer.org/docroot/STT/stt_0.asp.
2 Jemal A, Murray T, Ward E, et al. Cancer statistics, 2005. CA Cancer J Clin. 2005;55(1):10-30. [pmid: 15661684].
3 Greenlee RT, Hill-Harmon MB, Murray T, et al. Cancer statistics, 2001. CA Cancer J Clin. 2001;51(1):15-36. [pmid: 11577478].
4 Guinee VF. Epidemiology of breast cancer. In: Bland KI, Copeland EM 3rd, editors. The breast: comprehensive management of benign and malignant diseases. 2nd ed. Vol. 1. Philadelphia (PA): W.B. Saunders Company; 1998. p. 339–51.
5 Jemal A, Tiwari RC, Murray T, et al. Cancer statistics, 2004. CA Cancer J Clin. 2004;54(1):8-29. [pmid: 14974761].
6 Yeatman TJ, Bland KI. Assessment and designation of breast cancer stage. In: Bland KI, Copeland EM 3rd, editors. The breast: comprehensive management of benign and malignant diseases. 2nd ed. Vol. 1. Philadelphia (PA): W.B. Saunders Company; 1998. p. 400–17.
7 American Cancer Society (ACS). After the tests: staging. [internet]. Atlanta (GA): American Cancer Society (ACS); 2001 [cited 2002 Jan 2]. [2 p]. Available: http://www.cancer.org.
8 U.S. Preventive Services Task Force (USPSTF). Screening for breast cancer: recommendations and rationale. Washington (DC): Agency for Healthcare Research and Quality (AHRQ); 2002 Feb. 10 p. (AHRQ Pub.; no. 02‐507A). Also available: http://www.ahrq.gov/clinic/3rduspstf/ breastcancer.
9 Humphrey LL, Helfand M, Chan BK, et al. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Sep 3. 2002;137(5 Part 1):347-67. [pmid: 12204020].
10 Rosato FE, Rosato EL. Examination techniques: roles of the physician and patient in evaluating breast diseases. In: Bland KI, Copeland EM 3rd, editors. The breast: comprehensive management of benign and malignant diseases. 2nd ed. Vol. 1. Philadelphia (PA): W.B. Saunders Company; 1998. p. 615–23.
11 Liberman L, Menell JH. Breast imaging reporting and data system (BI-RADS). Radiol Clin North Am. May. 2002;40(3):409-30. [pmid: 12117184].
12 Diagnostic and Interventional Radiology Department. Mammography. Omaha (NE): Creighton University School of Medicine; 22 p. Also available: http://radiology.creighton.edu/mammo.html.
13 Obenauer S, Hermann KP, Grabbe E. Applications and literature review of the BI-RADS classification. Eur Radiol. May. 2005;15(5):1027-36. [pmid: 15856253].
14 Schillaci O, Buscombe JR. Breast scintigraphy today: indications and limitations. Eur J Nucl Med Mol Imaging. Jun. 2004;31(Suppl 1):S35-45. [pmid: 15103505].
15 Kopans DB. The positive predictive value of mammography. AJR Am J Roentgenol. Mar. 1992;158(3):521-6. [pmid: 1310825].
16 Khan KS. Systematic reviews of diagnostic tests: a guide to methods and application. Baillieres Best Pract Res Clin Obstet Gynaecol. Feb. 2005;19(1):37-46.
17 Dujardin B, Van den Ende J, Van Gompel A, et al. Likelihood ratios: a real improvement for clinical decision making. Eur J Epidemiol. Feb. 1994;10(1):29-36. [pmid: 7957786].
18 Gallagher EJ. Clinical utility of likelihood ratios. Ann Emerg Med. Mar. 1998;31(3):391-7. [pmid: 9506499].
19 Eisenberg JM. Derived thresholds. Determining the diagnostic probabilities at which clinicians initiate testing and treatment. Med Decis Making. 1983;3(2):155-68. [pmid: 6415358].
20 Barone JE. Evidence-based medicine applied to sentinel lymph node biopsy in patients with breast cancer. Am Surg. Jan. 2005;71(1):66-70. [pmid: 15757061].
21 Verkooijen HM. Diagnostic accuracy of large-core needle biopsy for nonpalpable breast disease: a meta-analysis. Br J Cancer. Mar. 2000;82(5):1017-21. [pmid: 10737383].
22 Kerlikowske K. Evaluation of abnormal mammography results and palpable breast abnormalities. Ann Intern Med. Aug 19. 2003;139(4):274-84. [pmid: 12965983].
23 Yasmeen S. Frequency and predictive value of a mammographic recommendation for short-interval follow-up. J Natl Cancer Inst. Mar 19. 2003;95(6):429-36. [pmid: 12644536].
24 Chalmers I, Adams M, Dickersin K, et al. A cohort study of summary reports of controlled trials. JAMA. Mar 9. 1990;263(10):1401-5. [pmid: 2304219].
25 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. Mar. 1987;8(2):198-203. [pmid: 3818406].
26 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. Mar. 1992;3(3):187-91. [pmid: 1586615].
27 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. In: Cochrane Library [Cochrane methodology review]. Issue 2. Oxford: Update Software; 2001 [cited 2001 Apr 23]. [35 p]. Available: http://www.cochranelibrary.com.
28 Marx WF, Cloft HJ, Do HM, et al. The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. AJNR Am J Neuroradiol. 1999;20(6):1173-7. [pmid: 10445467].
29 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. Jul. 1993;40(7):632-4. [pmid: 8403137].
30 Carneiro AV. Applicability of clinical trial results to the individual patient: practice guidelines. Rev Port Cardiol. Feb. 2003;22(2):259-68. [pmid: 12769004].
31 Armitage P, Berry G. Statistical methods in medical research. 3rd ed. Oxford, England: Blackwell Scientific; 1994. 620 p.
32 Lopis R. A personal encounter with a mystery illness. Aust Fam Physician. Mar. 1991;20(3):316-7. [pmid: 2039419].
33 Bojia F. Comparison of fine-needle aspiration cytology and excisional biopsy of breast lesions. East Afr Med J. May. 2001;78(5):226-8. [pmid: 12002079].
34 Vetrani A. Fine-needle aspiration biopsies of breast masses. An additional experience with 1153 cases (1985 to 1988) and a meta-analysis. Cancer. Feb 1. 1992;69(3):736-40. [pmid: 1530911].
35 Abu-Salem OT. Fine needle aspiration biopsy (FNAB) of breast lumps: comparison study between pre- and post-operative histological diagnosis. Arch Inst Pasteur Tunis. 2002;79(14):59-63. [pmid: 15072246].
36 Ljung BM. Diagnostic accuracy of fine-needle aspiration biopsy is determined by physician training in sampling technique. Cancer. Aug 25. 2001;93(4):263-8. [pmid: 11507700].
37 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Contract no. 290-97-0011. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2002 Apr. 199 p. (Evidence report/technology assessment; no. 47).
38 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. Jun 19. 2004;328(7454):1490. [pmid: 15205295]. [pmcid: 428525].
39 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun 15. 2002;21(11):1539-58. [pmid: 12111919].
40 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analysis. BMJ. Sep 6. 2003;327:557-60. [pmid: 12958120]. [pmcid: 192859].
41 Ioannidis JP, Contopoulos-Ioannidis DG, Lau J. Recursive cumulative meta-analysis: a diagnostic for the evolution of total randomized evidence from group and individual patient data. J Clin Epidemiol. Apr. 1999;52(4):281-91. [pmid: 10235168].
42 Lau J, Schmid CH, Chalmers TC. Cumulative meta-analysis of clinical trials builds evidence for exemplary medical care. J Clin Epidemiol 1995 Jan;48(1):45–57; 59–60.
43 Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. Jul 30. 1993;12(14):1293-316. [pmid: 8210827].
44 Deeks JJ. Systematic reviews of evaluations of diagnostic and screening tests. In: Egger M, Smith GD, Altman DG, editors. Systematic reviews in health care: meta-analysis in context. 2nd ed. London, England: BMJ Books; 2001. p. 248–82.
45 Stengel D, Bauwens K, Sehouli J, et al. A likelihood ratio approach to meta-analysis of diagnostic studies. J Med Screen. 2003;10(1):47-51. [pmid: 12790315].
46 Banks E. Influence of personal characteristics of individual women on sensitivity and specificity of mammography in the Million Women Study: cohort study. BMJ. Aug 28. 2004;329(7464):477. [pmid: 15331472]. [pmcid: 515195].
47 Higgins JP, Thompson SG. Controlling the risk of spurious findings from meta-regression. Stat Med. Jun 15. 2004;23(11):1663-82. [pmid: 15160401].
48 Harbord R, Statistical Software Components, Boston College Department of Economics. METAREG: Stata module to perform meta-analysis regression. [software download]. Stockholm, Sweden: EconPapers; 2004 Sep 22 [cited 2004 Nov 3]. Available: http://econpapers.hhs.se/software/bocbocode/s446201.htm.
49 Elan Avinza approved. Pharm Approval Monthly 2002 Apr 1;7(4):56
50 Agency for Healthcare Research and Quality (AHRQ). FDG positron emission tomography for evaluating breast cancer - systematic review. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2001. Also available: http://www.mrw.interscience.wiley.com/cochrane/clhta/articles/HTA-20020419/frame.html.
51 Holle LH, Trampert L, Lung-Kurt S, et al. Investigations of breast tumors with fluorine-18-fluorodeoxyglucose and SPECT. J Nucl Med. Apr. 1996;37(4):615-22. [pmid: 8691251].
52 Brix G, Henze M, Knopp MV, et al. Comparison of pharmacokinetic MRI and [18F] fluorodeoxyglucose PET in the diagnosis of breast cancer: initial experience. Eur Radiol. 2001;11(10):2058-70. [pmid: 11702142].
53 Crowe JP Jr, Adler LP, Shenk RR, et al. Positron emission tomography and breast masses: comparison with clinical, mammographic, and pathological findings. Ann Surg Oncol. Mar. 1994;1(2):132-40. [pmid: 7834438].
54 Yutani K, Tatsumi M, Shiba E, et al. Comparison of dual-head coincidence gamma camera FDG imaging with FDG PET in detection of breast cancer and axillary lymph node metastasis. J Nucl Med. Jun. 1999;40(6):1003-8. [pmid: 10452318].
55 Yutani K, Shiba E, Kusuoka H, et al. Comparison of FDG-PET with MIBI-SPECT in the detection of breast cancer and axillary lymph node metastasis. J Comput Assist Tomogr. 2000;24(2):274-80. [pmid: 10752892].
56 Heinisch M, Gallowitsch HJ, Mikosch P, et al. Comparison of FDG-PET and dynamic contrast-enhanced MRI in the evaluation of suggestive breast lesions. Breast. Feb. 2003;12(1):17-22. [pmid: 14659351].
57 Walter C, Scheidhauer K, Scharl A, et al. Clinical and diagnostic value of preoperative MR mammography and FDG-PET in suspicious breast lesions. Eur Radiol. Jul. 2003;13(7):1651-6. [pmid: 12835981].
58 Palmedo H, Bender H, Grunwald F, et al. Comparison of fluorine-18 fluorodeoxyglucose positron emission tomography and technetium-99m methoxyisobutylisonitrile scintimammography in the detection of breast tumours. Eur J Nucl Med. Sep. 1997;24(9):1138-45. [pmid: 9283107].
59 Tse NY, Hoh CK, Hawkins RA, et al. The application of positron emission tomographic imaging with fluorodeoxyglucose to the evaluation of breast disease. Ann Surg. Jul. 1992;216(1):27-34. [pmid: 1632699]. [pmcid: 1242543].
60 Bergmann H. An inter-laboratory comparison study of image quality of PET scanners using the NEMA NU 2-2001 procedure for assessment of image quality. Phys Med Biol. May 21. 2005;50(10):2193-207. [pmid: 15876661].
61 Levine EA, Freimanis RI, Perrier ND, et al. Positron emission mammography: initial clinical results. Ann Surg Oncol. 2003;10(1):86-91. [pmid: 12513966].
62 McDonough MD, DePeri ER, Mincey BA. The role of positron emission tomographic imaging in breast cancer. Curr Oncol Rep. Jan. 2004;6(1):62-8. [pmid: 14664763].
63 Avril N, Schelling M, Dose J, et al. Utility of PET in Breast Cancer. Clin Positron Imaging. Oct. 1999;2(5):261-71. [pmid: 14516650].
64 Hoh CK, Schiepers C. 18-FDG imaging in breast cancer. Semin Nucl Med. Jan. 1999;29(1):49-56. [pmid: 9990683].
65 Bleckmann C, Dose J, Bohuslavizki KH, et al. Effect of attenuation correction on lesion detectability in FDG PET of breast cancer. J Nucl Med. Dec. 1999;40(12):2021-4. [pmid: 10616880].
66 Doshi NK, Shao Y, Silverman RW, et al. Design and evaluation of an LSO PET detector for breast cancer imaging. Med Phys. Jul. 2000;27(7):1535-43. [pmid: 10947256].
67 Yutani K, Tatsumi M, Uehara T, et al. Effect of patients' being prone during FDG PET for the diagnosis of breast cancer. AJR Am J Roentgenol. Nov. 1999;173(5):1337-9. [pmid: 10541114].
68 Rosen EL, Turkington TG, Soo MS, et al. Detection of primary breast carcinoma with a dedicated, large-field-of-view FDG PET mammography device: initial experience. Radiology. Feb. 2005;234(2):527-34. [pmid: 15671006].
69 Bhargava P, Zhuang H, Kumar R, et al. Iatrogenic artifacts on whole-body F-18 FDG PET imaging. Clin Nucl Med. Jul. 2004;29(7):429-39. [pmid: 15192468].
70 Murthy K, Aznar M, Bergman AM, et al. Positron emission mammographic instrument: initial results. Radiology. Apr. 2000;215(1):280-5. [pmid: 10751499].
71 Boerner AR, Weckesser M, Herzog H, et al. Optimal scan time for fluorine-18 fluorodeoxyglucose positron emission tomography in breast cancer. Eur J Nucl Med. Mar. 1999;26(3):226-30. [pmid: 10079312].
72 Wahl RL. Current status of PET in breast cancer imaging, staging, and therapy. Semin Roentgenol. Jul. 2001;36(3):250-60. [pmid: 11475071].
73 Marshall C, Mustafa S, Wheatley DC, et al. A comparison of 18F-FDG gamma camera PET, mammography and ultrasonography in demonstrating primary disease in locally advanced breast cancer. Nucl Med Commun. Jul. 2004;25(7):721-5. [pmid: 15208500].
74 Cronin B, Marsden PK, O'Doherty MJ. Are restrictions to behaviour of patients required following fluorine-18 fluorodeoxyglucose positron emission tomographic studies. Eur J Nucl Med. Feb. 1999;26(2):121-8. [pmid: 9933345].
75 Silberstein EB. Prevalence of adverse reactions to positron emitting radiopharmaceuticals in nuclear medicine. Pharmacopeia Committee of the Society of Nuclear Medicine. J Nucl Med. Dec. 1998;39(12):2190-2. [pmid: 9867168].
76 Katanick SL. Fundamentals of ICANL accreditation. J Nucl Med Technol. Mar. 2005;33(1):19-23. [pmid: 15731016].
77 Hillner BE. Decision analysis: MIBI imaging of nonpalpable breast abnormalities. J Nucl Med. Nov. 1997;38(11):1772-8. [pmid: 9374352].
78 Allen MW, Hendi P, Schwimmer J, et al. Decision analysis for the cost effectiveness of sestamibi scintimammography in minimizing unnecessary biopsies. Q J Nucl Med. Jun. 2000;44(2):168-85. [pmid: 10967626].
79 Liberman M, Sampalis F, Mulder DS, et al. Breast cancer diagnosis by scintimammography: a meta-analysis and review of the literature (Provisional record). Breast Cancer Res Treat. 2003;80(1):115-26. [pmid: 12889605].
80 Medical Advisory Secretariat, Ontario Ministry of Health and Long-Term Care. Scintimammography. Toronto: Ontario Ministry of Health and Long-Term Care; 2003. Also available: http://www.mrw.interscience.wiley.com/cochrane/clhta/articles/HTA-20040735/frame.html.
81 Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. 1993;13(4):313-21. [pmid: 8246704].
82 Sampalis FS, Denis R, Picard D, et al. International prospective evaluation of scintimammography with (99m)technetium sestamibi. Am J Surg. Jun. 2003;185(6):544-9. [pmid: 12781883].
83 Khalkhali I, Baum JK, Villanueva-Meyer J, et al. (99m)Tc sestamibi breast imaging for the examination of patients with dense and fatty breasts: multicenter study. Radiology. Jan. 2002;222(1):149-55. [pmid: 11799940].
84 Scopinaro F, Schillaci O, Ussof W, et al. A three center study on the diagnostic accuracy of 99mTc-MIBI scintimammography. Anticancer Res. 1997;17(3B):1631-4. [pmid: 9179208].
85 Tofani A, Sciuto R, Semprebene A, et al. 99Tcm-MIBI scintimammography in 300 consecutive patients: factors that may affect accuracy. Nucl Med Commun. Dec. 1999;20(12):1113-21. [pmid: 10664992].
86 Mekhmandarov S, Sandbank J, Cohen M, et al. Technetium-99m-MIBI scintimammography in palpable and nonpalpable breast lesions. J Nucl Med. Jan. 1998;39(1):86-91. [pmid: 9443742].
87 Danielsson R, Bone B, Gad A, et al. Sensitivity and specificity of planar scintimammography with 99mTc‐sestamibi. Acta Radiol. Jul. 1999;40(4):394-9. [pmid: 10394867].
88 Wilczek B, Aspelin P, Bone B, et al. Complementary use of scintimammography with 99m-Tc-MIBI to triple diagnostic procedure in palpable and non-palpable breast lesions. Acta Radiol. May. 2003;44(3):288-93. [pmid: 12752000].
89 Krishnaiah G, Sher-Ahmed A, Ugwu-Dike M, et al. Technetium-99m sestamibi scintimammography complements mammography in the detection of breast cancer. Breast J. 2003;9(4):288-94. [pmid: 12846862].
90 Obwegeser R, Berghammer P, Rodrigues M, et al. A head-to-head comparison between technetium-99m-tetrofosmin and technetium-99m-MIBI scintigraphy to evaluate suspicious breast lesions. Eur J Nucl Med. Dec. 1999;26(12):1553-9. [pmid: 10638406].
91 Koukouraki S, Koukourakis MI, Vagios E, et al. The role of 99m Tc-sestamibi scintimammography and colour Doppler ultrasonography in the evaluation of breast lesions. Nucl Med Commun. Nov. 2001;22(11):1243-8. [pmid: 11606891].
92 Schillaci O, Scopinaro F, Danieli R, et al. 99Tcm-sestamibi scintimammography in patients with suspicious breast lesions: comparison of SPET and planar images in the detection of primary tumours and axillary lymph node involvement. Nucl Med Commun. Sep. 1997;18(9):839-45. [pmid: 9352550].
93 Villanueva-Meyer J, Leonard MH Jr, Briscoe E, et al. Mammoscintigraphy with technetium-99m-sestamibi in suspected breast cancer. J Nucl Med. Jun. 1996;37(6):926-30. [pmid: 8683313].
94 Chen SL, Yin YQ, Chen JX, et al. The usefulness of technetium-99m-MIBI scintimammography in diagnosis of breast cancer: using surgical histopathologic diagnosis as the gold standard. Anticancer Res. 1997;17(3B):1695-8. [pmid: 9179221].
95 Tiling R, Sommer H, Pechmann M, et al. Comparison of technetium-99m-sestamibi scintimammography with contrast- enhanced MRI for diagnosis of breast lesions. J Nucl Med. Jan. 1997;38(1):58-62. [pmid: 8998151].
96 Palmedo H, Grunwald F, Bender H, et al. Scintimammography with technetium-99m methoxyisobutylisonitrile: comparison with mammography and magnetic resonance imaging. Eur J Nucl Med. Aug. 1996;23(8):940-6. [pmid: 8753683].
97 Leidenius MH, Leppanen EA, Tykka HT, et al. The role of Tc99m-sestamibi scintimammography in combination with the triple assessment of primary breast cancer. Eur J Surg Oncol. Mar. 2002;28(2):108-12. [pmid: 11884044].
98 Imbriaco M, Del Vecchio S, Riccardi A, et al. Scintimammography with 99mTc-MIBI versus dynamic MRI for non-invasive characterization of breast masses. Eur J Nucl Med. Jan. 2001;28(1):56-63. [pmid: 11202453].
99 Papantoniou V, Christodoulidou J, Papadaki E, et al. 99mTc-(V)DMSA scintimammography in the assessment of breast lesions: comparative study with 99mTc-MIBI. Eur J Nucl Med. Jul. 2001;28(7):923-8. [pmid: 11504092].
100 Sanidas EE, Koukouraki S, Velidaki A, et al. Contribution of 99mTc-anti-carcinoembryonic antigen antibody and 99mTc-sestamibi scintimammography in the evaluation of high risk palpable breast lesions. Nucl Med Commun. Mar. 2003;24(3):291-6. [pmid: 12612470].
101 Gutfilen B, Fonseca LM. Comparison of Tc-99m THY and Tc-99m MIBI scans for diagnosis of breast lesions. J Exp Clin Cancer Res. Sep. 2001;20(3):385-91. [pmid: 11718219].
102 Yuen-Green M, Wasnich R, Caindec-Ranchez S, et al. New method for breast cancer detection using TC-99m sestamibi scintimammography. Hawaii Med J. Feb. 1996;55(2):26-8. [pmid: 8820628].
103 Alonso O, Massardo T, Delgado LB, et al. Is (99m)Tc-sestamibi scintimammography complementary to conventional mammography for detecting breast cancer in patients with palpable masses. J Nucl Med. Nov. 2001;42(11):1614-21. [pmid: 11696629].
104 Ambrus E, Rajtar M, Ormandi K, et al. Value of 99m-Tc MIBI and 99m-Tc(V) DMSA scintigraphy in evaluation of breast mass lesions. Anticancer Res. 1997;17(3B):1599-605. [pmid: 9179201].
105 Burak Z, Argon M, Memis A, et al. Evaluation of palpable breast masses with 99Tcm-MIBI: a comparative study with mammography and ultrasonography. Nucl Med Commun. Aug. 1994;15(8):604-12. [pmid: 7970442].
106 Palmedo H, Schomburg A, Grunwald F, et al. Scintimammography with Tc-99m MIBI in patients with suspicion of primary breast cancer. Nucl Med Biol. Aug. 1996;23(6):681-4. [pmid: 8940710].
107 Palmedo H, Schomburg A, Grunwald F, et al. Technetium-99m-MIBI scintimammography for suspicious breast lesions. J Nucl Med. Apr. 1996;37(4):626-30. [pmid: 8691253].
108 Chen S, Liu W, Mao Y, et al. 99 mTc-MIBI and 99 mTc-MDP scintimammography for detecting breast carcinoma. Chin Med J. 2000;113(5):400-3. [pmid: 11776092].
109 Carril JM, Gomez-Barquin R, Quirce R, et al. Contribution of 99mTc-MIBI scintimammography to the diagnosis of non- palpable breast lesions in relation to mammographic probability of malignancy. Anticancer Res. 1997;17(3B):1677-81. [pmid: 9179217].
110 Aguilar J, Andres B, Nicolas F, et al. Value of 99mTc-MIBI scintimammography in women with impalpable breast lesions seen on mammography. Eur J Surg. May. 2001;167(5):344-6. [pmid: 11419548].
111 Bekis R. 99mTc sestamibi scintimammography. Screening mammographic non-palpable suspicious breast lesions: preliminary results. Nucl Med (Stuttg). Feb. 2004;43(1):16-20.
112 Maffioli L, Agresti R, Chiti A, et al. Prone scintimammography in patients with non-palpable breast lesions. Anticancer Res. 1996;16(3A):1269-73. [pmid: 8702249].
113 Fondrinier E, Muratet JP, Anglade E, et al. Clinical experience with 99mTc-MIBI scintimammography in patients with breast microcalcifications. Breast. Aug. 2004;13(4):316-20. [pmid: 15325666].
114 Spanu A, Schillaci O, Meloni GB, et al. The usefulness of 99mTc-tetrofosmin SPECT scintimammography in the detection of small size primary breast carcinomas. Int J Oncol. Oct. 2002;21(4):831-40. [pmid: 12239623].
115 Khalkhali I, Vargas HI. The role of nuclear medicine in breast cancer detection: functional breast imaging. Radiol Clin North Am. Sep. 2001;39(5):1053-68. [pmid: 11587058].
116 Khalkhali I, Caravaglia G, Abdel-Nabi HH, et al. Society of Nuclear Medicine procedure guideline for breast scintigraphy. version 2.0. Reston (VA): Society of Nuclear Medicine; 2004 Jun 2. 4 p. Also available: http://interactive.snm.org/docs/Breast_v2.0.pdf.
117 Coover LR, Caravaglia G, Kuhn P. Scintimammography with dedicated breast camera detects and localizes occult carcinoma. J Nucl Med. Apr. 2004;45(4):553-8. [pmid: 15073249].
118 Yildiz A, Colak T, Gungor F, et al. Diagnostic value of 99mTc MIBI scintimammography in patients with breast lesions. Rev Esp Med Nucl. Jun. 2001;20(4):276-81. [pmid: 11440709].
119 Bombardieri E, Crippa F, Baio SM, et al. Nuclear medicine advances in breast cancer imaging. Tumori. 2001;87(5):277-87. [pmid: 11765174].
120 Clarke EA, Notghi A, Harding LK. Can reduced imaging times be used for scintimammography. Nucl Med Commun. Oct. 1999;20(10):883-6. [pmid: 10528291].
121 Edell SL, Eisen MD. Current imaging modalities for the diagnosis of breast cancer. Del Med J. Sep. 1999;71(9):377-82. [pmid: 10584437].
122 Zegel H, Heller L, Edell S, et al. Tc-99m sestamibi scintimammography in the mammographically dense breast. Clin Nucl Med. Dec. 1999;24(12):968-74. [pmid: 10595479].
123 Monticciolo DL. How useful are new radiographic tools for detecting breast cancer. Postgrad Med. Mar. 2004;115(3):76-7. [pmid: 15038257].
124 Thomson LE, Allman KC. Erythema multiforme reaction to sestamibi. J Nucl Med. Mar. 2001;42(3):534. [pmid: 11337537].
125 Hesslewood SR, Keeling DH. Frequency of adverse reactions to radiopharmaceuticals in Europe. Eur J Nucl Med. Sep. 1997;24(9):1179-82. [pmid: 9283115].
126 Silberstein EB, Ryan J. Prevalence of adverse reactions in nuclear medicine. Pharmacopeia Committee of the Society of Nuclear Medicine. J Nucl Med. Jan. 1996;37(1):185-92. [pmid: 8543992].
127 Klaus AJ, Klingensmith WC 3rd, Parker SH, et al. Comparative value of 99mTc-sestamibi scintimammography and sonography in the diagnostic workup of breast masses. AJR Am J Roentgenol. Jun. 2000;174(6):1779-83. [pmid: 10845522].
128 Blue Cross Blue Shield Association (BCBS). Breast MRI for detection or diagnosis of primary or recurrent breast cancer. Chicago (IL): Blue Cross Blue Shield Association; 2004 Apr. 88 p. (TEC Assessment Program; vol. 19, no. 1). Also available: http://www.mrw.interscience.wiley.com/cochrane/clhta/articles/HTA-20040234/frame.html.
129 Hrung JM, Sonnad SS, Schwartz JS, et al. Accuracy of MR imaging in the work-up of suspicious breast lesions: a diagnostic meta-analysis (Structured abstract). Acad Radiol. 1999;6(7):387-97. [pmid: 10410164].
130 Bluemke DA, Gatsonis CA, Chen MH, et al. Magnetic resonance imaging of the breast prior to biopsy. JAMA. Dec 8. 2004;292(22):2735-42. [pmid: 15585733].
131 Heiberg EV, Perman WH, Herrmann VM, et al. Dynamic sequential 3D gadolinium-enhanced MRI of the whole breast. Magn Reson Imaging. 1996;14(4):337-48. [pmid: 8782170].
132 Obdeijn IM, Kuijpers TJ, van Dijk P, et al. MR lesion detection in a breast cancer population. J Magn Reson Imaging. 1996;6(6):849-54. [pmid: 8956127].
133 Hachiya J, Seki T, Okada M, et al. MR imaging of the breast with Gd-DTPA enhancement: comparison with mammography and ultrasonography. Radiat Med. 1991;9(6):232-40. [pmid: 1668410].
134 Cecil KM, Schnall MD, Siegelman ES, et al. The evaluation of human breast lesions with magnetic resonance imaging and proton magnetic resonance spectroscopy. Breast Cancer Res Treat. Jul. 2001;68(1):45-54. [pmid: 11678308].
135 Del Maschio A, Bazzocchi M, Giuseppetti GM, et al. Breast MRI: report on a multicentric national trial by the Study Section of Magnetic Resonance and Breast Imaging. Radiol Med (Torino). Oct. 2002;104(4):262-72. [pmid: 12569307].
136 Nakahara H, Namba K, Fukami A, et al. Three-dimensional MR imaging of mammographically detected suspicious microcalcifications. Breast Cancer. 2001;8(2):116-24. [pmid: 11342984].
137 Malich A, Boehm T, Facius M, et al. Differentiation of mammographically suspicious lesions: evaluation of breast ultrasound, MRI mammography and electrical impedance scanning as adjunctive technologies in breast cancer detection. Clin Radiol. Apr. 2001;56(4):278-83. [pmid: 11286578].
138 Knopp MV, Bourne MW, Sardanelli F, et al. Gadobenate dimeglumine-enhanced MRI of the breast: analysis of dose response and comparison with gadopentetate dimeglumine. AJR Am J Roentgenol. Sep. 2003;181(3):663-76. [pmid: 12933457].
139 Huang W, Fisher PR, Dulaimy K, et al. Detection of breast malignancy: diagnostic MR protocol for improved specificity. Radiology. Aug. 2004;232(2):585-91. [pmid: 15205478].
140 Magnetic resonance imaging systems. Health Devices 2005 Apr 1;34(4):117–38
141 Paakko E, Reinikainen H, Lindholm EL, et al. Low-field versus high-field MRI in diagnosing breast disorders. Eur Radiol. Jul. 2005;15(7):1361-8. [pmid: 15711841].
142 Yen YF, Han KF, Daniel BL, et al. Dynamic breast MRI with spiral trajectories: 3D versus 2D. J Magn Reson Imaging. 2000;11(4):351-9. [pmid: 10767063].
143 Sardanelli F, Rescinito G, Giordano GD, et al. MR dynamic enhancement of breast lesions: high temporal resolution during the first-minute versus eight-minute study. J Comput Assist Tomogr. 2000;24(5):724-31. [pmid: 11045693].
144 Sardanelli F, Lozzelli A, Fausto A. MR imaging of the breast: indications, established technique, and new directions. Eur Radiol 2003 Nov;13 Suppl 3(N28–36.
145 Orel SG, Schnall MD. MR imaging of the breast for the detection, diagnosis, and staging of breast cancer. Radiology. Jul. 2001;220(1):13-30. [pmid: 11425968].
146 Lee CH. Problem solving MR imaging of the breast. Radiol Clin North Am. Sep. 2004;42(5):919-34. [pmid: 15337425].
147 Szabo BK, Aspelin P, Wiberg MK, et al. Dynamic MR imaging of the breast. Analysis of kinetic and morphologic diagnostic criteria. Acta Radiol. Jul. 2003;44(4):379-86. [pmid: 12846687].
148 Kuhl CK, Klaschik S, Mielcarek P, et al. Do T2-weighted pulse sequences help with the differential diagnosis of enhancing lesions in dynamic breast MRI?. J Magn Reson Imaging. Feb. 1999;9(2):187-96. [pmid: 10077012].
149 Schnall MD, Rosten S, Englander S, et al. A combined architectural and kinetic interpretation model for breast MR images. Acad Radiol. Jul. 2001;8(7):591-7. [pmid: 11450959].
150 Agoston AT, Daniel BL, Herfkens RJ, et al. Intensity-modulated parametric mapping for simultaneous display of rapid dynamic and high-spatial-resolution breast MR imaging data. Radiographics. 2001;21(1):217-26. [pmid: 11158656].
151 American College of Radiology (ACR). ACR Breast Imaging and Reporting Data System, Breast Imaging Atlas. Reston (VA): American College of Radiology (ACR); 2003. ACR BI-RADS - Magnetic Resonance Imaging.
152 Helbich TH. Contrast-enhanced magnetic resonance imaging of the breast. Eur J Radiol. Jun. 2000;34(3):208-19. [pmid: 10927162].
153 Artemov D, Revelon G, Atalar E, et al. Switchable multicoil array for MR micro-imaging of breast lesions. Magn Reson Med. Mar. 1999;41(3):569-74. [pmid: 10204882].
154 Shen GX, Wu J, Boada FE. Multiple channel phased arrays for echo planar imaging. MAGMA. Dec. 2000;11(3):138-43. [pmid: 11154955].
155 Friedman PD, Swaminathan SV, Smith R. SENSE imaging of the breast. AJR Am J Roentgenol. Feb. 2005;184(2):448-51. [pmid: 15671362].
156 Morris EA. Breast cancer imaging with MRI. Radiol Clin North Am. May. 2002;40(3):443-66. [pmid: 12117186].
157 Orel SG. MR imaging of the breast. Radiol Clin North Am. Jul. 2000;38(4):899-913. [pmid: 10943285].
158 Sardanelli F, Iozzelli A, Fausto A. Contrast agents and temporal resolution in breast MR imaging. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):69-75. [pmid: 12585658].
159 National Cancer Data Base (NCDB) [database online]. Chicago (IL): American College of Surgeons (ACS); 1996‐1998 [cited 1999 Mar 5]. Relative survival of breast cancer patients by AJCC stage of disease at diagnosis, 1985-1990 cases [table]. [3 p]. Available: http://www.facs.org/about_college/acsdept/cancer_dept/programs/ncdb/breastcancer4.html.
160 Coulthard A, Potterton AJ. Pitfalls of breast MRI. Br J Radiol. Jun. 2000;73(870):665-71. [pmid: 10911793].
161 Kuhl CK, Schild HH. Dynamic image interpretation of MRI of the breast. J Magn Reson Imaging. Dec. 2000;12(6):965-74. [pmid: 11105038].
162 Chen W, Giger ML, Lan L, et al. Computerized interpretation of breast MRI: investigation of enhancement-variance dynamics. Med Phys. May. 2004;31(5):1076-82. [pmid: 15191295].
163 Partridge SC, Heumann EJ, Hylton NM. Semi-automated analysis for MRI of breast tumors. Stud Health Technol Inform. 1999;62:259-60. [pmid: 10538368].
164 Szabo BK, Wiberg MK, Bone B, et al. Application of artificial neural networks to the analysis of dynamic MR imaging features of the breast. Eur Radiol. Jul. 2004;14(7):1217-25. [pmid: 15034745].
165 Kelcz F, Furman-Haran E, Grobgeld D, et al. Clinical testing of high-spatial-resolution parametric contrast-enhanced MR imaging of the breast. AJR Am J Roentgenol. Dec. 2002;179(6):1485-92. [pmid: 12438042].
166 Liney GP, Gibbs P, Hayes C, et al. Dynamic contrast-enhanced MRI in the differentiation of breast tumors: user‐defined versus semi-automated region-of-interest analysis. J Magn Reson Imaging. Dec. 1999;10(6):945-9. [pmid: 10581507].
167 Heywang-Kobrunner SH, Bick U, Bradley WG Jr, et al. International investigation of breast MRI: results of a multicentre study (11 sites) concerning diagnostic parameters for contrast-enhanced MRI based on 519 histopathologically correlated lesions. Eur Radiol. 2001;11(4):531-46. [pmid: 11354744].
168 Heywang-Kobrunner SH, Heinig A, Pickuth D, et al. Interventional MRI of the breast: lesion localisation and biopsy. Eur Radiol. 2000;10(1):36-45. [pmid: 10663716].
169 Schedel H. Magnetic Resonance Female Breast Imaging (MRFBI) - Evaluation of the Changes in Signal Intensity over Time Pre- and Post-administration of 0.2 mmol/kg Gd-DTPA. Zentralbl Gynakol. Feb. 2002;124(2):104-10. [pmid: 11935495].
170 Morris EA. Review of breast MRI: indications and limitations. Semin Roentgenol. Jul. 2001;36(3):226-37. [pmid: 11475069].
171 Rieber A, Nussle K, Merkle E, et al. MR mammography: influence of menstrual cycle on the dynamic contrast enhancement of fibrocystic disease. Eur Radiol. 1999;9(6):1107-12. [pmid: 10415244].
172 Runge VM. Safety of approved MR contrast media for intravenous injection. J Magn Reson Imaging. Aug 1. 2000;12(2):205-13. [pmid: 10931582].
173 Medical magnetic resonance (MR) procedures: protection of patients. Health Phys 2004 Aug;87(2):197–216.
174 Shellock FG. Radiofrequency energy-induced heating during MR procedures: a review. J Magn Reson Imaging. Jul. 2000;12(1):30-6. [pmid: 10931562].
175 Fiek M, Remp T, Reithmann C, et al. Complete loss of ICD programmability after magnetic resonance imaging. Pacing Clin Electrophysiol. Jul. 2004;27(7):1002-4. [pmid: 15271024].
176 Shellock FG. Magnetic resonance safety update 2002: implants and devices. J Magn Reson Imaging. Nov. 2002;16(5):485-96. [pmid: 12412025].
177 Foster JR, Hall DA, Summerfield AQ, et al. Sound-level measurements and calculations of safe noise dosage during EPI at 3 T. J Magn Reson Imaging. Jul. 2000;12(1):157-63. [pmid: 10931575].
178 Dempsey MF, Condon B, Hadley DM. Investigation of the factors responsible for burns during MRI. J Magn Reson Imaging. Apr. 2001;13(4):627-31. [pmid: 11276109].
179 Shellock FG, Crues JV. MR procedures: biologic effects, safety, and patient care. Radiology. Sep. 2004;232(3):635-52. [pmid: 15284433].
180 Shellock FG. Biomedical implants and devices: Assessment of magnetic field interactions with a 3.0-Tesla MR system. J Magn Reson Imaging. Dec. 2002;16(6):721-32. [pmid: 12451586].
181 Feychting M. Health effects of static magnetic fields--a review of the epidemiological evidence. Prog Biophys Mol Biol. 2005;87(23):241-6. [pmid: 15556662].
182 Hong CZ, Shellock FG. Short-term exposure to a 1.5 tesla static magnetic field does not affect somato-sensory-evoked potentials in man. Magn Reson Imaging. 1990;8(1):65-9. [pmid: 2325519].
183 Shellock FG, Schaefer DJ, Gordon CJ. Effect of a 1.5 T static magnetic field on body temperature of man. Magn Reson Med. Aug. 1986;3(4):644-7. [pmid: 3747826].
184 Budinger TF. Nuclear magnetic resonance (NMR) in vivo studies: known thresholds for health effects. J Comput Assist Tomogr. Dec. 1981;5(6):800-11. [pmid: 7033311].
185 Brice J. Experts put MRI accreditation program to the test. Diagn Imaging 2001 Jul;23(7):44–7, 49.
186 Skaane P. Ultrasonography as adjunct to mammography in the evaluation of breast tumors. Acta Radiol Suppl. 1999;420:7-47.
187 Flobbe K. Costs and effects of ultrasonography in the evaluation of palpable breast masses. Int J Technol Assess Health Care. Fall. 2004;20(4):440-8. [pmid: 15609793].
188 Flobbe K, Bosch AM, Kessels AG, et al. The additional diagnostic value of ultrasonography in the diagnosis of breast cancer. Arch Intern Med. May 26. 2003;163(10):1194-9. [pmid: 12767956].
189 Meyberg-Solomayer GC, Kraemer B, Bergmann A, et al. Does 3-D sonography bring any advantage to noninvasive breast diagnostics. Ultrasound Med Biol. May. 2004;30(5):583-9. [pmid: 15183222].
190 Chao TC, Lo YF, Chen SC, et al. Prospective sonographic study of 3093 breast tumors. J Ultrasound Med. May. 1999;18(5):363-70. [pmid: 10327015].
191 Chen SC, Cheung YC, Su CH, et al. Analysis of sonographic features for the differentiation of benign and malignant breast tumors of different sizes. Ultrasound Obstet Gynecol. Feb. 2004;23(2):188-93. [pmid: 14770402].
192 Perre CI, Koot VC, de Hooge P, et al. The value of ultrasound in the evaluation of palpable breast tumours: a prospective study of 400 cases. Eur J Surg Oncol. Dec. 1994;20(6):637-40. [pmid: 7995413].
193 van Oord JC. The value of ultrasound mammography in palpable breast masses. Rofo. Jul. 1991;155(1):63-6. [pmid: 1854938].
194 McNicholas MM, Mercer PM, Miller JC, et al. Color Doppler sonography in the evaluation of palpable breast masses. AJR Am J Roentgenol. Oct. 1993;161(4):765-71. [pmid: 8372754].
195 American Institute of Ultrasound in Medicine. AIUM standard for the performance of breast ultrasound examination. Laurel (MD): American Institute of Ultrasound in Medicine; 2002. 6 p. Also available: http://www.aium.org/publications/clinical/breast.pdf.
196 American College of Radiology. Breast ultrasound accreditation program requirements. Reston (VA): American College of Radiology; 2005. 9 p. Also available: http://www.acr.org/s_acr/bin.asp?CID=591&DID=12137&DOC=FILE.PDF.
197 Watson L. The role of ultrasound in breast imaging. Radiol Technol. 2000;71(5):441-59. quiz 460–2. [pmid: 10840855].
198 Baker JA, Soo MS, Rosen EL. Artifacts and pitfalls in sonographic imaging of the breast. AJR Am J Roentgenol. May. 2001;176(5):1261-6. [pmid: 11312192].
199 Drukker K, Giger ML, Horsch K, et al. Computerized lesion detection on breast ultrasound. Med Phys. Jul. 2002;29(7):1438-46. [pmid: 12148724].
200 Baker JA, Kornguth PJ, Soo MS, et al. Sonography of solid breast lesions: observer variability of lesion description and assessment. AJR Am J Roentgenol. Jun. 1999;172(6):1621-5. [pmid: 10350302].
201 Weinstein SP, Conant EF, Mies C, et al. Posterior acoustic shadowing in benign breast lesions: sonographic-pathologic correlation. J Ultrasound Med. Jan. 2004;23(1):73-83. [pmid: 14756356].
202 Rahbar G, Sie AC, Hansen GC, et al. Benign versus malignant solid breast masses: US differentiation. Radiology. Dec. 1999;213(3):889-94. [pmid: 10580971].
203 Murad M, Bari V. Ultrasound differentiation of benign versus malignant solid breast masses. J Coll Physicians Surg Pak. Mar. 2004;14(3):166-9. [pmid: 15228851].
204 Skaane P, Engedal K, Skjennald A. Interobserver variation in the interpretation of breast imaging. Comparison of mammography, ultrasonography, and both combined in the interpretation of palpable noncalcified breast masses. Acta Radiol. Jul. 1997;38(4 Pt 1):497-502. [pmid: 9240666].
205 Bosch AM, Kessels AG, Beets GL, et al. Interexamination variation of whole breast ultrasound. Br J Radiol. May. 2003;76(905):328-31. [pmid: 12763948].
206 Shimamoto K, Sawaki A, Ikede M, et al. Interobserver agreement in sonographic diagnosis of breast tumors. Eur J Ultrasound. Sep. 1998;8(1):25-31. [pmid: 9795006].
207 Smith AP, Hall PA, Marcello DM. Emerging technologies in breast cancer detection. Radiol Manage. 2004;26(4):16-24. quiz 25–7. [pmid: 15377106].
208 Siegmann KC, Muller-Schimpfle M, Schick F, et al. MR imaging-detected breast lesions: histopathologic correlation of lesion characteristics and signal intensity data. AJR Am J Roentgenol. Jun. 2002;178(6):1403-9. [pmid: 12034606].
209 Boonjunwetwat D, Prathombutr A. Imaging of benign papillary neoplasm of the breast: mammographic, galactographic and sonographic findings. J Med Assoc Thai. Aug. 2000;83(8):832-8. [pmid: 10998834].
210 Adler LP, Crowe JP, al-Kaisi NK, et al. Evaluation of breast masses and axillary lymph nodes with [F-18] 2-deoxy-2-fluoro-D-glucose PET. Radiology. Jun. 1993;187(3):743-50. [pmid: 8497624].
211 Avril N, Bense S, Ziegler SI, et al. Breast imaging with fluorine-18-FDG PET: quantitative image analysis. J Nucl Med. Aug. 1997;38(8):1186-91. [pmid: 9255146].
212 Avril N, Dose J, Janicke F, et al. Metabolic characterization of breast tumors with positron emission tomography using F-18 fluorodeoxyglucose. J Clin Oncol. Jun. 1996;14(6):1848-57. [pmid: 8656253].
213 Avril N, Rose CA, Schelling M, et al. Breast imaging with positron emission tomography and fluorine-18 fluorodeoxyglucose: use and limitations. J Clin Oncol. Oct 15. 2000;18(20):3495-502. [pmid: 11032590].
214 Buck A, Schirrmeister H, Kuhn T, et al. FDG uptake in breast cancer: correlation with biological and clinical prognostic parameters. Eur J Nucl Med Mol Imaging. Oct. 2002;29(10):1317-23. [pmid: 12271413].
215 Danforth DN Jr, Aloj L, Carrasquillo JA, et al. The role of 18F-FDG-PET in the local/regional evaluation of women with breast cancer. Breast Cancer Res Treat. Sep. 2002;75(2):135-46. [pmid: 12243506].
216 Fujiwara T, Miyake M, Watanuki S, et al. Easy detection of tumor in oncologic whole-body PET by projection reconstruction images with maximum intensity projection algorithm. Ann Nucl Med. Jun. 1999;13(3):199-203. [pmid: 10435383].
217 Inoue T, Yutani K, Taguchi T, et al. Preoperative evaluation of prognosis in breast cancer patients by [(18)F]2-Deoxy-2-fluoro-D-glucose-positron emission tomography. J Cancer Res Clin Oncol. May. 2004;130(5):273-8. [pmid: 14986112].
218 Murthy K, Aznar M, Thompson CJ, et al. Results of preliminary clinical trials of the positron emission mammography system PEM-I: a dedicated breast imaging system producing glucose metabolic images using FDG. J Nucl Med. Nov. 2000;41(11):1851-8. [pmid: 11079494].
219 Nieweg OE, Wong WH, Singletary SE, et al. Positron emission tomography of glucose metabolism in breast cancer. Potential for tumor detection, staging, and evaluation of chemotherapy. Ann N Y Acad Sci. Nov 30. 1993;698:423-8. [pmid: 8279782].
220 Noh DY, Yun IJ, Kim JS, et al. Diagnostic value of positron emission tomography for detecting breast cancer. World J Surg. Mar. 1998;22(3):223-7. discussion 227–8. [pmid: 9494412].
221 Pietrzyk U, Scheidhauer K, Scharl A, et al. Presurgical visualization of primary breast carcinoma with PET emission and transmission imaging. J Nucl Med. Oct. 1995;36(10):1882-4. [pmid: 7562059].
222 Scheidhauer K, Scharl A, Pietrzyk U, et al. Qualitative [18F]FDG positron emission tomography in primary breast cancer: clinical relevance and practicability. Eur J Nucl Med. Jun. 1996;23(6):618-23. [pmid: 8662094].
223 Smyczek-Gargya B. PET with [18F]fluorothymidine for imaging of primary breast cancer: a pilot study. Eur J Nucl Med Mol Imaging. May. 2004;31(5):720-4. [pmid: 14991243].
224 Arslan N, Ozturk E, Ilgan S, et al. 99Tcm-MIBI scintimammography in the evaluation of breast lesions and axillary involvement: a comparison with mammography and histopathological diagnosis. Nucl Med Commun. Apr. 1999;20(4):317-25. [pmid: 10319351].
225 Aziz A, Hashmi R, Ogawa Y, et al. Tc-99m-MIBI scintimammography; SPECT versus planar imaging. Cancer Biother Radiopharm. Dec. 1999;14(6):495-500. [pmid: 10850336].
226 Becherer A, Helbich T, Staudenherz A, et al. The diagnostic value of planar and SPET scintimammography in different age groups. Nucl Med Commun. Aug. 1997;18(8):710-8. [pmid: 9293501].
227 Buscombe JR, Cwikla JB, Holloway B, et al. Prediction of the usefulness of combined mammography and scintimammography in suspected primary breast cancer using ROC curves. J Nucl Med. Jan. 2001;42(1):3-8. [pmid: 11197976].
228 Buscombe JR, Cwikla JB, Thakrar DS, et al. Uptake of Tc-99m MIBI related to tumour size and type. Anticancer Res. 1997;17(3B):1693-4. [pmid: 9179220].
229 Clifford EJ, Lugo-Zamudio C. Scintimammography in the diagnosis of breast cancer. Am J Surg. Nov. 1996;172(5):483-6. [pmid: 8942549].
230 Cwikla JB, Buscombe JR, Kelleher SM, et al. Comparison of accuracy of scintimammography and X-ray mammography in the diagnosis of primary breast cancer in patients selected for surgical biopsy. Clin Radiol. Apr. 1998;53(4):274-80. [pmid: 9585043].
231 Danielsson R, Sanchez-Crespo A, Pegerfalk A, et al. 99mTc-sestamibi uptake and histological malignancy grade in invasive breast carcinoma. Eur J Nucl Med Mol Imaging. May. 2003;30(5):662-6. [pmid: 12616323].
232 Dunnwald LK, Hartnett SD, Mankoff DA. Utility and reproducibility of semiquantitative analysis of sestamibi breast images. J Nucl Med Technol. Jun. 1997;25(2):106-9. [pmid: 9239613].
233 Farias-Jimenez J, Rivera A, Carlo VM. Technetium-99m sestamibi in the diagnosis of breast cancer. The Mayaguez Medical Center experience. Bol Asoc Med P R. 2001;93(112):9-11. [pmid: 12755069].
234 Fleming RM. Mitochondrial uptake of sestamibi distinguishes between normal, inflammatory breast changes, pre‐cancers, and infiltrating breast cancer. Integr Cancer Ther. Sep. 2002;1(3):229-37. [pmid: 14667281].
235 Fleming RM, Dooley WC. Breast enhanced scintigraphy testing distinguishes between normal, inflammatory breast changes, and breast cancer: a prospective analysis and comparison with mammography. Integr Cancer Ther. Sep. 2002;1(3):238-45. [pmid: 14667282].
236 Horne T, Pappo I, Cohenpour M, et al. 99Tcm-MIBI scintimammography for the detection of breast malignancies: the contribution of the count ratio to specificity. Nucl Med Commun. Jun. 1999;20(6):511-6. [pmid: 10451862].
237 Horne T, Pappo I, Cohen-Pour M, et al. 99Tc(m)-tetrofosmin scintimammography for detecting breast cancer: a comparative study with 99Tc(m)-MIBI. Nucl Med Commun. Jul. 2001;22(7):807-11. [pmid: 11453054].
238 Howarth D, Sillar R, Lan L, et al. Scintimammography: an adjunctive test for the detection of breast cancer. Med J Aust. Jun 21. 1999;170(12):588-91. [pmid: 10416428].
239 Howarth D, Sillar R, Clark D, et al. Technetium-99m sestamibi scintimammography: the influence of histopathological characteristics, lesion size and the presence of carcinoma in situ in the detection of breast carcinoma. Eur J Nucl Med. Nov. 1999;26(11):1475-81. [pmid: 10552090].
240 Iraniha S, Khalkhali II, Cutrone JA, et al. Breast Cancer Imaging: Can Tc-99m Sestamibi Scintimammography Fit In?. Medscape Womens Health. Apr. 1997;2(4):2. [pmid: 9746689].
241 Khalkhali I, Cutrone JA, Mena IG, et al. Scintimammography: the complementary role of Tc-99m sestamibi prone breast imaging for the diagnosis of breast carcinoma. Radiology. Aug. 1995;196(2):421-6. [pmid: 7617855].
242 Khalkhali I, Cutrone J, Mena I, et al. Technetium-99m-sestamibi scintimammography of breast lesions: clinical and pathological follow-up. J Nucl Med. Oct. 1995;36(10):1784-9. [pmid: 7562043].
243 Khalkhali I, Mena I, Jouanne E, et al. Prone scintimammography in patients with suspicion of carcinoma of the breast. J Am Coll Surg. May. 1994;178(5):491-7. [pmid: 8167887].
244 Khalkhali I, Iraniha S, Cutrone JA, et al. Scintimammography with Tc-99m sestamibi. Acta Med Austriaca. 1997;24(2):46-9. [pmid: 9227786].
245 Kim SJ. Incremental diagnostic value of quantitative analysis of double phase Tc-99m MIBI scintimammography for the detection of primary breast cancer additive to visual analysis. Breast Cancer Res Treat. Jan. 2004;83(2):129-38. [pmid: 14997043].
246 Lumachi F, Marzola MC, Zucchetta P, et al. Breast cancer detection with 99m-Tc-sestamibi scintigraphy, mammography, and fine-needle aspiration cytology: comparative study in 64 surgically treated patients. Ann Surg Oncol. Sep. 1999;6(6):568-71. [pmid: 10493625].
247 Lumachi F, Ferretti G, Povolato M, et al. Accuracy of technetium-99m sestamibi scintimammography and X-ray mammography in premenopausal women with suspected breast cancer. Eur J Nucl Med. Dec. 2001;28(12):1776-80. [pmid: 11734915].
248 Lumachi F, Ferretti G, Povolato M, et al. Sestamibi scintimammography in pT1 breast cancer: alternative or complementary to X-ray mammography. Anticancer Res. 2001;21(3C):2201-5. [pmid: 11501847].
249 Lumachi F, Zucchetta P, Marzola MC, et al. Positive predictive value of 99mTc sestamibi scintimammography in patients with non-palpable, mammographically detected, suspicious, breast lesions. Nucl Med Commun. Nov 1. 2002;23(11):1073-8. [pmid: 12411835].
250 Lumachi F, Ferretti G, Povolato M, et al. Usefulness of 99m-Tc-sestamibi scintimammography in suspected breast cancer and in axillary lymph node metastases detection. Eur J Surg Oncol. Apr. 2001;27(3):256-9. [pmid: 11373101].
251 Massardo T, Alonso O, Kabasakal L, et al. Diagnostic value of 99mTc-methylene diphosphonate and 99mTc-pentavalent DMSA compared with 99mTc-sestamibi for palpable breast lesions. J Nucl Med. Jul. 2002;43(7):882-8. [pmid: 12097457].
252 Maurer AH, Caroline DF, Jadali FJ, et al. Limitations of craniocaudal thallium-201 and technetium-99m-sestamibi mammoscintigraphy. J Nucl Med. Sep. 1995;36(9):1696-700. [pmid: 7658233].
253 Myslivecek M, Koranda P, Kaminek M, et al. Technetium-99m-MIBI scintimammography by planar and SPECT imaging in the diagnosis of breast carcinoma and axillary lymph node involvement. Nucl Med Rev. 2004;7(2):151-5.
254 Nishiyama Y, Yamamoto Y, Ono Y, et al. Comparative evaluation of 99mTc-MIBI and 99mTc-HMDP scintimammography for the diagnosis of breast cancer and its axillary metastases. Eur J Nucl Med. Apr. 2001;28(4):522-8. [pmid: 11357504].
255 Palmedo H, Biersack HJ, Lastoria S, et al. Scintimammography with technetium-99m methoxyisobutylisonitrile: results of a prospective European multicentre trial. Eur J Nucl Med. Apr. 1998;25(4):375-85. [pmid: 9553167].
256 Papantoniou V, Christodoulidou J, Papadaki E, et al. Uptake and washout of 99mTcV-dimercaptosuccinic acid and 99mTc-sestamibi in the assessment of histological type and grade in breast cancer. Nucl Med Commun. May. 2002;23(5):461-7. [pmid: 11973487].
257 Polan RL, Klein BD, Richman RH. Scintimammography in patients with minimal mammographic or clinical findings. Radiographics. 2001;21(3):641-53. discussion 653–5. [pmid: 11353112].
258 Prats E, Aisa F, Abos MD, et al. Mammography and 99mTc-MIBI scintimammography in suspected breast cancer. J Nucl Med. Feb. 1999;40(2):296-301. [pmid: 10025838].
259 Ren C, Jin S, Zhou Q, et al. Clinical significance of 99mTc-MIBI breast imaging in the diagnosis of early breast cancer. Asian J Surg. Apr. 2002;25(2):126-9. [pmid: 12376231].
260 Sampalis FS, Denis R, Picard D, et al. International prospective evaluation of scintimammography with technetium-99m sestamibi: interim results. Am J Surg. Oct. 2001;182(4):399-403. [pmid: 11720679].
261 Scopinaro F, Pani R, De Vincentis G, et al. High-resolution scintimammography improves the accuracy of technetium-99m methoxyisobutylisonitrile scintimammography: use of a new dedicated gamma camera. Eur J Nucl Med. Oct. 1999;26(10):1279-88. [pmid: 10541826].
262 Sillar R, Howarth D, Clark D. The initial Australian experience of technetium-99M sestamibi scintimammography: a complementary test in the management of breast cancer. Aust N Z J Surg. Jul. 1997;67(7):433-7. [pmid: 9236609].
263 Taillefer R. Technetium-99m-sestamibi prone scintimammography to detect primary breast cancer and axillary lymph node involvement. J Nucl Med. Oct. 1995;36(10):1758-65. [pmid: 7562039].
264 Tiling R, Tatsch K, Sommer H, et al. Technetium-99m-sestamibi scintimammography for the detection of breast carcinoma: comparison between planar and SPECT imaging. J Nucl Med. May. 1998;39(5):849-56. [pmid: 9591588].
265 Tiling R, Kessler M, Untch M, et al. Initial evaluation of breast cancer using Tc-99m sestamibi scintimammography. Eur J Radiol. 2005;53(2):206-12. [pmid: 15664284].
266 Tolmos J, Cutrone JA, Wang B, et al. Scintimammographic analysis of nonpalpable breast lesions previously identified by conventional mammography. J Natl Cancer Inst. Jun 3. 1998;90(11):846-9. [pmid: 9625173].
267 Vargas HI, Agbunag RV, Kalinowski A, et al. The clinical utility of Tc-99m sestamibi scintimammography in detecting multicentric breast cancer. Am Surg. Dec. 2001;67(12):1204-8. [pmid: 11768831].
268 Barbacioru C, Arunachalam A, Cowden D, et al. Pharmacokinetic mapping of breast tumors: a new statistical analysis technique for dynamic magnetic resonance imaging. AMIA Symposium Proceedings 2003;783.
269 Baum E, Fischer U, Vosshenrich R, et al. Classification of hypervascularized lesions in CE MR imaging of the breast. Eur Radiol. May 1. 2002;12(5):1087-92. [pmid: 11976850].
270 Baum F, Fischer U, Vosshenrich R, et al. Classification of hypervascularized lesions in CE MR imaging of the breast. Eur Radiol. May. 2002;12(5):1087-92. [pmid: 11976850].
271 Meriggi F. Surgical therapy of colorectal metastases - state of the art. Rom J Gastroenterol. 2004;13(3):233-5. [pmid: 15470537].
272 Bone B, Szabo BK, Perbeck LG, et al. Can contrast-enhanced MR imaging predict survival in breast cancer. Acta Radiol. Jul. 2003;44(4):373-8. [pmid: 12846686].
273 Carriero A, Di Credico A, Mansour M, et al. Maximum intensity projection analysis in magnetic resonance of the breast. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):77-81. [pmid: 12585659].
274 Choi BG, Kim HH, Kim EN, et al. New subtraction algorithms for evaluation of lesions on dynamic contrast-enhanced MR mammography. Eur Radiol. Dec. 2002;12(12):3018-22. [pmid: 12439585].
275 Fenlon HM, Phelan NC, O'Sullivan P, et al. Benign versus malignant breast disease: comparison of contrast-enhanced MR imaging and Tc-99m tetrofosmin scintimammography. Radiology. Oct. 1997;205(1):214-20. [pmid: 9314988].
276 Furman B, Gardner MS, Romilly P, et al. Effect of 0.5 Tesla magnetic resonance imaging on the surgical management of breast cancer patients. Am J Surg. Oct. 2003;186(4):344-7. [pmid: 14553847].
277 Gibbs P. Differentiation of benign and malignant sub-1 cm breast lesions using dynamic contrast enhanced MRI. Breast. Apr. 2004;13(2):115-21. [pmid: 15019691].
278 German Agency for Health Technology Assessment. Assessment of magnetic resonance imaging in diagnostics of breast carcinoma - systematic review. Koln: German Agency for Health Technology Assessment at the German Institute for Medical Documentation and Information (DAHTA) (DIMDI); 1998. Also available: http://www.mrw.interscience.wiley.com/cochrane/clhta/articles/HTA-999821/frame.html.
279 Guo Y, Cai YQ, Cai ZL, et al. Differentiation of clinically benign and malignant breast lesions using diffusion-weighted imaging. J Magn Reson Imaging. Aug. 2002;16(2):172-8. [pmid: 12203765].
280 Jacobs MA, Barker PB, Bottomley PA, et al. Proton magnetic resonance spectroscopic imaging of human breast cancer: a preliminary study. J Magn Reson Imaging. Jan. 2004;19(1):68-75. [pmid: 14696222].
281 Jacobs MA. Benign and malignant breast lesions: diagnosis with multiparametric MR imaging. Radiology. Oct. 2003;229(1):225-32. [pmid: 14519877].
282 Kaiser W. MRI of the female breast. First clinical results. Arch Int Physiol Biochim. Dec. 1985;93(5):67-76. [pmid: 2424392].
283 Khatri VP, Stuppino JJ, Espinosa MH, et al. Improved accuracy in differentiating malignant from benign mammographic abnormalities: a simple, improved magnetic resonance imaging method. Cancer. Aug 1. 2001;92(3):471-8. [pmid: 11505390].
284 Kim SJ, Morris EA, Liberman L, et al. Observer variability and applicability of BI-RADS terminology for breast MR imaging: invasive carcinomas as focal masses. AJR Am J Roentgenol. Sep. 2001;177(3):551-7. [pmid: 11517046].
285 Kramer S, Schulz-Wendtland R, Hagedorn K, et al. Magnetic resonance imaging and its role in the diagnosis of multicentric breast cancer. Anticancer Res. 1998;18(3C):2163-4. [pmid: 9703777].
286 Lee SG, Orel SG, Woo IJ, et al. MR imaging screening of the contralateral breast in patients with newly diagnosed breast cancer: preliminary results. Radiology. Mar. 2003;226(3):773-8. [pmid: 12601182].
287 Lucht RE, Knopp MV, Brix G. Classification of signal-time curves from dynamic MR mammography by neural networks. Magn Reson Imaging. Jan. 2001;19(1):51-7. [pmid: 11295347].
288 Nagashima T, Suzuki M, Yagata H, et al. Dynamic-enhanced MRI predicts metastatic potential of invasive ductal breast cancer. Breast Cancer. 2002;9(3):226-30. [pmid: 12185334].
289 Nakahara H, Namba K, Wakamatsu H, et al. Extension of breast cancer: comparison of CT and MRI. Radiat Med. 2002;20(1):17-23. [pmid: 12002599].
290 Obenauer S, Schorn C, Stelter B, et al. Contrast-enhanced high in-plane resolution dynamic MRI of the breast. Are there advantages in comparison to standard dynamic MRI?. Clin Imaging. 2002;26(3):161-5. [pmid: 11983466].
291 Reinikainen H, Paakko E, Suramo I, et al. Dynamics of contrast enhancement in MR imaging and power Doppler ultrasonography of solid breast lesions. Acta Radiol. Sep. 2002;43(5):492-500. [pmid: 12423460].
292 Rigauts H, Casselman J, Steyaert L, et al. Contribution of MRI and color Doppler sonography in breast cancer diagnosis. J Belge Radiol. Aug. 1993;76(4):226-31. [pmid: 8294376].
293 Schelfout K, Van Goethem M, Kersschot E, et al. Contrast-enhanced MR imaging of breast lesions and effect on treatment. Eur J Surg Oncol. Jun. 2004;30(5):501-7. [pmid: 15135477].
294 Schelfout K, Van Goethem M, Kersschot E, et al. Preoperative breast MRI in patients with invasive lobular breast cancer. Eur Radiol. Jul. 2004;14(7):1209-16. [pmid: 15024602].
295 Shahar KH, Solaiyappan M, Bluemke DA. Quantitative differentiation of breast lesions based on three-dimensional morphology from magnetic resonance imaging. J Comput Assist Tomogr. 2002;26(6):1047-53. [pmid: 12488759].
296 Slanetz PJ, Edmister WB, Yeh ED, et al. Occult contralateral breast carcinoma incidentally detected by breast magnetic resonance imaging. Breast J. 2002;8(3):145-8. [pmid: 12047470].
297 Szabo BK, Aspelin P, Kristoffersen Wiberg M, et al. Invasive breast cancer: correlation of dynamic MR features with prognostic factors. Eur Radiol. Nov. 2003;13(11):2425-35. [pmid: 12898176].
298 Teifke A, Hlawatsch A, Beier T, et al. Undetected malignancies of the breast: dynamic contrast-enhanced MR imaging at 1.0 T. Radiology. Sep. 2002;224(3):881-8. [pmid: 12202728].
299 Trecate G, Tess JD, Vergnaghi D, et al. Breast microcalcifications studied with 3D contrast-enhanced high-field magnetic resonance imaging: more accuracy in the diagnosis of breast cancer. Tumori. 2002;88(3):224-33. [pmid: 12195761].
300 Tuncbilek N, Unlu E, Karakas HM, et al. Evaluation of tumor angiogenesis with contrast-enhanced dynamic magnetic resonance mammography. Breast J. 2003;9(5):403-8. [pmid: 12968962].
301 Van Goethem M, Schelfout K, Dijckmans L, et al. MR mammography in the pre-operative staging of breast cancer in patients with dense breast tissue: comparison with mammography and ultrasound. Eur Radiol. May. 2004;14(5):809-16. [pmid: 14615904].
302 Wedegartner U, Bick U, Wortler K, et al. Differentiation between benign and malignant findings on MR-mammography: usefulness of morphological criteria. Eur Radiol. 2001;11(9):1645-50. [pmid: 11511885].
303 Louie L, Velez N, Earnest D, et al. Management of nonpalpable ultrasound-indeterminate breast lesions. Surgery. Oct. 2003;134(4):667-73. discussion 673–4. [pmid: 14605628].
304 Kristoffersen Wiberg M, Aspelin P, Sylvan M, et al. Comparison of lesion size estimated by dynamic MR imaging, mammography and histopathology in breast neoplasms. Eur Radiol. Jun. 2003;13(6):1207-12. [pmid: 12764634].
305 Yeh ED, Slanetz PJ, Edmister WB, et al. Invasive lobular carcinoma: spectrum of enhancement and morphology on magnetic resonance imaging. Breast J. 2003;9(1):13-8. [pmid: 12558665].
306 Zuiani C, Francescutti GE, Londero V, et al. Ductal carcinoma in situ: is there a role for MRI. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):89-95. [pmid: 12585661].
307 Allen SA, Cunliffe WJ, Gray J, et al. Pre-operative estimation of primary breast cancer size: a comparison of clinical assessment, mammography and ultrasound. Breast. 2001;10(4):299-305. [pmid: 14965598].
308 Arger PH, Sehgal CM, Conant EF, et al. Interreader variability and predictive value of US descriptions of solid breast masses: pilot study. Acad Radiol. Apr. 2001;8(4):335-42. [pmid: 11293782].
309 Baker JA, Soo MS. Breast US: assessment of technical quality and image interpretation. Radiology. Apr. 2002;223(1):229-38. [pmid: 11930071].
310 Beeckman P, De Clerck S, Jong B, et al. The ultrasound aspect of the skin and subcutaneous fat layer in various benign and malignant breast conditions. J Belge Radiol. 1991;74(4):283-8. [pmid: 1797793].
311 Bhatti PT, LeCarpentier GL, Roubidoux MA, et al. Discrimination of sonographically detected breast masses using frequency shift color Doppler imaging in combination with age and gray scale criteria. J Ultrasound Med. Apr. 2001;20(4):343-50. [pmid: 11316312].
312 Bosch AM, Kessels AG, Beets GL, et al. Preoperative estimation of the pathological breast tumour size by physical examination, mammography and ultrasound: a prospective study on 105 invasive tumours. Eur J Radiol. Dec. 2003;48(3):285-92. [pmid: 14652148].
313 Butler RS, Venta LA, Wiley EL, et al. Sonographic evaluation of infiltrating lobular carcinoma. AJR Am J Roentgenol. Feb. 1999;172(2):325-30. [pmid: 9930776].
314 Britton PD, Coulden RA. The use of duplex Doppler ultrasound in the diagnosis of breast cancer. Clin Radiol. Dec. 1990;42(6):399-401. [pmid: 2175686].
315 Buadu LD, Murakami J, Murayama S, et al. Colour Doppler sonography of breast masses: a multiparameter analysis. Clin Radiol. 1997;52:917-23. [pmid: 9413965].
316 Carson PL, Moskalik AP, Govil A, et al. The 3D and 2D color flow display of breast masses. Ultrasound Med Biol. 1997;23(6):837-49. [pmid: 9300987].
317 Kawashima M, Tamaki Y, Nonaka T, et al. MR imaging of mucinous carcinoma of the breast. AJR Am J Roentgenol. Jul. 2002;179(1):179-83. [pmid: 12076930].
318 Chandawarkar RY, Shinde SR. Preoperative diagnosis of carcinoma of the breast: is a "cost-cutter" algorithm tenable?. J Surg Oncol. Feb. 1997;64(2):153-8. [pmid: 9047254].
319 Chao TC, Lo YF, Chen SC, et al. Color Doppler ultrasound in benign and malignant breast tumors. Breast Cancer Res Treat. Sep. 1999;57(2):193-9. [pmid: 10598046].
320 Chen DR, Jeng LB, Kao A, et al. Comparing thallium-201 spect mammoscintigraphy and ultrasonography to detect breast cancer in mammographical dense breasts. Neoplasma. 2003;50(3):222-6. [pmid: 12937857].
321 Chen DR, Chang RF, Kuo WJ, et al. Diagnosis of breast tumors with sonographic texture analysis using wavelet transform and neural networks. Ultrasound Med Biol. Oct. 2002;28(10):1301-10. [pmid: 12467857].
322 Chen WM, Chang RF, Moon WK, et al. Breast cancer diagnosis using three-dimensional ultrasound and pixel relation analysis. Ultrasound Med Biol. Jul. 2003;29(7):1027-35. [pmid: 12878249].
323 Choi HY, Kim HY, Baek SY, et al. Significance of resistive index in color Doppler ultrasonogram: differentiation between benign and malignant breast masses. Clin Imaging. 1999;23(5):284-8. [pmid: 10665344].
324 Ciatto S, Rosselli del Turco M, Catarzi S, et al. The contribution of ultrasonography to the differential diagnosis of breast cancer. Neoplasma. 1994;41(6):341-5. [pmid: 7870218].
325 Cilotti A, Bagnolesi P, Moretti M, et al. Comparison of the diagnostic performance of high-frequency ultrasound as a first- or second-line diagnostic tool in non-palpable lesions of the breast. Eur Radiol. 1997;7(8):1240-4. [pmid: 9377509].
326 Cimitan M, Volpe R, Candiani E, et al. The use of thallium-201 in the preoperative detection of breast cancer: an adjunct to mammography and ultrasonography. Eur J Nucl Med. Oct. 1995;22(10):1110-7. [pmid: 8542893].
327 Cosgrove DO, Kedar RP, Bamber JC, et al. Breast diseases: color Doppler US in differential diagnosis. Radiology. Oct. 1993;189(1):99-104. [pmid: 8372225].
328 Cosmacini P, Veronesi P, Galimberti V, et al. Ultrasonographic evaluation of palpable breast masses: analysis of 134 cases. Tumori. Oct 31. 1990;76(5):495-8. [pmid: 2256197].
329 Debniak B, Debniak T, Breborowicz GH, et al. The usefulness of Doppler angiography in differential diagnosis of benign and malignant breast lesions. Int J Fertil Womens Med. 2004;49(3):138-43. [pmid: 15303315].
330 Delorme S, Zuna I, Huber S, et al. Colour Doppler sonography in breast tumours: an update. Eur Radiol. 1998;8(2):189-93. [pmid: 9477264].
331 Dixon JM, Walsh J, Paterson D, et al. Colour Doppler ultrasonography studies of benign and malignant breast lesions. Br J Surg. Mar. 1992;79(3):259-60. [pmid: 1555096].
332 Dock W. Duplex sonography of mammary tumors: a prospective study of 75 patients. J Ultrasound Med. Feb. 1993;12(2):79-82. [pmid: 8468740].
333 Drukker K, Giger ML, Mendelson EB. Computerized analysis of shadowing on breast ultrasound for improved lesion detection. Med Phys. Jul. 2003;30(7):1833-42. [pmid: 12906202].
334 Edde DJ. Whole-breast compression ultrasonography with the patient in the sitting position. Can Assoc Radiol J. Aug. 1994;45(4):324-6. [pmid: 8062127].
335 Staren ED. Surgical office-based ultrasound of the breast. Am Surg. Jul. 1995;61(7):619-26. discussion 627. [pmid: 7793744].
336 Eltahir A, Jibril JA, Squair J, et al. The accuracy of ‘one-stop’ diagnosis for 1,110 patients presenting to a symptomatic breast clinic. J R Coll Surg Edinb. Aug. 1999;44(4):226-30. [pmid: 10453144].
337 Finlay ME, Liston JE, Lunt LG, et al. Assessment of the role of ultrasound in the differentiation of radial scars and stellate carcinomas of the breast. Clin Radiol. Jan. 1994;49(1):52-5. [pmid: 8299333].
338 Forsberg F, Goldberg BB, Merritt CR, et al. Diagnosing breast lesions with contrast-enhanced 3-dimensional power Doppler imaging. J Ultrasound Med. Feb. 2004;23(2):173-82. [pmid: 14992354].
339 Foxcroft LM, Evans EB, Porter AJ. The diagnosis of breast cancer in women younger than 40. Breast. Aug. 2004;13(4):297-306. [pmid: 15325664].
340 Fung HM, Jackson FI. Clinically and mammographically occult breast lesions demonstrated by ultrasound. J R Soc Med. Nov. 1990;83(11):696-8. [pmid: 2250265]. [pmcid: 1292915].
341 Garra BS, Krasner BH, Horii SC, et al. Improving the distinction between benign and malignant breast lesions: the value of sonographic texture analysis. Ultrason Imaging. Oct. 1993;15(4):267-85. [pmid: 8171752].
342 Gefen S, Tretiak OJ, Piccoli CW, et al. ROC analysis of ultrasound tissue characterization classifiers for breast cancer diagnosis. IEEE Trans Med Imaging. Feb. 2003;22(2):170-7. [pmid: 12715993].
343 Germer U, Tetzlaff A, Geipel A, et al. Strong impact of estrogen environment on Doppler variables used for differentiation between benign and malignant breast lesions. Ultrasound Obstet Gynecol. Apr. 2002;19(4):380-5. [pmid: 11952968].
344 Giuseppetti GM, Baldassarre S, Marconi E. Color Doppler sonography. Eur J Radiol. May. 1998;27(Suppl 2):S254-8. [pmid: 9652531].
345 Golshan M, Fung BB, Wolfman J, et al. The effect of ipsilateral whole breast ultrasonography on the surgical management of breast carcinoma. Am J Surg. Oct. 2003;186(4):391-6. [pmid: 14553857].
346 Golub RM. Differentiation of breast tumors by ultrasonic tissue characterization. J Ultrasound Med. Oct. 1993;12(10):601-8. [pmid: 8246339].
347 Graf O, Helbich TH, Fuchsjaeger MH, et al. Follow-up of palpable circumscribed noncalcified solid breast masses at mammography and US: can biopsy be averted?. Radiology. Dec. 2004;233(3):850-6. [pmid: 15486217].
348 Hieken TJ, Harrison J, Herreros J, et al. Correlating sonography, mammography, and pathology in the assessment of breast cancer size. Am J Surg. Oct. 2001;182(4):351-4. [pmid: 11720669].
349 Hieken TJ, Velasco JM. A prospective analysis of office-based breast ultrasound. Arch Surg. May. 1998;133(5):504-7. discussion 507–8. [pmid: 9605912].
350 Hollerweger A, Rettenbacher T, Macheiner P, et al. New signs of breast cancer: high resistance flow and variations in resistive indices evaluation by color Doppler sonography. Ultrasound Med Biol. 1997;23(6):851-6. [pmid: 9300988].
351 Houssami N, Irwig L, Simpson JM, et al. Sydney Breast Imaging Accuracy Study: Comparative sensitivity and specificity of mammography and sonography in young women with symptoms. AJR Am J Roentgenol. Apr. 2003;180(4):935-40. [pmid: 12646432].
352 Huang CS, Wu CY, Chu JS, et al. Microcalcifications of non-palpable breast lesions detected by ultrasonography: correlation with mammography and histopathology. Ultrasound Obstet Gynecol. Jun. 1999;13(6):431-6. [pmid: 10423808].
353 Huber S, Helbich T, Kettenbach J, et al. Effects of a microbubble contrast agent on breast tumors: computer-assisted quantitative assessment with color Doppler US--early experience. Radiology. Aug. 1998;208(2):485-9. [pmid: 9680580].
354 Huber S, Delorme S, Knopp MV, et al. Breast tumors: computer-assisted quantitative assessment with color Doppler US. Radiology. Sep. 1994;192(3):797-801. [pmid: 8058950].
355 Jackson VP, Kelly-Fry E, Rothschild PA, et al. Automated breast sonography using a 7.5-MHz PVDF transducer: preliminary clinical evaluation. Work in progress. Radiology. 1986;159(3):679-84. [pmid: 3517952].
356 Joo S, Yang YS, Moon WK, et al. Computer-aided diagnosis of solid breast nodules: use of an artificial neural network based on multiple sonographic features. IEEE Trans Med Imaging. Oct. 2004;23(10):1292-300. [pmid: 15493696].
357 Kaiser JS, Helvie MA, Blacklaw RL, et al. Palpable breast thickening: role of mammography and US in cancer detection. Radiology. Jun. 2002;223(3):839-44. [pmid: 12034957].
358 Kaplan SS. Clinical utility of bilateral whole-breast US in the evaluation of women with dense breast tissue. Radiology. Dec. 2001;221(3):641-9. [pmid: 11719658].
359 Kedar RP, Cosgrove DO, Bamber JC, et al. Automated quantification of color Doppler signals: a preliminary study in breast tumors. Radiology. Oct. 1995;197(1):39-43. [pmid: 7568851].
360 Kimme-Smith C, Bassett LW, Gold RH. High frequency breast ultrasound. Hand-held versus automated units; examination for palpable mass versus screening. J Ultrasound Med. 1988;7(2):77-81. [pmid: 3279228].
361 Kolb TM, Lichy J, Newhouse JH. Comparison of the performance of screening mammography, physical examination, and breast US and evaluation of factors that influence them: an analysis of 27,825 patient evaluations. Radiology. Oct. 2002;225(1):165-75. [pmid: 12355001].
362 Kolb TM, Lichy J, Newhouse JH. Occult cancer in women with dense breasts: detection with screening US--diagnostic yield and tumor characteristics. Radiology. Apr. 1998;207(1):191-9. [pmid: 9530316].
363 Ultrasound detects missed cancers. Biomed Instrum Technol 1997;31(3):217–8.
364 Kook SH, Kwag HJ. Value of contrast-enhanced power Doppler sonography using a microbubble echo-enhancing agent in evaluation of small breast lesions. J Clin Ultrasound. Jun. 2003;31(5):227-38. [pmid: 12767017].
365 Kook SH, Park HW, Lee YR, et al. Evaluation of solid breast lesions with power Doppler sonography. J Clin Ultrasound. Jun. 1999;27(5):231-7. [pmid: 10355886].
366 Krestan CR, Riedl C, Memarsadeghi M, et al. 3D-power Doppler ultrasound of breast lesions with a microbubble contrast agent. Acad Radiol. Aug. 2002;9(Suppl 2):S384-5. [pmid: 12188284].
367 Kuijpers TJ, Obdeijn AI, Kruyt RH, et al. Solid breast neoplasms: differential diagnosis with pulsed Doppler ultrasound. Ultrasound Med Biol. 1994;20(6):517-20. [pmid: 7998372].
368 Lam WW, Chu WC, Tse GM, et al. Sonographic appearance of mucinous carcinoma of the breast. AJR Am J Roentgenol. Apr. 2004;182(4):1069-74. [pmid: 15039190].
369 Leconte I, Feger C, Galant C, et al. Mammography and subsequent whole-breast sonography of nonpalpable breast cancers: the importance of radiologic breast density. AJR Am J Roentgenol. Jun. 2003;180(6):1675-9. [pmid: 12760942].
370 Lee SK, Lee T, Lee KR, et al. Evaluation of breast tumors with color Doppler imaging: a comparison with image-directed Doppler ultrasound. J Clin Ultrasound. 1995;23(6):367-73. [pmid: 7673453].
371 Lee WJ, Chu JS, Huang CS, et al. Breast cancer vascularity: color Doppler sonography and histopathology study. Breast Cancer Res Treat. 1996;37(3):291-8. [pmid: 8825140].
372 Leung JW, Kornguth PJ, Gotway MB. Utility of targeted sonography in the evaluation of focal breast pain. J Ultrasound Med. May. 2002;21(5):521-6. [pmid: 12008815].
373 Lister D, Evans AJ, Burrell HC, et al. The accuracy of breast ultrasound in the evaluation of clinically benign discrete, symptomatic breast lumps. Clin Radiol. Jul. 1998;53(7):490-2. [pmid: 9714387].
374 Nunes LW, Englander SA, Charafeddine R, et al. Optimal post-contrast timing of breast MR image acquisition for architectural feature analysis. J Magn Reson Imaging. Jul. 2002;16(1):42-50. [pmid: 12112502].
375 Madjar H, Prompeler HJ, Sauerbrei W, et al. Differential diagnosis of breast lesions by color Doppler. Ultrasound Obstet Gynecol. Sep. 1995;6(3):199-204. [pmid: 8521070].
376 Madjar H, Sauerbrei W, Prompeler HJ, et al. Color Doppler and duplex flow analysis for classification of breast lesions. Gynecol Oncol. Mar. 1997;64(3):392-403. [pmid: 9062140].
377 Madjar H, Prompeler HJ, Sauerbrei W, et al. Color Doppler flow criteria of breast lesions. Ultrasound Med Biol. 1994;20(9):849-58. [pmid: 7886845].
378 Madjar H, Sauerbrei W, Munch S, et al. Continuous-wave and pulsed Doppler studies of the breast: clinical results and effect of transducer frequency. Ultrasound Med Biol. 1991;17(1):31-9. [pmid: 2021009].
379 Madjar H, Prompeler HJ, Del Favero C, et al. A new Doppler signal enhancing agent for flow assessment in breast lesions. Eur J Ultrasound. Dec. 2000;12(2):123-30. [pmid: 11118919].
380 Marini C, Traino C, Cilotti A, et al. Differentiation of benign and malignant breast microcalcifications: mammography versus mammography-sonography combination. Radiol Med (Torino). 2003;105(12):17-26. [pmid: 12700541].
381 Martinez AM, Medina CJ, Bustos C, et al. Assessment of breast lesions using Doppler with contrast agents. Eur J Gynaecol Oncol. 2003;24(6):527-30. [pmid: 14658595].
382 Medl M, Peters-Engl C, Leodolter S. The use of color-coded Doppler sonography in the diagnosis of breast cancer. Anticancer Res. 1994;14(5B):2249-51. [pmid: 7840531].
383 Mesaki K, Hisa N, Kubota K, et al. Differentiation of benign and malignant breast tumors using Doppler spectral parameters including acceleration time index. Oncol Rep (Athens). 2003;10(4):945-50.
384 Milz P, Lienemann A, Kessler M, et al. Evaluation of breast lesions by power Doppler sonography. Eur Radiol. 2001;11(4):547-54. [pmid: 11354745].
385 Moss HA, Britton PD, Flower CDR, et al. How reliable is modern breast imaging in differentiating benign from malignant breast lesions in the symptomatic population?. Clin Radiol. 1999;54(10):676-82. [pmid: 10541394].
386 Obwegeser R, Berghammer P, Kubista E. Ultrasound-imaging of lateral thoracic arteries to detect breast cancer. Lancet. Jun 5. 1999;353(9168):1938. [pmid: 10371578].
387 Ohlinger R, Klein GM, Kohler G. Ultrasound of the breast - value of sonographic criteria for the differential diagnosis of solid lesions. Ultraschall Med. Feb. 2004;25(1):48-53. [pmid: 14961424].
388 Ozdemir A, Kilic K, Ozdemir H, et al. Contrast-enhanced power doppler sonography in breast lesions: effect on differential diagnosis after mammography and gray scale sonography. J Ultrasound Med. 2004;23(2):183-96. [pmid: 14992355].
389 Zdemir A, Kilic K, Ozdemir H, et al. Contrast-enhanced power Doppler sonography in breast lesions: effect on differential diagnosis after mammography and gray scale sonography. J Ultrasound Med. Feb. 2004;23(2):183-95. quiz 196–7. [pmid: 14992355].
390 Ozdemir A, Ozdemir H, Maral I, et al. Differential diagnosis of solid breast lesions: contribution of Doppler studies to mammography and gray scale imaging. J Ultrasound Med. Oct. 2001;20(10):1091-101. quiz 1102. [pmid: 11587016].
391 Ozdemir A, Oznur II, Vural G, et al. Tl-201 scintigraphy, mammography and ultrasonography in the evaluation of palpable and nonpalpable breast lesions: a correlative study. Eur J Radiol. Feb. 1997;24(2):145-54. [pmid: 9097057].
392 Pamilo M, Soiva M, Anttinen I, et al. Ultrasonography of breast lesions detected in mammography screening. Acta Radiol. May. 1991;32(3):220-5. [pmid: 2064866].
393 Park JM, Yoon GS, Kim SM, et al. Sonographic detection of multifocality in breast carcinoma. J Clin Ultrasound. 2003;31(6):293-8. [pmid: 12811787].
394 Peters-Engl C, Medl M, Mirau M, et al. Color-coded and spectral Doppler flow in breast carcinomas--relationship with the tumor microvasculature. Breast Cancer Res Treat. Jan. 1998;47(1):83-9. [pmid: 9493979].
395 Peters-Engl C, Medl M, Leodolter S. The use of colour-coded and spectral Doppler ultrasound in the differentiation of benign and malignant breast lesions. Br J Cancer. Jan. 1995;71(1):137-9. [pmid: 7819029].
396 Pillsbury SG Jr, Haugen JA, Roux S. Reliability of multimodal evaluation of abnormal screening mammogram results. Am J Obstet Gynecol. Jun. 1996;174(6):1683-6. discussion 1686–7. [pmid: 8678127].
397 Pinero A, Reus M, Illana J, et al. Palpable breast lesions: utility of Doppler sonography for diagnosis of malignancy. Breast. Aug. 2003;12(4):258-63. [pmid: 14659310].
398 Pritt B, Ashikaga T, Oppenheimer RG, et al. Influence of breast cancer histology on the relationship between ultrasound and pathology tumor size measurements. Mod Pathol. Aug. 2004;17(8):905-10. [pmid: 15105809].
399 Puglisi F, Zuiani C, Bazzocchi M, et al. Role of mammography, ultrasound and large core biopsy in the diagnostic evaluation of papillary breast lesions. Oncology. 2003;65(4):311-5. [pmid: 14707450].
400 Ramlau C, Sledzikowski J. Combination of thermographic and ultrasound methods for the diagnosis of female breast cancer. Eur J Gynaecol Oncol. 1993;14 Suppl:152-4. [pmid: 8200367].
401 Ranieri E, D'Andrea MR, D'Alessio A, et al. Ultrasound in the detection of breast cancer associated with isolated clustered microcalcifications, mammographically identified. Anticancer Res. 1997;17(4A):2831-5. [pmid: 9252725].
402 Raza S, Baum JK. Solid breast lesions: evaluation with power Doppler US. Radiology. Apr. 1997;203(1):164-8. [pmid: 9122386].
403 Reinikainen H, Rissanen T, Paivansalo M, et al. B-mode, power Doppler and contrast-enhanced power Doppler ultrasonography in the diagnosis of breast tumors. Acta Radiol. Jan. 2001;42(1):106-13. [pmid: 11167342].
404 Richter K. Clinical amplitude/velocity reconstructive imaging (CARI)--a new sonographic method for detecting breast lesions. Br J Radiol. Apr. 1995;68(808):375-84. [pmid: 7795973].
405 Richter K. Detection of diffuse breast cancers with a new sonographic method. J Clin Ultrasound. May. 1996;24(4):157-68. [pmid: 8727413].
406 Richter K, Heywang-Kobrunner SH. Sonographic differentiation of benign from malignant breast lesions: value of indirect measurement of ultrasound velocity. AJR Am J Roentgenol. Oct. 1995;165(4):825-31. [pmid: 7676975].
407 Richter K, Heywang-Kobrunner SH. Quantitative parameters measured by a new sonographic method for differentiation of benign and malignant breast disease. Invest Radiol. Jul. 1995;30(7):401-11. [pmid: 7591649].
408 Richter K, Heywang-Kobrunner SH, Winzer KJ, et al. Detection of malignant and benign breast lesions with an automated US system: results in 120 cases. Radiology. Dec. 1997;205(3):823-30. [pmid: 9393543].
409 Rosen EL, Soo MS. Tissue harmonic imaging sonography of breast lesions: improved margin analysis, conspicuity, and image quality compared to conventional ultrasound. Clin Imaging. 2001;25(6):379-84. [pmid: 11733148].
410 Rubin E, Mennemeyer ST, Desmond RA, et al. Reducing the cost of diagnosis of breast carcinoma: impact of ultrasound and imaging-guided biopsies on a clinical breast practice (Structured abstract). Cancer. 2001;91(2):324-32. [pmid: 11180078].
411 Saarenmaa I, Salminen T, Geiger U, et al. The effect of age and density of the breast on the sensitivity of breast cancer diagnostic by mammography and ultasonography. Breast Cancer Res Treat. May. 2001;67(2):117-23. [pmid: 11519860].
412 Sahin-Akyar G, Sumer H. Color Doppler ultrasound and spectral analysis of tumor vessels in the differential diagnosis of solid breast masses. Invest Radiol. Feb. 1996;31(2):72-9. [pmid: 8750441].
413 Saitoh R, Kojima R, Ito K, et al. Real-time high resolution ultrasonography of solid breast masses: use of a 10‐MHz mechanical sector transducer with a water bag. Radiat Med. 1994;12(5):201-8. [pmid: 7863023].
414 Schelling M, Gnirs J, Braun M, et al. Optimized differential diagnosis of breast lesions by combined B-mode and color Doppler sonography. Ultrasound Obstet Gynecol. Jul. 1997;10(1):48-53. [pmid: 9263423].
415 Schroeder RJ, Maeurer J, Vogl TJ, et al. D-galactose-based signal-enhanced color Doppler sonography of breast tumors and tumorlike lesions. Invest Radiol. Feb. 1999;34(2):109-15. [pmid: 9951790].
416 Schutze B, Marx C, Fleck M, et al. Diagnostic evaluation of sonographically visualized breast lesions by using a new clinical amplitude/velocity reference imaging technique (CARI sonography). Invest Radiol. Jun. 1998;33(6):341-7. [pmid: 9647446].
417 Sehgal CM, Cary TW, Kangas SA, et al. Computer-based margin analysis of breast sonography for differentiating malignant and benign masses. J Ultrasound Med. Sep. 2004;23(9):1201-9. [pmid: 15328435].
418 Selinko VL, Middleton LP, Dempsey PJ. Role of sonography in diagnosing and staging invasive lobular carcinoma. J Clin Ultrasound. Sep. 2004;32(7):323-32. [pmid: 15293298].
419 Seo BK, Oh YW, Kim HR, et al. Sonographic evaluation of breast nodules: comparison of conventional, real-time compound, and pulse-inversion harmonic images. Korean J Radiol. 2002;3(1):38-44. [pmid: 11919477].
420 Shetty MK, Shah YP, Sharman RS. Prospective evaluation of the value of combined mammographic and sonographic assessment in patients with palpable abnormalities of the breast. J Ultrasound Med. Mar. 2003;22(3):263-8. [pmid: 12636326].
421 Skaane P. The additional value of US to mammography in the diagnosis of breast cancer. A prospective study. Acta Radiol. Sep. 1999;40(5):486-90. [pmid: 10485236].
422 Skaane P, Sauer T. Ultrasonography of malignant breast neoplasms. Analysis of carcinomas missed as tumor. Acta Radiol. Jul. 1999;40(4):376-82. [pmid: 10394864].
423 Skaane P, Skjorten F. Ultrasonographic evaluation of invasive lobular carcinoma. Acta Radiol. Jul. 1999;40(4):369-75. [pmid: 10394863].
424 Skaane P, Olsen JB, Sager EM, et al. Variability in the interpretation of ultrasonography in patients with palpable noncalcified breast tumors. Acta Radiol. Mar. 1999;40(2):169-75. [pmid: 10080729].
425 Snelling JD, Abdullah N, Brown G, et al. Measurement of tumour size in case selection for breast cancer therapy by clinical assessment and ultrasound. Eur J Surg Oncol. Feb. 2004;30(1):5-9. [pmid: 14736515].
426 Spreafico C, Lanocita R, Frigerio LF, et al. The Italian experience with SH U 508 A (Levovist) in breast disease. Radiol Med (Torino). May. 1994;87(5 Suppl 1):59-64. [pmid: 8209019].
427 Stavros AT, Thickman D, Rapp CL, et al. Solid breast nodules: use of sonography to distinguish between benign and malignant lesions. Radiology. Jul. 1995;196(1):123-34. [pmid: 7784555].
428 Steinberg BD, Carlson DL, Birnbaum JA. Sonographic discrimination between benign and malignant breast lesions with use of disparity processing. Acad Radiol. Aug. 2001;8(8):705-12. [pmid: 11508749].
429 Szopinski KT, Pajk AM, Wysocki M, et al. Tissue harmonic imaging: utility in breast sonography. J Ultrasound Med. May. 2003;22(5):479-87. [pmid: 12751859].
430 Tavassoli K, Cavalla P, Porcelli A, et al. Ultrasound diagnostic criteria in breast disease. Panminerva Med. Sep. 1997;39(3):178-82. [pmid: 9360418].
431 Taylor KJ, Merritt C, Piccoli C, et al. Ultrasound as a complement to mammography and breast examination to characterize breast masses. Ultrasound Med Biol. Jan. 2002;28(1):19-26. [pmid: 11879948].
432 Tohnosu N, Okuyama K, Koide Y, et al. A comparison between ultrasonography and mammography, computed tomography and digital subtraction angiography for the detection of breast cancers. Surg Today. 1993;23(8):704-10. [pmid: 8400674].
433 Vetto JT, Pommier RF, Schmidt WA, et al. Diagnosis of palpable breast lesions in younger women by the modified triple test is accurate and cost-effective (Structured abstract). Arch Surg. 1996;131(9):967-72. [pmid: 8790167].
434 Wang HC, Chen DR, Kao CH, et al. Detecting breast cancer in mammographically dense breasts: comparing technetium-99m tetrofosmin mammoscintigraphy and ultrasonography. Cancer Invest. 2002;20(78):932-8. [pmid: 12449724].
435 Whitehouse PA, Baber Y, Brown G, et al. The use of ultrasound by breast surgeons in outpatients: an accurate extension of clinical diagnosis. Eur J Surg Oncol. Nov. 2001;27(7):611-6. [pmid: 11669586].
436 Whitehouse PA, Barber Y, Brown G, et al. Office ultrasound by breast surgeons: a rapid, accurate adjuct to clinical diagnosis. Breast Cancer Res Treat. 2001;69(3):237.
437 Wilkens TH, Burke BJ, Cancelada DA, et al. Evaluation of palpable breast masses with color Doppler sonography and gray scale imaging. J Ultrasound Med. Feb. 1998;17(2):109-15. [pmid: 9527570].
438 Wright IA, Pugh ND, Lyons K, et al. Power Doppler in breast tumours: a comparison with conventional colour Doppler imaging. Eur J Ultrasound. Aug. 1998;7(3):175-81. [pmid: 9700212].
439 Yang WT, Metreweli C. Assessment of factors affecting palpability of breast masses using ultrasonography in Chinese women. J Ultrasound Med. Dec. 1996;15(12):807-12. [pmid: 8947854].
440 Yang WT, Tse GM. Sonographic, mammographic, and histopathologic correlation of symptomatic ductal carcinoma in situ. AJR Am J Roentgenol. Jan. 2004;182(1):101-10. [pmid: 14684521].
441 Yang WT, Suen M, Ahuja A, et al. In vivo demonstration of microcalcification in breast cancer using high resolution ultrasound. Br J Radiol. Jul. 1997;70(835):685-90. [pmid: 9245879].
442 Yang WT, Metreweli C, Lam PK, et al. Benign and malignant breast masses and axillary nodes: evaluation with echo-enhanced color power Doppler US. Radiology. Sep. 2001;220(3):795-802. [pmid: 11526284].
443 Yang WT, Mok CO, King W, et al. Role of high frequency ultrasonography in the evaluation of palpable breast masses in Chinese women: alternative to mammography. J Ultrasound Med. Sep. 1996;15(9):637-44. [pmid: 8866446].
444 Youssefzadeh S, Eibenberger K, Helbich T, et al. Use of resistance index for the diagnosis of breast tumours. Clin Radiol. Jun. 1996;51(6):418-20. [pmid: 8654007].
445 Zonderland HM, Coerkamp EG, Hermans J, et al. Diagnosis of breast cancer: contribution of US as an adjunct to mammography. Radiology. Nov. 1999;213(2):413-22. [pmid: 10551221].
446 Bagni B, Franceschetto A, Casolo A, et al. Scintimammography with 99mTc-MIBI and magnetic resonance imaging in the evaluation of breast cancer. Eur J Nucl Med Mol Imaging. Oct. 2003;30(10):1383-8. [pmid: 12910383].
447 Berg WA, Gutierrez L, NessAiver MS, et al. Diagnostic accuracy of mammography, clinical examination, US, and MR imaging in preoperative assessment of breast cancer. Radiology. Dec. 2004;233(3):830-49. [pmid: 15486214].
448 Boetes C, Mus RD, Holland R, et al. Breast tumors: comparative accuracy of MR imaging relative to mammography and US for demonstrating extent. Radiology. Dec. 1995;197(3):743-7. [pmid: 7480749].
449 Hardy JR, Powles TJ, Judson I, et al. How many tests are required in the diagnosis of palpable breast abnormalities. Clin Oncol (R Coll Radiol). May. 1990;2(3):148-52. [pmid: 2261402].
450 Hata T, Takahashi H, Watanabe K, et al. Magnetic resonance imaging for preoperative evaluation of breast cancer: a comparative study with mammography and ultrasonography. J Am Coll Surg. Feb. 2004;198(2):190-7. [pmid: 14759774].
451 Hlawatsch A, Teifke A, Schmidt M, et al. Preoperative assessment of breast cancer: sonography versus MR imaging. AJR Am J Roentgenol. Dec. 2002;179(6):1493-501. [pmid: 12438043].
452 Leinsinger GL, Friedl L, Tiling R, et al. Comparison of dynamic MR imaging of the breast and sestamibi scintimammography for evaluation of indeterminate mammographic lesions. Eur Radiol. 2001;11(10):2050-7. [pmid: 11702141].
453 Liang W, Lawrence WF, Burnett CB, et al. Acceptability of diagnostic tests for breast cancer. Breast Cancer Res Treat. May. 2003;79(2):199-206. [pmid: 12825854].
454 Malur S, Wurdinger S, Moritz A, et al. Comparison of written reports of mammography, sonography and magnetic resonance mammography for preoperative evaluation of breast lesions, with special emphasis on magnetic resonance mammography. Breast Cancer Res. 2001;3(1):55-60. [pmid: 11250746]. [pmcid: 13900].
455 Muller-Schimpfle M, Stoll P, Stern W, et al. Do mammography, sonography, and MR mammography have a diagnostic benefit compared with mammography and sonography?. AJR Am J Roentgenol. May. 1997;168(5):1323-9. [pmid: 9129436].
456 Rieber A, Schirrmeister H, Gabelmann A, et al. Pre-operative staging of invasive breast cancer with MR mammography and/or PET: boon or bunk. Br J Radiol. Oct. 2002;75(898):789-98. [pmid: 12381687].
457 Sommer H, Tiling R, Pechmann M, et al. Evaluation of mammographic breast lesions with Tc-99m sestamibi scintimammography and contrast enhanced MRI. Zentralbl Gynakol. 1997;119(1):6-11. [pmid: 9050197].
458 Tiling R, Khalkhali I, Sommer H, et al. Limited value of scintimammography and contrast-enhanced MRI in the evaluation of microcalcification detected by mammography. Nucl Med Commun. Jan. 1998;19(1):55-62. [pmid: 9515547].
459 Wang HC, Sun SS, Kao A, et al. Comparison of technetium-99m methoxyisobutylisonitrile scintimammography and ultrasonography in the diagnosis of breast cancer in patients with mammographically dense breast. Cancer Invest. 2002;20(3):318-23. [pmid: 12025226].
460 Yang WT, Lam WW, Cheung H, et al. Sonographic, magnetic resonance imaging, and mammographic assessments of preoperative size of breast cancer. J Ultrasound Med. Dec. 1997;16(12):791-7. [pmid: 9401992].
461 Bone B, Wiberg MK, Szabo BK, et al. Comparison of 99mTc-sestamibi scintimammography and dynamic MR imaging as adjuncts to mammography in the diagnosis of breast cancer. Acta Radiol. Jan. 2003;44(1):28-34. [pmid: 12630995].
462 Maunda KY, Chande H, Mselle TF, et al. 99mTc sestamibi scintimammography in the diagnosis of palpable breast masses. Nucl Med Commun. Feb. 2003;24(2):141-4. [pmid: 12548038].
463 Brem RF, Schoonjans JM, Kieper DA, et al. High-resolution scintimammography: a pilot study. J Nucl Med. Jul. 2002;43(7):909-15. [pmid: 12097461].
464 Danielsson R, Bone B, Agren B, et al. Comparison of planar and SPECT scintimammography with 99mTc-sestamibi in the diagnosis of breast carcinoma. Acta Radiol. Mar. 1999;40(2):176-80. [pmid: 10080730].
465 De Vincentis G, Gianni W, Pani R, et al. Role of 99 mTc-Sestamibi scintimammography by SPEM camera in the management of breast cancer in the elderly. Breast Cancer Res Treat. 1998;48(2):159-63. [pmid: 9596487].
466 Uriarte I, Carril JM, Quirce R, et al. Optimization of X-ray mammography and technetium-99m methoxyisobutylisonitrile scintimammography in the diagnosis of non-palpable breast lesions. Eur J Nucl Med. May. 1998;25(5):491-6. [pmid: 9575244].
467 Alonso JC, Soriano A, Zarca MA, et al. Breast cancer detection with sestamibi-Tc-99m and Tl-201 radionuclides in patients with non conclusive mammography. Anticancer Res. 1997;17(3B):1661-5. [pmid: 9179214].
468 Scopinaro F, Ierardi M, Porfiri LM, et al. 99mTc-MIBI prone scintimammography in patients with high and intermediate risk mammography. Anticancer Res. 1997;17(3B):1635-8. [pmid: 9179209].
469 Tiling R, Khalkhali I, Sommer H, et al. Role of technetium-99m sestamibi scintimammography and contrast- enhanced magnetic resonance imaging for the evaluation of indeterminate mammograms. Eur J Nucl Med. Oct. 1997;24(10):1221-9. [pmid: 9323262].
470 Kristoffersen Wiberg M, Aspelin P, Perbeck L, et al. Value of MR imaging in clinical evaluation of breast lesions. Acta Radiol. May. 2002;43(3):275-81. [pmid: 12100324].