# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report.

## Technical Expert Panel

- Robyn L. Birdwell, MD
- Director, Breast Imaging Section
- Brigham and Women's Hospital
- Department of Radiology
- Boston, MA

- Robert D. Rosenberg, MD
- Professor of Radiology
- Chief, Diagnostic Imaging
- University of New Mexico/
- Albuquerque, NM

- M. Carolina Hinestrosa, MA, MPH
- Executive Vice President for Programs and Planning
- National Breast Cancer Coalition
- Washington, DC

## EPC Program Director

We would also like to acknowledge with appreciation the EPC Program Director during the conduct of this project.

- Kenneth S. Fink, MD, MGA, MPH
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

## AHRQ Contacts

- Beth A. Collins Sharp, PhD, RN
- Acting Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- William Lawrence, MD, MS
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD