# Results

## Overview of Evidence Base for Questions 1 and 2

Our literature searches identified 1,030 potentially relevant articles. The processing of these documents is summarized in Figure 1. The titles and abstracts of these articles were examined. All studies (333) that potentially met the inclusion criteria for Questions 1 and 2 were retrieved. The most common reason for not retrieving an article was because it clearly did not address either of the questions of interest. After retrieval, the full text of the articles was examined. Two hundred sixty four of the 333 retrieved articles did not meet our inclusion criteria. The primary reason for exclusion (63 articles) was not studying women who presented with an abnormal finding by mammography or physical examination. The remaining articles were excluded for a variety of other reasons, shown in Figure 1. These articles and the reason(s) for their exclusion are listed in Appendix C. List of Studies Excluded from Questions 1 and 2.

Figure 1. Flow of Documents for Questions 1 and 2

Having excluded 264 articles, 69 articles remained. These articles are listed in Appendix E. Evidence Tables.

## Summary of Results

### Positron Emission Tomography Scanning

In positron emission tomography (PET) scanning, a small amount of radioactive glucose (18-fluoro-2-deoxyglucose: FDG) is injected into the bloodstream, and a gamma camera, dedicated breast scanner, or whole-body scanner is used to generate images that highlight areas of high tracer uptake. Glucose accumulates in tissues of high growth rate or rapid metabolism (i.e., tumors). Whole-body scanners have a ring of detectors that surround the patient and image the entire body. Gamma cameras have only two detectors, one at each side of the patient, and image only a restricted portion of the body. Dedicated breast scanners have two detectors designed to image only the breasts.

#### Summary

Our analysis found that whole-body PET scanning was more accurate than gamma camera PET imaging for ruling out breast cancer. The strength of the evidence supporting this conclusion was weak, indicating a reasonable chance that publication of new evidence could overturn this conclusion. No studies of dedicated breast PET scanners met the inclusion criteria. At a fixed sensitivity of 95%, the specificity of whole-body PET scanning was only 46.7%. At the mean threshold of the included studies, the sensitivity of PET scanning was 82.2%, the specificity was 78.3%, and the negative predictive value (for a population with a prevalence of 70%) was 64.8%. The stability of the summary diagnostic odds ratio used to obtain these summary diagnostic test characteristics was low, indicating a reasonable chance that publication of new evidence could substantially change these estimates.

We found that the negative likelihood ratio for whole-body PET scanning of women referred for further evaluation of the breast was 0.33. This result means that if a woman with a suspicious lesion is diagnosed as cancer-free by PET scanning, her actual chance of having breast cancer drops from 20% ^1^ to 7.6%. There were no or insufficient data to come to any conclusions about the use of PET to evaluate any sub-populations of patients.

A woman in the general screening population who has a positive finding on mammography and/or physical examination has an approximately 20% chance of having breast cancer.

The authors of one systematic review published in 2001 concluded that the negative predictive value of PET was too low for routine use in ruling out breast cancer after detection of an abnormality. The results of our analysis concur with this conclusion.

The studies, patients, and analyses used to reach these conclusions are described in the following section. The performance of PET in evaluating women with suspicious breast lesions is summarized in Table 3. The estimates of summary diagnostic test characteristics are of low stability, indicating that there is a reasonable chance that the magnitude of the estimate could substantially change as a result of the publication of new evidence.

Table 3 Summary Test Performance of PET

Patient subgroup | N studies | N lesions | Sensitivity | Specificity | Prevalence (Range) | PPV | NPV | + LHR (95% CI) | - LHR (95% CI)
Suspicious breast lesion, whole-body scanning | 6 | 186 | At mean threshold 82.2% | At mean threshold 78.3% | 70.4% (45.2% to 95.0%) | At mean threshold 90.0% | At mean threshold 64.8% | Evidence is unacceptably weak to support a conclusion | 0.33 (95% CI 0.24 to 0.46)
| | | Stability of estimate: Low | At 95% sensitivity 46.7% | | At 95% sensitivity 80.9% | At 95% sensitivity 79.7% | | Stability of estimate: Low
| | | | Stability of estimate: Low | | Stability of estimate: Low | Stability of estimate: Low
Suspicious breast lesion, whole-body scanning vs. gamma camera imaging | 1 | 30 | No summary diagnostic test characteristics were calculated because the evidence base was unacceptably weak to support a quantitative conclusion. | | 86.7% | Whole-body PET scanning is more accurate for ruling out breast cancer than is gamma camera imaging.
| | | | | | Strength of evidence: weak.
Suspicious breast lesion, gamma camera | 2 | 58 | The body of evidence is unacceptably weak for evaluation of test performance.
Palpable lesion | 2 | 66 | The body of evidence is unacceptably weak for evaluation of test performance.
Palpable lesion, ≥1.0 cm | 1 | 24 | The body of evidence is unacceptably weak for evaluation of test performance.
BIRADS 5 | 2 | 49 | The body of evidence is unacceptably weak for evaluation of test performance.
BIRADS 3, ≥1.0 cm | 1 | 18 | The body of evidence is unacceptably weak for evaluation of test performance.
BIRADS 4–5, ≥1.0 cm | 1 | 14 | The body of evidence is unacceptably weak for evaluation of test performance.
Lesions ≥1.0 cm | 2 | 50 | The body of evidence is unacceptably weak for evaluation of test performance.
Lesions ≥1.5 cm | 1 | 29 | The body of evidence is unacceptably weak for evaluation of test performance.
Patients <65 yrs of age: whole-body | 2 | 58 | The body of evidence is unacceptably weak for evaluation of test performance.
Patients <65 yrs of age: gamma camera | 2 | 55 | The body of evidence is unacceptably weak for evaluation of test performance.
Patients ≥65 years of age | 1 | 19 | The body of evidence is unacceptably weak for evaluation of test performance.

PPV = positive predictive value

NPV = negative predictive value

LHR = likelihood ratioTable 4. Studies of PET for Suspicious Breast Lesions

#### Analysis and Results for Key Questions 1. and 2. Diagnostic Test Characteristics, Predictive Values, and Likelihood Ratios of PET

##### Other Published Technology Assessments

We identified one systematic review of PET use after mammography. This review, published by Sampson et al. in 2002, assessed the performance of PET in the differential diagnosis of benign and malignant lesions among patients with abnormal mammograms or a palpable breast mass. ^49,^ ^50^ The review included 13 articles published before March 2001.

Sampson et al. performed a meta-analysis using a random-effects model, and selected a point on the SROC that reflected test performance, with a sensitivity of 89% and a specificity of 80%. When the prevalence of malignancy was 50%, 40% of all patients would benefit by avoiding the harm of a biopsy with negative biopsy results. However, the negative predictive value was found to only be 88%. For a patient with a negative PET scan, the authors concluded that a 12% chance of a missed or delayed diagnosis of breast cancer is too high to make it worth the 88% chance of avoiding biopsy of a benign lesion.

##### Included Studies

Nine diagnostic cohort studies of 18-fluorodeoxyglucose PET scanning met our inclusion criteria. Characteristics of the studies and included patients are summarized in Table 28, in Appendix E. Evidence Tables. All but one of the studies used a whole-body PET scanner. The other (Holle et al. 1996 ^51^ ) used a gamma camera. The quality of all of the studies was moderate (median score of 7.9, range 7.4 to 8.8). The most common flaw in these studies was not reporting whether readers of tests were blinded to patient information or the results of other tests.

The included patients were incompletely described, with few details about demographics reported. The patients were primarily women with suspicious lesions, detected by physical exam, mammography, or ultrasound, who had been scheduled for biopsy, who presented at a time when the PET scanner was available. The number of patients enrolled in the studies was restricted due to scanner availability. Two of the studies excluded patients with lesions smaller than 1.0 cm (Brix et al. ^52^ and Crowe et al. ^53^ ). Patients ranged in age from 20 to 86, and reported mean ages ranged from 48.3 to 58.4, suggesting that the patient populations studied are younger than the typical breast cancer population. Only three of the nine studies (Holle et al. 1996 ^51^ , Yutani et al. 1999 ^54^ , Yutani et al. 2000 ^55^ ) reported the percentage of patients 65 years of age or older: 31 out of 120 patients, 25.8%. Information about the percentage of patients 65 years of age or older was not reported for the remaining 156 patients (see Table 30 in Appendix E. Evidence Tables).

##### Patients Referred for Evaluation of Suspicious Breast Lesions

Six studies reported results for 186 lesions in patients referred for further evaluation by whole-body PET scanning for suspicious breast lesions (abnormal mammogram and/or physical examination and/or ultrasound examination), listed in Table 4. The data were not heterogeneous (I^2^ = 0.0%), indicating no substantial variability among their results (see Table 31, in Appendix E. Evidence Tables). We therefore combined the data to produce a SROC curve (Figure 2). At the mean threshold of these studies, the sensitivity was 82.2%, and the specificity was 78.3%. At a fixed sensitivity of 95%, the specificity was 46.7%, the positive predictive value was 95.7%, and the negative predictive value was 79.7% (the prevalence of breast cancer in this population was 70.4%). This evidence base is of moderate quality; however, cumulative meta-analysis shows that the stability of the diagnostic odds ratio (and, hence, the stability of the sensitivity, specificity, and positive and negative predictive values) is low.

Table 4 Studies of PET for Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Hienisch et al. 2003 ^56^ | 40 | 7.4 | 68.0% (48.4 to 82.7) | 73.3% (48.0 to 88.9) | 81.0% (59.9 to 92.1) | 57.9% (36.3 to 76.7) | 2.55 (1.95 to 3.34) | 0.44 (0.23 to 0.83)
Walter et al. 2003 ^57^ | 42 | 7.9 | 63.2% (41.0 to 80.7) | 91.3% (73.0 to 97.4) | 85.7% (59.8 to 95.7) | 75.0% (56.6 to 87.2) | 7.26 5.15 to 10.24) | 0.40 (0.22 to 0.74)
Yutani et al. 2000 ^55^ | 40 | 7.9 | 78.9% (63.6 to 88.8) | 100.0% (34.0 to 99.3) | 100.0% (88.4 to 99.9) | 20.0% (6.0 to 51.1) | 4.69 (3.98 to 5.54) | 0.26 (0.12 to 0.57)
Yutani et al. 1999 ^54^ | 30 | 8.8 | 100.0% (86.8 to 99.9) | 50.0% (15.4 to 84.6) | 92.9% (77.1 to 97.9) | 100.0% (34.0 to 99.3) | 1.96 (1.86 to 2.07) | 0.04 (0.00 to 0.66)
Palmedo et al. 1997 ^58^ | 20 | 7.9 | 92.3% (66.4 to 98.3) | 85.7% (48.4 to 97.0) | 92.3% (66.4 to 98.3) | 85.7% (48.4 to 97.0) | 6.46 (5.52 to 7.56) | 0.09 (0.01 to 0.60)
Tse et al. 1992 ^59^ | 14 | 7.9 | 80.0% (48.9 to 94.0) | 100.0% (50.5 to 99.5) | 100.0% (67.0 to 99.7) | 66.7% (30.1 to 89.9) | 7.73 (5.61 to 10.65) | 0.25 (0.08 to 0.78)
6 studies | 186 lesions | median 7.9 Moderate | At mean threshold 82.2% | At mean threshold 78.3% At 95% sensitivity 46.7% | At mean threshold 90.0% At 95% sensitivity 80.9% | At mean threshold 64.8% At 95% sensitivity 79.7% | Heterogeneous, no summary estimate calculated | 0.33 (0.24 to 0.46)

Figure 2. SROC of Whole-Body PET Scanning of Patients Referred for Evaluation of Suspicious Breast Lesions

We calculated the summary likelihood ratios from the six studies of patients referred for further evaluation. The data for the negative likelihood ratio were not heterogeneous (I^2^ = 12.3%), so we meta-analytically combined them. The summary negative likelihood ratio was 0.33 (95% CI 0.24 to 0.46), indicating that the test is possibly useful in the clinic. The evidence base is moderate in quality; however, cumulative meta-analysis showed that the summary negative likelihood ratio was of low stability.

The data for the positive likelihood ratio were heterogeneous (I^2^ = 73.1%) and therefore not combined. These likelihood ratios were within the possibly clinically useful range (2 or greater, or in natural logs, as used in Figure 3, 0.69 or greater) for only four out of the six studies (67%). Therefore the data are not qualitatively robust, and cannot be used to support a qualitative conclusion. Because positive likelihood ratios are not directly relevant to the purpose of the PET scan for this report, we did not attempt to explain the heterogeneity further.

Figure 3. Likelihood Ratios of PET for Evaluating Suspicious Breast Lesions

##### Other Patient Groups

Only one or two studies reported results for several different patient subgroups (see Table 3, and Table 30 in Appendix E. Evidence Tables). For all of these subgroups, the evidence bases were found to be unacceptably weak for evaluation of test performance due to their small sizes.

##### Gamma Camera vs. Whole-Body Scanning

One study evaluated the same 30 patients, referred for evaluation of suspicious breast lesions, by both whole-body PET scanning and by gamma camera. Although this evidence base is unacceptably weak for estimation of summary diagnostic test characteristics due to its small size, it is sufficient to support a weak qualitative conclusion because of the extremely large magnitude of the reported difference in diagnostic accuracy between the two methods of imaging. The negative predictive value of whole-body scanning was reported to be 100%, while the negative predictive value of gamma camera imaging was reported to only be 33.3% (Table 5). The negative likelihood ratio of whole-body scanning was 0.04, indicating a clinically useful test, while the negative likelihood ratio of gamma camera imaging was only 0.31. The study is of moderate quality (8.8), and the magnitude of effect is extremely large; therefore, the strength of the evidence is weak.

Table 5 Whole-Body PET Scanning vs. Gamma Camera PET Scanning^a^

Type of scan | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Whole-body | 100.0% (86.8 to 99.9) | 50.0% (15.4 to 84.6) | 92.9% (77.1 to 97.9) | 100.0% (34.0 to 99.3) | 1.96 (1.86 to 2.07) | 0.04 (0.00 to 0.66)
Gamma camera | 84.6% (66.3 to 93.7) | 50.0% (15.4 to 84.6) | 91.7% (73.9 to 97.5) | 33.3% (10.1 to 69.9) | 1.69 (1.44 to 1.99) | 0.31 (0.08 to 1.17)

a Data from Yutani et al. 1999 ^54^ , for 30 lesions.

#### Key Question 3. Are there other factors which affect the accuracy or acceptability of PET scanning?

The following narrative review identifies and discusses key factors that experts in the field believe may affect the performance of PET imaging of the breast.

##### Equipment Differences

###### [underlined: Camera Design]

Three types of detectors are used for PET imaging of the breast: whole-body PET cameras, standard gamma cameras modified for coincidence detection, and dedicated breast PET cameras. Whole-body PET cameras consist of a ring of detectors that surround the patient. The ring of detectors maximizes the geometric detection efficiency of gamma photons emitted from the patient. Standard gamma cameras can be used if detector heads are placed on opposing sides of the patient and modifications of the electronics (to enable detection of coincident events) are used. The geometry of this arrangement is, however, not optimal for breast imaging since a significant proportion of photons will not be detectable. Also, gamma cameras are designed to detect gamma rays of lower energy compared to those emitted in PET studies. Dedicated mammography PET scanners consist of two small detector heads similar to a standard gamma camera. However, since they are used close to the patient's breast, the geometrical losses are significantly reduced.

There are variations in PET camera performance. ^60^ Since PET camera performance is governed by the statistic of photon counting, it is theoretically possible to compensate for inferior counting performance with longer image acquisition times or higher doses of FDG. However, factors such as image reconstruction algorithm cannot be corrected for. ^60^ In a general comparison of PET cameras the investigators concluded that the difference in contrast leads to a systematic difference in measured standardized uptake value (SUV; see below for further explanation), which may affect diagnostic accuracy. ^60^ It is not clear how clinically relevant these differences are with respect to breast imaging.

###### [underlined: Scan Time]

Longer image acquisition times will improve the count statistics and, therefore, image quality of any PET scan. However, other factors such as patient movement, comfort, and workflow mean that acquisition times should be kept as short as possible. The optimum exam time will depend on the characteristics of the detector. ^60^ Users of dedicated breast PET cameras report acquisition times of four to five minutes. ^61^ Direct comparisons of scan times between dedicated breast and whole-body PET cameras are difficult because a much larger area is included in whole-body scans and the exam time usually includes an attenuation correction step. Typically the exam takes 45 to 60 minutes. ^62^ The acquisition time for a single table position is seven to fifteen minutes. ^60,^ ^63^ Lesion detection is compromised if the acquisition time is too short. ^64^

###### [underlined: Attenuation Correction and SUV Calculation]

In whole-body PET studies it is standard practice to acquire a second set of images so that the reconstructed images can be corrected to account for differences in the attenuation of the gamma photons in different areas of the body. In breast imaging some users believe that attenuation correction is essential for tumor localization and quantification of uptake. ^63^ In contrast, one study found that lesion detectability was impaired when attenuation correction was used. ^65^

An attenuation correction image is not acquired when using dedicated mammography PET cameras. Instead, a simple geometric attenuation correction is effective since the attenuation properties of the breast are relatively uniform compared to other body parts. ^66^

Regions with higher FDG uptake will appear as foci on the reconstructed images. The SUV is the mean activity detected normalized for the injected dose and body weight. Regions with higher FDG uptake will have a higher SUV. A threshold value is used to identify possible malignancies. ^61^ However, the SUV is dependent on the image reconstruction algorithm to the extent that diagnostic accuracy may be affected. ^60^ The reconstruction algorithm is manufacturer dependent. In addition, the SUV depends on several study-specific factors such as FDG uptake time, patient motion, size of the lesion, histology of lesion, patient motion, patient weight, blood glucose level, patient position, and spatial resolution. ^62,^ ^63,^ ^67^ Therefore, it is reasonable to conclude that the diagnostic performance of breast PET imaging will vary among manufacturers and studies.

##### Effect of Operator and Image Interpreter on PET Imaging

The interpretation of breast PET images involves the visual identification of foci and analysis of the computed SUV. Judgment is required to identify foci from the sometimes patchy background. ^68^ Breast implants can cause photopenic artifacts that underestimate the SUVs. ^69^ However, automatic SUV calculation is a standard feature on all PET systems. A threshold value is used to determine malignancy. ^63^ Therefore, intra-observer differences should be insignificant.

##### Patient Glucose Levels

Since FDG is a glucose analog, the performance of FDG imaging is affected by the patient's glucose levels. It is common practice to instruct patients to fast for four to six hours before any PET study and to monitor glucose levels during imaging. Because muscle activity can affect blood glucose levels, it may be necessary to use a muscle relaxant to reduce muscle activity in anxious patients. ^62^ Glucose levels must be low. Diabetic patients must have controlled glucose levels. ^62,^ ^63^

##### Administered Dose of Tracer

Since FDG is a non-specific tracer, the administered dose does not depend on the anatomy of interest. Therefore, standard doses of FDG are administered for breast imaging using whole-body scanners (300 to 400 MBq, 10 mCi). ^62,^ ^63^ Dedicated mammography PET cameras use significantly lower doses of FDG (~75 MBq, 2 mCi) due to improved geometrical detection efficacy. ^68,^ ^70^ Higher doses may result in a higher tumor detection rate. ^63^ The relatively short half-life of FDG compared to other radiopharmaceuticals means that the exact dose administered will depend on the availability of FDG and skill of the radiopharmacist. To avoid the effects of FDG contamination at the injection site, the injection site should be contra-lateral to the breast with the suspected lesion. ^63^

##### Radioisotope Uptake Time

FDG is gradually taken up in areas of increased metabolism. Concurrently the ^18^ F is decaying. These two processes counteract each other. Therefore, there is an optimum uptake time. The standard uptake time used in routine PET imaging is about an hour. ^62,^ ^63^ Longer uptake times may improve diagnostic performance. ^71^ However, other factors must be considered when deciding upon an uptake time, such as workflow and patient well-being (during uptake the patient must rest in isolation, which can be stressful for some patients).

##### Patient Position

When imaging the breast in a whole-body PET camera, the optimum position for the patient is to lie prone with the breasts hanging free. ^63^ A study comparing the prone and supine positioning found that SUVs were significantly higher when the patient was prone and padding was used to enable the breasts to hang free. ^67^

When using dedicated breast PET cameras, the positioning is similar to x-ray mammography with the breast compressed between the two detector heads. ^61,^ ^68,^ ^70^ The compression helps reduce patient movement and the patient may be seated or prone during the acquisition.

##### Lesion Size

The detectability of lesions that are smaller than the spatial resolution of the imaging system is compromised by the partial volume effect. ^63^ Spatial resolution is important in breast imaging since the lesions are small. Spatial resolution in PET imaging is influenced by the camera design and the physics of positron annihilation. Whole-body cameras have spatial resolution specifications in the range 6 to 8 mm. The spatial resolution of dedicated mammography PET cameras is reported to be 2 to 3 mm. ^61,^ ^70^ It is possible to increase sensitivity by mathematically correcting for partial volume contrast losses. However, as sensitivity is increased the specificity decreases. ^72^

The sensitivity of PET for breast cancer detection is believed to be highly dependent on the diameter of the lesions. ^63,^ ^64^ A number of studies have reported that the sensitivity of whole-body PET decreases for lesions less than 20 mm in diameter. ^54,^ ^72,^ ^73^ Detection of lesions with a modified gamma camera has only been demonstrated for lesions greater than 20 mm in diameter. ^54,^ ^73^ Dedicated mammography PET cameras are reported to be able to detect lesions less than 10 mm in size. ^61,^ ^68^

##### Patient Safety and Comfort

Two issues should be considered for patient safety: the radiation dose and pharmaceutical-related adverse reactions. Patient comfort depends on the type of PET camera being used. These issues are discussed below:

###### [underlined: Radiation Dose]

Using a typical dose for a whole-body scan, the effective radiation dose delivered is 19 μSv/MBq (the value depends on the how often the patient voids). This translates to 7.6 mSv for a typical 400 MBq whole-body PET exam or 1.4 mSv in dedicated mammography PET. The whole-body effective dose is similar to other nuclear medicine studies and equivalent to about two and a half years of background radiation. The dedicated mammography PET effective dose is similar to some x-ray examinations or about 6 months of background radiation. Therefore, radiation dose is not a significant concern, particularly if a dedicated mammography PET camera is used.

Following the exam, the short half-life of ^18^ F means that additional precautions, such as avoiding public transportation, are not necessary. ^74^

###### [underlined: Pharmaceutical Safety]

The intravenous administration of any pharmaceutical could lead to an adverse reaction. In a retrospective analysis of 81,801 administrations of PET radiopharmaceutical, the number of serious adverse reactions reported was zero. ^75^ Therefore, PET radiopharmaceuticals can be considered safe.

###### [underlined: Patient Comfort]

All PET studies require the patient to relax for about an hour before image acquisition begins. In a whole-body PET camera, the patient must lie prone for fifteen minutes to an hour, depending on the coverage of the study. No compression is used and the gantry is not as confining as an MR unit. No significant patient comfort issues have been reported.

When using a dedicated mammography PET camera, mild compression is used for about five minutes. The level of compression is less than that used during x-ray mammography. ^68^ Therefore, patient comfort is not a significant concern.

###### [underlined: Accreditation Factors]

PET systems are cleared for marketing through the U.S. Food and Drug Administration (FDA) 510(k) process. This clearance is for general-purpose whole-body imaging and is not limited to specific indications. In August 2003, the FDA cleared the first small field-of-view positron emission tomography system (i.e., a dedicated mammography PET camera). Naviscan PET Systems, Inc., formerly PEM Technologies (Rockville, MD, USA), received 510(k) clearance for its PEM 2400 PET system for general imaging of the distribution of injected PET radiopharmaceuticals to determine various metabolic and physiologic functions.

The Intersocietal Commission for the Accreditation of Nuclear Medicine Laboratories (ICANL) offers voluntary accreditation to facilities based on a peer review of their staff's qualifications, education, equipment, quality control, and volume of clinical procedures. ^76^

All medical and technical staff are required to meet specific minimum experience and education requirements in order for their facility to be accredited by ICANL. Options available to a facility's medical staff range from board certification in nuclear medicine to board certification in a specialty area with a minimum number of years practice and volume of studies interpreted.

The accreditation program requires the technical director and all technologists working in the facility to hold the RT(N) credential from the American Registry of Radiologic Technologists (ARRT) or the CNMT credential from the Nuclear Medicine Technology Certification Board (NMTCB). In all situations, the physician is ultimately responsible to see that the appropriate images are obtained.

### Scintimammography

Scintimammography is similar to PET scanning in that it detects tissues that accumulate higher levels of a radioactive tracer. The tracer most commonly used for breast examination is ^99m^Tc-sestamibi. Gamma cameras used for scintimammography are designed to perform either planar (two-dimensional) imaging of the three-dimensional radiopharmaceutical distribution or single photon emission tomography (SPECT). SPECT is a technique that may use one, two, or three heads to create a three-dimensional representation of the administered radiopharmaceutical.

#### Summary

Our analysis found that for non-palpable lesions, at a fixed 95% sensitivity, the specificity of scintimammography was only 39.2%. At the mean threshold of the included studies, the sensitivity was 68.7% and the specificity was 84.8%. The stability of the summary diagnostic odds ratio used to obtain these summary estimates was moderate, indicating a small chance that publication of new evidence could substantially change these estimates.

For palpable lesions and suspicious breast lesions in general, there was unexplained heterogeneity in the data, and therefore summary diagnostic test characteristics could not be calculated (summarized in Table 6).

Table 6 Summary Test Performance of Scintimammography

Patient subgroup | N studies | N lesions | Sensitivity | Specificity | Prevalence (Range) | PPV | NPV | + LHR (95% CI) | z- LHR (95% CI)
Suspicious breast lesion | 22 | 3793 | Unexplained heterogeneity. No summary diagnostic test characteristics could be calculated. | | 45.7% (16.2% to 86.1%) | Unexplained heterogeneity. No summary diagnostic test characteristics could be calculated. | | Possibly clinically useful. | Possibly clinically useful in ruling out cancer.
| | | | | | | | Strength of evidence: Moderate | Strength of evidence: Moderate
Palpable lesions | 11 | 1012 | Unexplained heterogeneity. No summary diagnostic test characteristics could be calculated. | | 72.6% (27.1% to 85.9%) | Unexplained heterogeneity. No summary diagnostic test characteristics could be calculated. | | Possibly clinically useful. | The evidence base is unacceptably weak for evaluation of test performance
| | | | | | | | Strength of evidence: Moderate
Non-palpable lesions | 10 | 509 | At mean threshold 68.7% | At mean threshold 84.8% | 57.0% (17.8% to 78.3%) | At mean threshold 85.7% | At mean threshold 67.2% | Possibly clinically useful. | 0.41 (0.34 to 0.49)
| | | Stability of estimate: Moderate | At 95% sensitivity 39.2% | | At 95% sensitivity 67.4% | At 95% sensitivity 85.5% | Strength of evidence: Moderate | Stability of estimate: Low
| | | | Stability of estimate: Moderate | | Stabiility of estimate: Moderate | Stability of estimate: Moderate
Non-palpable lesions with microcalcifications | 3 | 79 | 58.1% (43.4% to 72.9%) | 86.1% (74.8% to 97.4%) | 54.4% (46.2% to 61.9%) | 83.3% (72.2% to 94.5%) | 63.3% (47.5% to 79.0%) | 4.27 (3.47 to 5.26) | 0.50 (0.32 to 0.78)
| | | Stability of estimate: Low | Stability of estimate: Low | | Stability of estimate: Low | Stability of estimate: Low | Stability of estimate: Low | Stabiliity of estimate: Low
Lesions >1.0 cm | 3 | 306 | 95.1% (92.2% to 97.9%) | 77.8% (68.7% to 86.8%) | 73.5% (61.5% to 87.0%) | 92.2% (88.7% to 95.7%) | 85.1% (77.4% to 92.9%) | The evidence base is unacceptably weak for evaluation of test performance | 0.07 (0.05 to 0.10)
| | | Stability of estimate: Low | Stability of estimate: Low | | Stability of estimate: Low | Stability of estimate: Low | | Stability of estimate: Low
Lesions ≤1.0 cm | 2 | 66 | The evidence base is unacceptably weak for evaluation of test performance.
Lesions 1.0 to 1.5 cm | 1 | 31 | The evidence base is unacceptably weak for evaluation of test performance.
Lesions >1.5 cm, planar imaging | 1 | 58 | The evidence base is unacceptably weak for evaluation of test performance.
Lesions ≥1.5 cm, SPECT imaging | 1 | 29 | The evidence base is unacceptably weak for evaluation of test performance.
Younger than 65 years of age, planar imaging | 2 | 47 | The evidence base is unacceptably weak for evaluation of test performance.
Younger than 65 years of age, SPECT imaging | 1 | 34 | The evidence base is unacceptably weak for evaluation of test performance.
65 years of age or older | 1 | 18 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 1–2 | 1 | 696 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 3–4 | 1 | 348 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 3–5 | 1 | 78 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 4–5 | 1 | 91 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 3 | 1 | 20 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 4 | 1 | 30 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 5, planar imaging | 2 | 227 | The evidence base is unacceptably weak for evaluation of test performance.
BIRADS 5, SPECT imaging | 1 | 30 | The evidence base is unacceptably weak for evaluation of test performance.
Indeterminate findings on mammogram | 2 | 100 | The evidence base is unacceptably weak for evaluation of test performance.
Positive by fine needle aspiration | 1 | 111 | The evidence base is unacceptably weak for evaluation of test performance.
Dense breast tissue | 1 | 276 | The evidence base is unacceptably weak for evaluation of test performance.
Fatty breast tissue | 1 | 304 | The evidence base is unacceptably weak for evaluation of test performance.
Premenopausal patients | 1 | 117 | The evidence base is unacceptably weak for evaluation of test performance.
Post-menopausal patients | 1 | 140 | The evidence base is unacceptably weak for evaluation of test performance.
SPECT vs. planar imaging | 4 | 243 | The evidence base is unacceptably weak to support a conclusion as to whether SPECT or planar is less likely to miss cases of cancer.

PPV = positive predictive value

NPV = negative predictive value

LHR = likelihood ratioTable

Our analysis found that, when used to evaluate women with non-palpable lesions, the negative likelihood ratio of scintimammography was 0.41. This finding means that if a woman with a non-palpable lesion is diagnosed as cancer-free by scintimammography, her chance of actually having breast cancer drops from 20% ^2^ to 9.3%. Similarly, for a woman referred for further evaluation of non-palpable lesions with microcalcifications who is diagnosed as cancer-free by scintimammography, her chance of actually having breast cancer is still 11.1%, and for a woman referred for further evaluation of lesions larger than 1 cm who is diagnosed as cancer-free by scintimammography, her chance of actually having breast cancer is only 1.7%. However, the stability of our estimates of diagnostic test performance is low and, therefore, there is a reasonable chance that the magnitude of the estimates could substantially change upon publication of new information.

A woman in the general screening population who has a positive finding on mammography and/or physical examination has an approximately 20% chance of having breast cancer.

The authors of four other technology assessments concluded that scintimammography was effective and cost-saving for identifying women who could safely avoid biopsy, but at an acceptable cost of some (28 cases/1,000 patients) missed cases of cancer and a potential loss of life. We, however, found a higher rate of missed cancers (93 cases/1,000 patients). The difference between our results and these previous findings may be attributable to the fact that we included studies published after these technology assessments were prepared.

#### Analysis and Results for Key Questions 1. and 2. Diagnostic Test Characteristics, Predictive Values, and Likelihood Ratios of Scintimammography

##### Other Published Technology Assessments

We identified two decision/cost effectiveness analyses and two systematic reviews of the use of scintimammography to evaluate women after a positive mammography exam. These reports were published prior to publication of some of the studies included in the present report. Regardless, the findings of these four reports are briefly summarized in Table 7. All of the authors of these analyses concluded that scintimammography was effective and cost-saving for identifying women who could safely avoid biopsy. However, the authors of both cost-effectiveness analyses concluded that there was a cost of some missed cancers, and a potential loss of life, associated with the routine use of scintimammography.

Table 7 Other Published Technology Assessments of Scintimammography

Study | Methods | Conclusions
Hillner 1997 ^77^ | A decision analysis model comparing scintimammography to core biopsy and open surgical biopsy for hypothetical cohorts of women with nonpalpable breast lesions detected by mammography. The performances of scintimammography and biopsy were estimated from the general literature. | The model predicted that per 1,000 women, core biopsy would miss seven invasive and 10 in situ cancers, as compared to open surgery. Scintimammography would miss an additional 16 invasive cancers and 12 in situ cancers, as compared to core biopsy. However, most missed cancers would be detected if all women with negative findings received a 6-month followup mammography, and 65% of women undergoing scintimammography would be able to avoid any type of biopsy. Compared to undergoing immediate surgery, costs would be reduced by 20% with core biopsy, and by 39% with scintimammography. For each cancer diagnosis that was delayed by six months, the authors concluded that scintimammography would save $77,500.
Allen et al. 2000 ^78^ | A decision tree sensitivity analysis comparing three patient management strategies: core needle biopsy after indeterminate or positive mammograms; core needle biopsy after positive mammograms, but patients with indeterminate mammograms were examined by scintimammography, and sent for core biopsy only if positive by scintimammography; all patients with indeterminate or positive mammograms were examined by scintimammography, and sent for core biopsy only if positive by scintimammography. Values used in the analysis were derived from the general literature. | The model predicted that the use of scintimammography would save money by reducing the number of biopsies, but at a cost of lost life expectancy. The use of scintimammography after indeterminate mammograms would save $189 million per year (assuming 21 million women undergo mammographic screening per year) at a cost of a loss of 0.000178 years of mean life expectancy. The use of scintimammography after positive and indeterminate mammograms would save $420 million per year, at a cost of a loss of 0.000222 years of life expectancy.
Liberman et al. 2003 ^79^ | A systematic review of the literature on the accuracy of scintimammography in the diagnosis of breast cancer. The review included 64 papers published between January 1967 and December 1999. The diagnostic test characteristics were individually combined meta-analytically in a fixed-effects model. Quality of the studies was formally assessed and used to weight the studies in the meta-analysis. | The aggregated summary test characteristics for scintimammography were 85.2% sensitivity and 86.6% specificity. For patients with a palpable mass, sensitivity was 87.8% and specificity was 87.5%. For patients without a palpable mass, lesions detected by mammography, sensitivity was 66.8% and specificity was 86.9%. The authors of the review concluded that scintimammography may be used effectively as an adjunct to mammography and physical examination in the diagnosis of breast cancer.
Medical Advisory Secretariat, Ontario Ministry of Health 2003 ^80^ | A systematic review of the literature on the effectiveness of scintimammography in breast cancer detection. Studies published between 1992 and 2002 were eligible for inclusion. Seven studies directly comparing ultrasound to scintimammography, and 49 studies assessing the accuracy of scintimammography, were included. The data from the included studies was combined meta-analytically using the method of Littenburg and Moses.^81^ | The authors concluded that scintimammography is an effective imaging technique that can improve the ability to classify patients correctly. Summary receiver operating curves were shown, but no summary test characteristics were derived.

The estimates of scintimammography test performance used in the two decision analyses were different than the estimates we derived from our analysis of the current literature. For non-palpable lesions, at mean threshold we found a sensitivity of 68.7% and a specificity of 84.8%, and we estimated the routine use of scintimammography would lead to 93 missed cancers per 1,000 women. Hillner ^77^ used a sensitivity of 85% and a specificity of 90%, data taken from a preliminary report from a single study (published only in abstract form at the time Hillner's report was being prepared in 1996). At a specificity of 85%, our analysis found scintimammography had a sensitivity of only 65%. Using higher estimates of test performance led Hillner et al. to conclude that scintimammography would miss fewer cancers (only 28 missed per 1,000 women) than our estimate of 93 missed per 1,000 women.

Allen et al. ^78^ obtained estimates of test performance from the literature available at the time, and the numbers used, 52% sensitivity, 93.3% specificity, are similar to our findings, but at a higher threshold than that used in the majority of recently published studies. The threshold chosen by Allen et al. would send very few women for biopsy, resulting in substantial cost savings in exchange for the missed cases of cancer. If Allen et al. had used the lower threshold in common use in the current literature (around 70% sensitivity), many more biopsies would have been performed per missed case of cancer, and Allen et al. may have reached a different conclusion as to the clinical utility of scintimammography.

The authors of the two systematic reviews both concluded that scintimammography was an effective imaging tool for aiding in the diagnosis of breast cancer. Both systematic reviews reported the sensitivity and specificity of scintimammography. They did not discuss the possible clinical implications of these estimates, nor did they report likelihood ratios or predictive values. Therefore, the authors'rationale for directly concluding from simple estimates of sensitivity and specificity that scintimammography is an effective imaging tool is unclear.

##### Included Studies

Forty-four diagnostic cohort studies published in 45 manuscripts met our inclusion criteria. Characteristics of the studies and included patients are summarized in Table 32, in Appendix E. Evidence Tables. The quality of all of the studies was moderate (median score of 7.9, range 6.0 to 8.8). A common shortcoming in these studies was not reporting whether readers of tests were blinded to patient information or the results of other tests.

The patients enrolled in these studies were incompletely described. Most of the studies enrolled any patient referred for biopsy due to a suspicious lesion discovered on physical exam or mammography. A few studies had more specific criteria, such as the presence of microcalcifications, specific BIRADS categories after mammography, or only non-palpable lesions. The patients ranged in age from 17 to 94. Reported mean ages were around 50, suggesting that the patient populations studied are younger than the typical breast cancer population. Information about the percentage of patients 65 years of age or older was only reported for 815 of the 5,644 patients. Of these 815 patients, 163, or 20%, were 65 years of age or older.

The diagnostic test characteristics that we computed from data reported by each of the studies are shown in Table 34, in Appendix E. Evidence Tables.

##### Patients Referred for Further Evaluation of Suspicious Breast Lesions

Twenty-two studies reported results for 3793 lesions in patients referred for further evaluation of suspicious breast lesions (abnormal mammogram and/or abnormal physical examination), listed in Table 8. The data were heterogenous (I^2^ = 68%) and therefore we did not combine them (Table 35, in Appendix E. Evidence Tables). We performed meta-regression to identify possible causes of the heterogeneity (the results of this analysis are summarized in Table 36, in Appendix E. Evidence Tables). None of the variables we examined had a statistically significant correlation with the diagnostic odds ratio. Because the heterogeneity could not be explained, we did not compute a summary estimate of diagnostic test performance. The individual study estimates of diagnostic test performance are shown in Figure 4. As can be seen, most of the estimates are tightly clustered in the 80 to 90% sensitivity/specificity region. For clarity, in the figure the clustered estimates have not been labeled with study names; only the outliers have been labeled.

Table 8 Studies of Scintimammography for Evaluation of Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Sampalis et al. 2003 ^82^ | 1243 | 6 | 92.5% (88.0% to 95.4%) | 86.9% (84.8% to 88.9%) | 57.8% (52.3% to 63.0%) | 98.4% (97.3% to 99.0%) | 7.09 6.82 to 7.37) | 0.09 (0.05 to 0.14)
Khalkhali et al. 2002 ^83^ | 580 | 8.3 | 71.5% (65.1% to 77.1%) | 79.2% (74.4% to 83.3%) | 69.5% (63.2% to 75.2%) | 80.7% (76.0% to 84.7%) | 3.44 (3.16 to 3.74) | 0.36 (0.29 to 0.45)
Scopinaro et al. 1997 ^84^ | 449 | 8.3 | 84.8% (80.7% to 88.1%) | 90.4% (82.7% to 94.8%) | 97.1% (94.5% to 98.4%) | 61.2% (52.8% to 68.8%) | 8.86 (8.47 to 9.25) | 0.17 (0.13 to 0.22)
Tofani et al. 1999 ^85^ | 300 | 8.3 | 89.0% (84.1% to 92.5%) | 82.9% (73.3% to 89.5%) | 93.3% (89.0% to 95.9%) | 73.9% (64.1% to 81.8%) | 5.21 (4.97 to 5.46) | 0.13 (0.09 to 0.20)
Mekhmandarov et al. 1998 ^86^ | 140 | 8.8 | 83.5% (74.2% to 89.9%) | 85.5% (73.8% to 92.4%) | 89.9% (81.2% to 94.7%) | 77.0% (65.0% to 85.7%) | 5.74 (5.23 to 6.31) | 0.19 (0.12 to 0.31)
Danielsson et al. 1999 ^87^ | 121 | 8.6 | 83.7% (74.5% to 90.0%) | 74.3% (57.9% to 85.7%) | 88.9% (80.1% to 94.0%) | 65.0% (49.5% to 77.8%) | 3.26 (2.97 to 3.57) | 0.22 0.13 to 0.37)
Wilczek et al. 2003 ^88^ | 119 | 8.6 | 85.5% (76.3% to 91.5%) | 75.0% (58.9% to 86.1%) | 88.8% (79.9% to 93.9%) | 69.2% (53.5% to 81.3%) | 3.42 (3.13 to 3.74) | 0.19 (0.11 to 0.34)
Krishnaiah et al. 2003 ^89^ | 104 | 7.4 | 83.3% (64.0% to 93.1%) | 82.5% (72.7% to 89.2%) | 58.8% (42.2% to 73.6%) | 94.3% (86.1% to 97.7%) | 4.76 (3.98 to 5.69) | 0.20 (0.08 to 0.50)
Obwegeser et al. 1999 ^90^ | 103 | 7.4 | 46.4% (34.0% to 59.3%) | 87.2% (74.7% to 93.9%) | 81.3% (64.6% to 91.0%) | 57.7% (46.1% to 68.5%) | 3.64 (2.75 to 4.82) | 0.61 (0.47 to 0.80)
Koukouraki et al. 2001 ^91^ | 86 | 7.5 | 93.0% (85.5% to 96.7%) | 83.3% (66.3% to 92.5%) | 94.1% (86.9% to 97.4%) | 80.6% (63.6% to 90.7%) | 5.58 (5.27 to 5.91) | 0.08 (0.04 to 0.18)
Schillaci et al. 1997 ^92^ | 66 | 8.8 | 85.7% (72.0% to 93.2%) | 91.7% (73.9% to 97.5%) | 94.7% (82.5% to 98.4%) | 78.6% (60.4% to 89.6%) | 10.29 (9.09 to 11.64) | 0.16 (0.07 to 0.33)
Villanueva-Meyer et al. 1996 ^93^ | 66 | 8.6 | 82.9% (67.2% to 91.8%) | 93.5% (79.1% to 98.1%) | 93.5% (79.1% to 98.1%) | 82.9% (67.2% to 91.8%) | 12.84 11.05 to 14.93) | 0.18 (0.09 to 0.38)
Chen et al. 1997 ^94^ | 63 | 8.1 | 78.1% (61.2% to 88.8%) | 90.3% (74.9% to 96.5%) | 89.3% (72.6% to 96.1%) | 80.0% (64.0% to 89.8%) | 8.07 (6.72 to 9.70) | 0.24 (0.12 to 0.47)
Tiling et al. 1997 ^95^ | 56 | 8.3 | 87.9% (72.5% to 95.0%) | 82.6% (62.7% to 92.8%) | 87.9% (72.5% to 95.0%) | 82.6% (62.7% to 92.8%) | 5.05 (4.45 to 5.74) | 0.15 (0.06 to 0.37)
Palmedo et al. 1996 ^96^ | 54 | 7.9 | 87.5% (68.8% to 95.5%) | 86.7% (70.2% to 94.5%) | 84.0% (65.2% to 93.4%) | 89.7% (73.4% to 96.3%) | 6.56 (5.64 to 7.63) | 0.14 (0.05 to 0.42)
Leidenius et al. 2002 ^97^ | 49 | 7.9 | 77.4% (60.1% to 88.5%) | 61.1% (38.6% to 79.6%) | 77.4% (60.1% to 88.5%) | 61.1% (38.6% to 79.6%) | 1.99 (1.65 to 2.41) | 0.37 (0.17 to 0.78)
Imbriaco et al. 2001 ^98^ | 49 | 7.6 | 80.8% (62.0% to 91.3%) | 87.5% (68.8% to 95.5%) | 87.5% (68.8% to 95.5%) | 80.8% (62.0% to 91.3%) | 6.46 (5.36 to 7.79) | 0.22 (0.10 to 0.49)
Papantoniou et al. 2001 ^99^ | 41 | 7.9 | 88.5% (70.8% to 95.8%) | 93.3% (69.9% to 98.6%) | 95.8% (79.5% to 99.1%) | 82.4% (58.8% to 93.6%) | 13.27 (11.55 to 15.25) | 0.12 (0.04 to 0.36)
Sanidas et al. 2003 ^100^ | 33 | 8.3 | 90.3% (74.9% to 96.5%) | 80.0% (37.4% to 95.9%) | 96.6% (82.6% to 99.2%) | 57.1% (25.2% to 83.9%) | 4.52 (4.02 to 5.07) | 0.12 (0.04 to 0.39)
Gutfilen et al. 2001 ^101^ | 30 | 6.9 | 95.7% (78.7% to 99.0%) | 42.9% (16.1% to 74.8%) | 84.6% (66.3% to 93.7%) | 75.0% (30.1% to 94.9%) | 1.67 (1.53 to 1.83) | 0.10 (0.01 to 0.83)
Yuen-Green et al. 1996 ^102^ | 21 | 7.9 | 83.3% (43.5% to 96.5%) | 93.3% (69.9% to 98.6%) | 83.3% (43.5% to 96.5%) | 93.3% (69.9% to 98.6%) | 12.50 (8.74 to 17.88) | 0.18 (0.03 to 1.07)
Palmedo et al. 1997 ^58^ | 20 | 7.9 | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 6.46 (5.52 to 7.56) | 0.09 (0.01 to 0.60)
22 studies | 3,793 lesions | median 8.0 Moderate | Heterogeneous, no summary estimates calculated.

Figure 4. Diagnostic Test Characteristics of Scintimammography for Evaluating Suspicious Breast Lesions

The natural log of the likelihood ratios calculated from data reported by each study are shown graphically in Figure 5. The majority (18 out of 22; 82%) of the negative likelihood ratios are within the possibly/clinically useful range (less than 0.5, or for natural logs as shown in the graph, less than -0.69). Therefore the data are qualitatively consistent, and we can conclude that scintimammography may be clinically useful in ruling out breast cancer, supported by evidence of moderate strength. Similarly, because all but two of the positive likelihood ratios are within the possibly/clinically useful range, we can conclude that scintimammography may be clinically useful for ruling in breast cancer, supported by evidence of moderate strength.

Figure 5. Likelihood Ratios of Scintimammography for Evaluating Suspicious Breast Lesions

##### Palpable Lesions

Eleven studies reported results for 1,012 lesions in patients referred for further examination after detection of a palpable lesion (listed in Table 9). The data were heterogeneous (I^2^ = 57%) and, therefore, we did not directly combine them (see Table 37 in Appendix E. Evidence Tables). Instead, we performed a meta-regression (summarized in Table 38, in Appendix E. Evidence Tables) to identify possible causes of the heterogeneity. “Time elapsed between tracer injection and scan” significantly correlated with the diagnostic odds ratio (p = 0.0040), but explained only 47% of the between-studies variation. None of the other variables we examined had a statistically significant correlation with the diagnostic odds ratio. The final model fitted is shown in Figure 6. All of the studies but one (Scopinaro et al.) allowed fewer than 20 minutes to elapse between injection of the tracer and the scan. When the data from Scopinaro et al. are removed from the analysis, the correlation between time elapsed and diagnostic odds ratio is no longer statistically significant (p = 0.0650). Because the statistically significant results are due to the results of one outlying study, this model is not robust enough to permit conclusions.

Table 9 Studies of Scintimammography for Palpable Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Scopinaro et al. 1997 ^84^ | 283 | 8.3 | 97.3% (94.3% to 98.7%) | 89.7% (79.1% to 95.1%) | 97.3% (94.3% to 98.7%) | 89.7% (79.1% to 95.1%) | 9.41 (9.21 to 9.61) | 0.03 (0.01 to 0.07)
Alonso et al. 2001 ^103^ | 245 | 7.9 | 83.1% (77.1% to 87.7%) | 76.8% (64.2% to 85.8%) | 92.4% (87.3% to 95.4%) | 57.3% (46.0% to 67.9%) | 3.58 (3.36 to 3.82) | 0.22 (0.16 to 0.31)
Mekhmandarov et al. 1998 ^86^ | 85 | 8.8 | 95.1% (86.4% to 98.2%) | 75.0% (55.0% to 87.8%) | 90.6% (80.9% to 95.5%) | 85.7% (65.2% to 94.8%) | 3.80 (3.59 to 4.03) | 0.07 (0.02 to 0.20)
Koukouraki et al. 2001 ^91^ | 78 | 7.5 | 94.0% (85.5% to 97.6%) | 72.7% (43.4% to 90.0%) | 95.5% (87.4% to 98.4%) | 66.7% (39.0% to 86.0%) | 3.45 (3.25 to 3.66) | 0.08 (0.03 to 0.23)
Wilczek et al. 2003 ^88^ | 65 | 8.6 | 91.3% (79.5% to 96.5%) | 63.2% (41.0% to 80.7%) | 85.7% (73.2% to 92.8%) | 75.0% (50.4% to 89.6%) | 2.48 (2.27 to 2.71) | 0.14 (0.05 to 0.37)
Krishnaiah et al. 2003 ^89^ | 59 | 7.4 | 87.5% (63.7% to 96.3%) | 79.1% (64.7% to 88.5%) | 60.9% (40.8% to 77.7%) | 94.4% (81.7% to 98.3%) | 4.18 (3.47 to 5.03) | 0.16 (0.04 to 0.58)
Ambrus et al. 1997 ^104^ | 51 | 7.5 | 50.0% (35.2% to 64.8%) | 90.9% (61.9% to 98.1%) | 95.2% (77.0% to 99.0%) | 33.3% (19.3% to 51.3%) | 5.50 4.03 to 7.50) | 0.55 (0.38 to 0.79)
Burak et al. 1994 ^105^ | 41 | 7.9 | 88.9% (71.8% to 96.0%) | 85.7% (59.8% to 95.7%) | 92.3% (75.6% to 97.7%) | 80.0% (54.7% to 92.7%) | 6.22 (5.45 to 7.11) | 0.13 (0.04 to 0.38)
Palmedo et al. 1996 ^106,^ ^107^ | 40 | 7.9 | 100.0% (83.5% to 99.8%) | 78.9% (56.5% to 91.3%) | 83.3% (64.0% to 93.1%) | 100.0% (79.2% to 99.8%) | 4.34 (4.06 to 4.64) | 0.03 (0.00 to 0.48)
Chen et al. 2000 ^108^ | 38 | 8.8 | 77.8% (54.7% to 90.8%) | 88.2% (65.4% to 96.5%) | 87.5% (63.7% to 96.3%) | 78.9% (56.5% to 91.3%) | 6.61 (5.16 to 8.46) | 0.25 (0.10 to 0.61)
Gutfilen et al. 2001 ^101^ | 27 | 6.9 | 95.7% (78.7% to 99.0%) | 50.0% (15.4% to 84.6%) | 91.7% (73.9% to 97.5%) | 66.7% (21.0% to 93.3%) | 1.91 (1.75 to 2.09) | 0.09 (0.01 to 0.75)
11 studies | 1,012 lesions | median 7.9 Moderate | Heterogeneous, no summary estimates calculated.

Figure 6. Palpable Lesions Examined by Scintimammography: Meta-Regression Model

The natural log of the likelihood ratios we calculated from data reported by each study are shown in Figure 7. Only seven out of eleven (63.6%) of the negative likelihood ratios are clearly within the possibly clinically useful or the clinically useful range (less than 0.5, or for natural logs as shown in the graph, less than -0.69). Therefore the negative likelihood ratios are not qualitatively robust, which renders the evidence unacceptably weak for supporting a conclusion about the usefulness of scintimammography in ruling out breast cancer when evaluating palpable lesions.

Figure 7. Likelihood Ratios of Scintimammography for Palpable Lesions

##### Non-Palpable Lesions

Ten studies reported results for 509 non-palpable lesions (Table 10). The data were not heterogeneous (I^2^ = 0%), so we combined them meta-analytically (Table 39, in Appendix E. Evidence Tables). The SROC curve is shown in Figure 8. At the mean of these studies'thresholds, the sensitivity of scintimammography was 68.7% and the specificity was 84.8%. At a fixed sensitivity of 95%, the specificity was 39.2%, the positive predictive value was 91.2%, and the negative predictive value was 54.1%. The prevalence of disease in this population was 57.0%. The evidence base is of moderate quality (median score 8.3), and the summary diagnostic odds ratio was stable as tested by cumulative meta-analysis. Therefore the estimates of diagnostic test performance derived from the SROC curve are of moderate stability.

Table 10 Studies of Scintimammography for Non-palpable Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Scopinaro et al. 1997 ^84^ | 166 | 8.3 | 62.3% (53.7% to 70.2%) | 91.7% (78.0% to 97.0%) | 96.4% (89.9% to 98.7%) | 40.2% (30.3% to 51.1%) | 7.48 (6.54 to 8.55) | 0.41 (0.32 to 0.52)
Mekhmandarove et al. 1998 ^86^ | 55 | 8.8 | 54.2% (35.1% to 72.0%) | 93.5% (79.1% to 98.1%) | 86.7% (61.9% to 96.0%) | 72.5% (57.1% to 83.8%) | 8.40 (5.81 to 12.13) | 0.49 (0.31 to 0.76)
Wilczek et al. 2003 ^88^ | 54 | 8.6 | 78.4% (62.7% to 88.5%) | 88.2% (65.4% to 96.5%) | 93.5% (79.1% to 98.1%) | 65.2% (44.9% to 81.1%) | 6.66 (5.62 to 7.89) | 0.25 (0.13 to 0.46)
Krishnaiah et al. 2003 ^89^ | 45 | 7.4 | 75.0% (40.8% to 92.5%) | 86.5% (71.9% to 94.0%) | 54.5% (28.1% to 78.6%) | 94.1% (80.7% to 98.2%) | 5.55 (3.72 to 8.28) | 0.29 (0.09 to 0.97)
Carril et al. 1997 ^109^ | 41 | 7.9 | 86.4% (66.5% to 95.1%) | 57.9% (36.3% to 76.7%) | 70.4% (51.5% to 84.0%) | 78.6% (52.3% to 92.2%) | 2.05 (1.74 to 2.42) | 0.24 (0.08 to 0.72)
Koukouraki et al. 2001 ^91^ | 38 | 7.5 | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 8.50 (7.29 to 9.92) | 0.12 (0.03 to 0.44)
Aguilar et al. 2001 ^110^ | 37 | 8.2 | 78.9% (56.5% to 91.3%) | 72.2% (49.1% to 87.3%) | 75.0% (53.0% to 88.6%) | 76.5% (52.6% to 90.2%) | 2.84 (2.25 to 3.58) | 0.29 (0.12 to 0.73)
Bekis et al. 2004 ^111^ | 35 | 8.3 | 84.6% (57.6% to 95.4%) | 81.8% (61.3% to 92.5%) | 73.3% (48.0% to 88.9%) | 90.0% (69.7% to 97.0%) | 4.65 (3.69 to 5.87) | 0.19 (0.05 to 0.68)
Maffioli et al. 1996 ^112^ | 24 | 7.5 | 50.0% (26.9% to 73.1%) | 90.0% (59.3% to 97.9%) | 87.5% (52.6% to 97.4%) | 56.3% (33.2% to 76.8%) | 5.00 (2.96 to 8.44) | 0.56 (0.32 to 0.98)
Palmedo et al. 1996 ^106,^ ^107^ | 14 | 8.3 | 25.0% (5.1% to 69.9%) | 100.0% (71.7% to 99.7%) | 100.0% (20.8% to 99.2%) | 76.9% (49.6% to 91.6%) | 6.60 (1.73 to 25.18) | 0.73 (0.41 to 1.32)
10 studies | 509 lesions | Median 8.3 Moderate | At mean threshold 68.7% | At mean threshold 84.8% At 95% sensitivity 39.2% | At mean threshold 85.7% At 95% sensitivity 67.4% | At mean threshold 67.2% At 95% sensitivity 54.1% | Heterogeneous, no summary estimate calculated | 0.41 (0.34 to 0.49)

Figure 8. SROC Curve of Scintimammography to Evaluate Non-Palpable Lesions

We calculated the summary likelihood ratios from the ten studies of patients referred with non-palpable lesions (see Figure 9 and also Table 39 in Appendix E. Evidence Tables for a summary of the likelihood ratio meta-analysis). The data for the negative likelihood ratios were not heterogeneous (I^2^ = 38.5%), so we combined them using meta-analysis. The summary negative likelihood ratio was 0.41 (0.34 to 0.49). The evidence base is moderate in quality, but the summary estimate is not stable by cumulative meta-analysis, and therefore is of low stability. The data for the positive likelihood ratios were hetereogeneous (I^2^ = 57.2%), and therefore could not be synthesized to produce a single summary estimate. However, 80% (eight out of ten) of the studies reported a positive likelihood ratio within the possible clinically useful range (2 or greater), supported by moderately strong evidence. Because positive likelihood ratios are not directly relevant to the indication under evaluation in this report, we did not attempt to explain the heterogeneity further.

Figure 9. Likelihood Ratios of Scintimammography to Evaluate Non-Palpable Lesions

###### [underlined: Non-Palpable Lesions with Microcalcifications]

Three studies reported outcomes for 79 non-palpable lesions with microcalcifications evident on mammography (Table 11). The data were not heterogeneous (I^2^ = 0%), so we combined them meta-analytically (Table 40, in Appendix E. Evidence Tables). Because there were only three studies, we directly pooled the diagnostic test characteristics instead of deriving a SROC curve. The summary sensitivity is 58.1%, the summary specificity is 86.1%, the summary positive predictive value is 83.3%, and the summary negative predictive value is 63.3%. The prevalence of disease in this population was 54.4%. The diagnostic test characteristics are shown graphically in Figure 10. Although the studies were of moderate quality and not heterogeneous, all of the summary estimates of test performance were not stable by cumulative meta-analysis, and are, therefore, of low stability.

Table 11 Studies of Scintimammography for Non-palpable Lesions with Microcalcifications

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Fondrinier et al. 2004 ^113^ | 45 | 7.2 | 58.3% (38.8% to 75.4%) | 81.0% (59.9% to 92.1%) | 77.8% (54.7% to 90.8%) | 63.0% (44.2% to 78.4%) | 3.06 (2.18 to 4.29) | 0.51 (0.31 to 0.86)
Maffioli et al. 1996 ^112^ | 21 | 7.5 | 53.8% (29.2% to 76.7%) | 87.5% (52.6% to 97.4%) | 87.5% (52.6% to 97.4%) | 53.8% (29.2% to 76.7%) | 4.31 (2.60 to 7.13) | 0.53 (0.28 to 1.00)
Bekis et al. 2004 ^111^ | 13 | 8.3 | 66.7% (30.1% to 89.9%) | 100.0% (64.0% to 99.6%) | 100.0% (50.5% to 99.5%) | 77.8% (45.1% to 93.3%) | 10.29 (5.92 to 17.87) | 0.38 (0.14 to 1.05)
3 studies | 79 lesions | Median 7.5 Moderate | 58.1% (43.3% to 72.9%) | 86.1% (74.8% to 97.4%) | 83.3% (72.2% to 94.5%) | 63.3% (47.6% to 79.0%) | 4.27 (3.47 to 5.26) | 0.50 (0.32 to 0.78)

Figure 10. Diagnostic Test Characteristics of Scintimammography to Evaluate Non-palpable Lesions with Microcalcifications

The likelihood ratios from these three studies are shown in Figure 11. Neither the negative or the positive likelihood ratios were heterogeneous (I^2^ = % for both), so we calculated summary estimates. The summary negative likelihood ratio is 0.50 (0.32 to 0.78), and the summary positive likelihood ratio is 4.27 (3.47 to 5.26). Neither estimate was stable by cumulative meta-analysis, and therefore the stability of the summary estimates is low.

Figure 11. Likelihood ratios of Scintimammography to Evaluate Non-Palpable Lesions with Microcalcifications

##### Large (Greater than 10 mm in diameter) Lesions

Three studies reported information about the use of scintimammography to evaluate 306 large lesions (lesions larger than 10 mm in diameter), listed in Table 12. The diagnostic odds ratios were not heterogeneous (I^2^ = 0%). Because there were only three studies, we directly pooled the diagnostic test characteristics rather than deriving a SROC curve (Table 41, in Appendix E. Evidence Tables). The summary sensitivity was 95.1%, the summary specificity was 77.8%, the summary positive predictive value was 92.2%, and the summary negative predictive value was 85.1%. The prevalence of disease in the population studied was 73.5%. The summary sensitivity was robust by cumulative meta-analysis, but the summary specificity was not. Therefore the stability of the summary estimates is low. The diagnostic test characteristics are shown graphically in Figure 12.

Table 12 Studies of Scintimammography for Lesions Larger than 10 mm

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Tofani et al. 1999 ^85^ | 257 | 8.3 | 95.2% (91.2% to 97.4%) | 79.4% (68.3% to 87.3%) | 92.8% (88.2% to 95.6%) | 85.7% (74.9% to 92.2%) | 4.63 (4.48 to 4.78) | 0.06 (0.03 to 0.11)
Imbriaco et al. 2001 ^98^ | 26 | 7.6 | 87.5% (63.7% to 96.3%) | 80.0% (48.9% to 94.0%) | 87.5% (63.7% to 96.3%) | 80.0% (48.9% to 94.0%) | 4.38 (3.64 to 5.27) | 0.16 (0.04 to 0.59)
Gutfilen et al. 2001 ^101^ | 23 | 6.9 | 100.0% (83.5% to 99.8%) | 33.3% (6.7% to 79.0%) | 90.9% (72.0% to 97.3%) | 100.0% (20.8% to 99.2%) | 1.56 (1.46 to 1.67) | 0.06 (0.00 to 1.30)
3 studies | 306 lesions | Median 7.6 Moderate | 95.1% (92.2% to 97.9%) | 77.8% (68.7% to 86.8%) | 92.2% (88.7% to 95.7%) | 85.1% (77.4% to 92.9%) | Heterogeneous, no summary estimate calculated | 0.07 (0.05 to 0.10)

Figure 12. Diagnostic Test Characteristics of the Performance of Scintimammography in Evaluating Large Lesions

We combined the likelihood ratios calculated from the three studies of large lesions (Figure 13.). The negative likelihood ratios were not hetereogeneous (I^2^ = 0%), and the summary estimate was 0.07 (0.05 to 0.10). However, the estimate was not stable by cumulative meta-analysis, and therefore its stability is low. The positive likelihood ratios were heterogeneous (I^2^ = 88.2%) and could not be directly combined. Only two of the three positive likelihood ratios fell within the possibly clinically useful range, and therefore the evidence is unacceptably weak for supporting a conclusion about the usefulness of scintimammography to rule in breast cancer. Because this indication is not directly relevant to the purposes of this report, we did not attempt to explore the heterogeneity further.

Figure 13. Likelihood Ratios of Scintimammography to Evaluate Large Lesions

##### Other Patient Groups

Two or fewer studies reported outcomes for multiple different patient subgroups (see Table 6 and Table 34 in Appendix E. Evidence Tables). For all of these subgroups, the evidence base was found to be unacceptably weak for evaluation of test performance due to the small size of the evidence bases.

##### SPECT Imaging

Four studies examined patients using both SPECT and planar imaging methods and reported the data separately for 243 lesions. For each data set, we calculated the ratio of the odds of receiving a false negative result on planar imaging and of the odds of receiving a false negative result on SPECT imaging (Table13; see also Table 42, in Appendix E. Evidence Tables). These odds ratios and their confidence intervals should not be interpreted to be precisely accurate estimates of the performance of these tests. Because the “control” group and the “experimental” group are the same patients, their measurements are not independent. Lack of independence violates many of the statistical assumptions underlying standard analysis methods. However, we can use these odds ratios to roughly estimate the relative performance of each of these tests, and therefore, while we cannot arrive at a quantitative conclusion, we may be able to derive a qualititative conclusion.

Table 13 Analysis of Studies of Scintimammography: SPECT vs. Planar Imaging

Study | N lesions | Quality score | False negatives on SPECT | False negatives on planar | Odds Ratio (95% CI) | p value of difference
Obwegeser et al. 1999 ^90^ | 103 | 7.4 | 17 | 30 | 0.48 (0.25 to 0.94) | 0.0327
Schillaci et al. 1997 ^92^ | 66 | 8.8 | 3 | 6 | 0.48 (0.11 to 2.0) | 0.309
Palmedo et al. 1996 ^106,^ ^107^ | 54 | 7.9 | 4 | 3 | 1.36 (0.29 to 6.36) | 0.697
Palmedo et al. 1997 ^58^ | 20 | 8.3 | 1 | 1 | 1.00 (0.058 to 17.12) | 1.00
4 studies | 243 lesions | Median 8.1 Moderate

Two of the studies found that planar was superior to SPECT, one found that SPECT was superior to planar, and one found no difference. Therefore the data are not qualitatively consistent or robust, and are unacceptably weak for reaching a conclusion about whether SPECT or planar imaging is less likely to miss cases of cancer. The paired diagnostic test characteristics are shown graphically in Figure 14.

Figure 14. SPECT vs. Planar Diagnostic Test Characteristics

#### Key Question 3. Are there other factors which affect the accuracy or acceptability of scintimammography?

The following narrative review identifies and discusses key factors that experts in the field believe may affect the performance of scintimammography of the breast.

##### Equipment Differences

Gamma cameras contain camera heads with collimators that route, to multiple detectors, photons that are emitted from the patient. Gamma cameras are designed to perform either planar (two-dimensional) imaging of the three-dimensional radiopharmaceutical distribution or single photon emission tomography (SPECT). SPECT is a technique that may use one, two, or three heads to create a three-dimensional representation of the administered radiopharmaceutical. Most of today's gamma cameras are capable of both planar and SPECT operation. Some experts believe that SPECT breast imaging has a higher overall accuracy compared to planar breast imaging to differentiate malignant from benign breast lesions smaller than 10 mm. ^114^ However, the literature has not revealed widespread agreement for the use of SPECT imaging for overall breast cancer detection. Because no consensus has been reached regarding SPECT's utility, specific parameters for SPECT breast imaging have not been recommended. ^115,^ ^116^

A general purpose gamma camera with the proper collimator may be used for nuclear medicine breast imaging. The collimator should be a low-energy, high-resolution (LEHR) type. LEHR collimators are used for imaging photon energies up to 1 MeV. The photopeak of ^99m^Tc is 140-keV and a symmetric 10% energy window (±5%) should be centered over the 140-keV photopeak. ^116^ However, a dedicated gamma camera with a unique collimator-detector arrangement and breast compression capabilities may offer other advantages (e.g., improved signal-to-noise ratio and spatial resolution). ^117^

##### Effect of Operator and Image Interpreter on Scintimammography

Nuclear medicine breast imaging is susceptible to a number of errors that could affect the accuracy of a diagnosis. These errors include infiltration of ^99m^Tc-sestamibi around the injection site, improper patient positioning or patient motion, and cross talk from ^99m^Tc-sestamibi uptake of the opposite breast. Nuclear medicine technologists performing breast imaging studies must be aware of the sources of these errors. ^116^

Images should be interpreted by the physician from the gamma camera's display. This permits adjustment of image contrast if necessary. Additionally, grayscale rather than color imaging is preferred. ^116^ Interpreters should consider a focal area of increased uptake positive for cancer regardless of its intensity. ^115^ Greater accuracy may be obtained when differentiating malignant from benign breast lesions when uptake patterns and sizes of lesions are considered in addition to tracer uptake levels. ^118^

##### Patient Position

Accurate prone positioning of the patient and the breast to be imaged is important. The breast to be imaged should be hanging down and a positioning device should be used to minimize patient motion. ^116,^ ^119^ Because the prone position can be very uncomfortable to the patient, which may result in movement, a reduction in total exam time should be attempted. ^120^

##### Lesion Size and Patient Characteristics

Scintimammography with ^99m^Tc-sestamibi is useful for screening women with dense breasts but has limited spatial resolution for demonstrating cancers with diameters smaller than 10 mm. ^116,^ ^121,^ ^122^ Spatial resolution is important in breast imaging since the lesions are small. The detectability of lesions that are smaller than the spatial resolution is compromised by the partial volume effect and tissue attenuation. ^119^

Sestamibi has a strong affinity for breast tumors, but may also accumulate in areas of inflammation or infection. ^123^ The sensitivity of scintimammography has been reported to be affected by type of tumor, size of tumor, and the phase of the menstrual cyle. ^14^ Scintimammography has been reported to be unaffected by the presence of a breast implant or by the density of the breast tissue. ^14^

##### Patient Safety and Comfort

Intravenous injection of ^99m^ Tc-sestamibi has been associated with very few adverse reactions. ^80^ A case of a patient without a past history of allergies, who developed a rash following administration of ^99m^Tc-sestamibi, has been reported in the literature. ^124^ Another study reports, in addition to rash development, patients experiencing a strange taste following injection of ^99m^Tc-sestamibi. ^125^ The incidence of adverse reactions to radiopharmaceuticals has been found to be 1,000 times lower than that of x-ray contrast media and other drugs administered in a hospital setting. ^126^

Other than removal of all clothing and jewelry above the waist, no special preparation is required of patients undergoing a nuclear medicine imaging study. Compared to other breast imaging procedures, nuclear medicine breast imaging takes longer to perform - forty minutes or more. ^127^ During a typical study, the patient is placed in a prone position with the breast to be imaged hanging down. ^119^ Although taut compression of the breast to be imaged is not required, prevention of cross-talk may require compression of the opposite breast. ^115,^ ^116^

A review of the literature has not revealed risks to the patient. As long as routine practices are followed, nuclear medicine breast imaging can be considered a safe exam for most patients.

##### Accreditation Factors

The Intersocietal Commission for the Accreditation of Nuclear Medicine Laboratories (ICANL) offers voluntary accreditation to facilities based on a peer review of their staff's qualifications, education, equipment, quality control, and volume of clinical procedures. ^76^

All medical and technical staff are required to meet specific minimum experience and education requirements in order for their facility to be accredited by ICANL. Options available to a facility's medical staff range from board certification in nuclear medicine to board certification in a specialty area with a minimum number of years practice and volume of studies interpreted.

The accreditation program requires the technical director and all technologists working in the facility to hold the RT(N) credential from the American Registry of Radiologic Technologists (ARRT) or the CNMT credential from the Nuclear Medicine Technology Certification Board (NMTCB). In all situations, the physician is ultimately responsible to see that the appropriate images are obtained.

### Magnetic Resonance Imaging

Magnetic resonance imaging (MRI) has been used for many medical applications since 1985. MR images are created by recording the signals generated after radio frequency excitation of nuclear particles in tissue exposed to a strong magnetic field. A contrast agent, injected into the bloodstream, accumulates in the vascular system and can aid in locating tumors by highlighting areas containing a dense blood vessel network.

#### Summary

We found that for suspicious lesions in general, at a fixed 95% sensitivity, the specificity of MRI was 62.8%. At the mean threshold of the studies, the sensitivity was 92.5%, the specificity was 72.4%, and the negative predictive value was 90.5% (for a population with a prevalence of disease of 50.3%). For lesions with microcalcifications, our analysis found that the sensitivity of MRI was 85.9%, the specificity was 75.5%, and the negative predictive value was 84.7% (for a population with a prevalence of disease of 50.3%). The stability of these estimates was moderate for lesions in general and low for lesions with microcalcifications, indicating a small (for lesions in general) or reasonable (for microcalcifications) chance that publication of new evidence could substantially change these summary estimates.

Our analysis found that the negative likelihood ratio of MRI to evaluate women referred for further evaluation of the breast was 0.16. Our findings indicate that if a woman with a suspicious lesion tests negative for breast cancer by MRI, her chance of actually having breast cancer drops from 20% ^3^ to 3.8%.

A woman in the general screening population who has a positive finding on mammography and/or physical examination has an approximately 20% chance of having breast cancer.

The authors of two other technology assessments concluded that the negative predictive value of MRI is too low for routine use to rule out breast cancer after detection of a possible abnormality. Our results agree with this conclusion.

The studies, patients, and analyses used to reach these conclusions are described in the text that follows this section. The performance of MRI in evaluating women with suspicious breast lesions is summarized in Table 14.

Table 14 Summary Test Performance of MRI

Patient subgroup | N studies | N lesions | | Sensitivity | Specificity | Prevalence (Range) | PPV | NPV | + LHR (95% CI) | - LHR (95% CI)
Suspicious breast lesion | 10 | 1289 | At mean threshold | 92.5% | 72.4% | 50.3% (25.9% to 73.1%) | 77.2% | 90.5% | Possibly clinically useful. | 0.16 (0.13 to 0.19)
| | | At 95% sensitivity | 95.0% | 62.8% | | 72.1% | 92.5% | SOE: Moderate | STE: Low
| | | STE | Moderate | Moderate | | Moderate | Moderate
Micro-calcifications | 3 | 474 | Summary estimate | 85.9% (81.5% to 90.4%) | 75.5% (70.1% to 80.9%) | 49.3% (42.3% to 64.4%) | 77.3% (71.9% to 82.7%) | 84.7% (80.1% to 89.2%) | Possibly clinically useful. | 0.20 (0.15 to 0.25)
| | | STE | Low | Low | | Low | Low | SOE: Moderate | STE: Low
BIRADS 4 or 5 | 3 | 201 | | Too weak | | 59.7% (36.0% to 78.7%) | Too weak | | Possibly clinically useful. | Too weak
| | | | | | | | | SOE: Moderate
No micro-calcifications | 1 | 470 | Too weak
Palpable lesion | 2 | 388 | Too weak
Non-palpable lesion | 2 | 487 | Too weak
Indeterminate mammogram or physical exam | 1 | 68 | Too weak
Positive by fine needle aspiration | 2 | 225 | Too weak
Lesions >1.0 cm | 2 | 38 | Too weak
Lesions ≤1.0 cm | 1 | 23 | Too weak
Patients <65 yrs of age | 2 | 77 | Too weak
Premenopausal patients | 1 | 346 | Too weak
Post-menopausal patients | 1 | 474 | Too weak

PPV = positive predictive value NPV = negative predictive value LHR = likelihood ratio Too weak = The evidence base is unacceptably weak for calculation of summary diagnostic test characteristics or evaluation of test performance SOE = Strength of evidence STE = Stability of estimate

#### Analysis and Results for Key Questions 1. and 2. Diagnostic Test Characteristics, Predictive Values, and Likelihood Ratios of MRI

##### Other Published Technology Assessments

We identified two systematic reviews of the use of MRI to evaluate women with prior clinical findings that suggest the possibility of breast cancer. The methods and conclusions of these reviews are summarized in Table 15. The authors of both systematic reviews concluded that the negative predictive value of MRI is too low for this indication, and therefore patients did not benefit from being examined by MRI after mammography.

Table 15 Other Published Technology Assessments of MRI

Study | Methods | Conclusions
The Blue Cross/ Blue Shield Technology Evaluation Program, 2004 ^128^ | Systematic review of the literature on the use of MRI to evaluate suspicious breast lesions in order to avoid biopsies. The review included 25 prospective studies and 14 retrospective studies. Reported data were described and a small, informal cost-benefit analysis was performed. | Reported sensitivity for MRI ranged from 91% to 99%; specificity ranged from 31% to 91%; and negative predictive value ranged from 56% to 99%. The authors of the review pointed out that in many of the populations studied, small breast lesions had been specifically excluded, and therefore the diagnostic performance of MRI in the clinic, where smaller lesions are often encountered, may be less accurate than predicted from these studies. The authors of the review performed a small, informal cost-benefit analysis and concluded that the negative predictive value of MRI was too low, even under the best possible conditions, to recommend the use of MRI for this indication. The potential benefit of sparing patients from unnecessary biopsy was not found to outweigh the potential harm of missed or delayed diagnosis of breast cancer.
Hrung et al. 1999 ^129^ | A systematic review focused on women presenting with either a lesion that was palpably abnormal, or a BIRADS category 4 lesion detected by mammography. The review included 16 studies published between 1994 and 1997. Quality of the studies was rated on a 10‐point scale (1 = highest quality, 10 = poorest quality). The data from the included studies was combined meta-analytically using the method of Littenburg and Moses.81 The authors then conducted a cost-effectiveness analysis. | The mean quality score of the included studies was 3.0, indicating low quality. The optimal operating point of MRI, chosen to have a sensitivity of 95%, was found to have a specificity of 67%. Breast MRI is cost-effective relative to needle core biopsy only if MRI performance achieves a sensitivity and specificity of 93%, and needle core biopsy performance is less than the best available estimates. Therefore, the authors concluded that choosing needle core biopsy instead of MRI both increased patients QALYs and lowered the average cost per patient.

##### Studies

Nineteen diagnostic cohort studies of MRI met the inclusion criteria. Characteristics of the studies and included patients are summarized in Table 43, in Appendix E. Evidence Tables. The overall quality of the studies was moderate (median score of 7.8, range 6.4 to 8.3). A common shortcoming of these studies was not reporting whether readers of tests were blinded to patient information or the results of other tests.

The enrolled patients were incompletely described. Most of the studies enrolled any patients referred for biopsy due to a suspicious lesion discovered on physical exam or mammography. A few studies had more specific enrollment criteria, such as the presence of microcalcifications, specific BIRADS categories after mammography, or specific lesion sizes. The patients ranged in age from 18 to 85. Reported mean ages ranged from 48.4 to 58, suggesting that the patient populations studied are younger than the typical breast cancer population. Only one of the 19 studies reported information on the percentage of patients 65 years of age or older (8% of 49 patients; Imbriaco et al. 2001 ^98^ ).

The diagnostic test characteristics we calculated from data reported by each of the studies are presented in Table 45, in Appendix E. Evidence Tables.

##### Patients Referred for Evaluation of Suspicious Breast Lesions

Ten studies reported results for 1289 lesions in patients referred for further evaluation of a suspicious breast lesion (abnormal mammogram and/or abnormal physical examination and/or abnormal ultrasound examination), listed in Table 16. The data were not heterogeneous (I^2^ = 34%), so we combined them meta-analytically (Table 46 in Appendix E. Evidence Tables). The SROC curve is shown in Figure 15. At the mean threshold used in these studies, the sensitivity of MRI was 92.5% and the specificity was 72.4%. At a fixed sensitivity of 95%, the specificity was 62.8%, the positive predictive value was 72.1%, and the negative predictive value was 92.5%. The prevalence of disease in this population was 50.3%. The evidence base is of moderate quality (median score 7.6), and the summary diagnostic odds ratio was stable as tested by cumulative meta-analysis. Therefore our estimates of diagnostic test performance are of moderate stability.

Table 16 Studies of MRI for Evaluation of Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Bluemke et al. 2004 ^130^ | 821 | 7.8 | 88.1% (84.6 to 91.1) | 67.4% (62.7 to 71.9) | 72.4% (68.2 to 76.3) | 85.4% (81.1 to 89.0) | 2.70 (2.61 to 2.80) | 0.18 (0.13 to 0.23)
Heiberg et al. 1996 ^131^ | 81 | 6.4 | 100.0% (84.2% to 99.8%) | 73.3% (60.9% to 82.8%) | 56.8% (40.9% to 71.3%) | 100.0% (91.8% to 99.9%) | 3.61 (3.39 to 3.85) | 0.03 (0.00 to 0.48)
Tiling et al. 1997 ^95^ | 56 | 7.4 | 90.9% (76.3% to 96.7%) | 52.2% (33.0% to 70.7%) | 73.2% (58.0% to 84.2%) | 80.0% (54.7% to 92.7%) | 1.90 (1.71 to 2.12) | 0.17 (0.06 to 0.55)
Palmedo et al. 1996 ^96^ | 56 | 7.9 | 92.6% (76.4% to 97.8%) | 20.7% (10.0% to 38.5%) | 52.1% (38.3% to 65.5%) | 75.0% (40.8% to 92.5%) | 1.17 (1.05 to 1.30) | 0.36 (0.08 to 1.62)
Obdejin et al. 1996 ^132^ | 54 | 7.9 | 90.9% (76.3% to 96.7%) | 66.7% (45.3% to 82.7%) | 81.1% (65.7% to 90.4%) | 82.4% (58.8% to 93.6%) | 2.73 (2.45 to 3.04) | 0.14 (0.04 to 0.42)
Hachiya et al. 1991 ^133^ | 52 | 7.5 | 94.7% (82.5% to 98.4%) | 100.0% (78.0% to 99.8%) | 100.0% (90.1% to 99.9%) | 87.5% (63.7% to 96.3%) | 28.08 (25.86 to 30.48) | 0.07 (0.02 to 0.22)
Imbracio et al. 2001 ^98^ | 49 | 7.6 | 96.0% (80.2% to 99.1%) | 75.0% (55.0% to 87.8%) | 80.0% (62.6% to 90.4%) | 94.7% (75.1% to 98.8%) | 3.84 (3.54 to 4.16) | 0.05 (0.01 to 0.37)
Walter et al. 2003 ^57^ | 42 | 7.9 | 89.5% (68.4% to 96.8%) | 73.9% (53.4% to 87.3%) | 73.9% (53.4% to 87.3%) | 89.5% (68.4% to 96.8%) | 3.43 (2.94 to 4.00) | 0.14 (0.04 to 0.54)
Hienisch et al. 2003 ^56^ | 40 | 7.2 | 92.0% (74.8% to 97.6%) | 73.3% (48.0% to 88.9%) | 85.2% (67.4% to 93.9%) | 84.6% (57.6% to 95.4%) | 3.45 (3.07 to 3.87) | 0.11 (0.03 to 0.43)
Cecil et al. 2001 ^134^ | 38 | 7.2 | 91.3% (73.0% to 97.4%) | 80.0% (54.7% to 92.7%) | 87.5% (68.8% to 95.5%) | 85.7% (59.8% to 95.7%) | 4.57 (4.02 to 5.18) | 0.11 (0.03 to 0.42)
10 studies | 1289 lesions | median 7.6 | At mean threshold 92.5% | At mean threshold 72.4% | At mean threshold 77.2% | At mean threshold 90.5% | Heterogeneous, no summary estimate calculated | 0.16 (0.13 to 0.19)
| | Moderate | | At 95% sensitivity 62.8% | At 95% sensitivity 72.1% | At 95% sensitivity 92.5%

Figure 15. SROC of MRI for Evaluation of Suspicious Breast Lesions

We calculated the summary likelihood ratios from the ten studies of patients referred for evaluation of suspicious breast lesions, shown graphically in Figure 16. The data for the negative likelihood ratios were not heterogeneous (I^2^ = 0%), so we meta-analytically combined them (Table 46, in Appendix E. Evidence Tables). The summary negative likelihood ratio is 0.16 (95% CI 0.13 to 0.19). The evidence base is of moderate quality, but the summary negative likelihood ratio was not stable as tested by cumulative meta-analysis. Therefore the stability of the summary estimate is low. The data for the positive likelihood ratio were heterogeneous (I^2^ = 97%), and therefore we did not attempt to compute a summary estimate. However, eight out of ten of the individual studies positive likelihood ratios are within the possibly/clinically useful range (2 or greater) and, therefore a qualititative conclusion that MRI is possibly clinically useful in detecting breast cancer, supported by a moderate strength of evidence, can be reached. Because positive likelihood ratios are not directly relevant to the purpose of MRI for this report, we did not attempt to explain the heterogeneity further.

Figure 16. Likelihood Ratios of MRI for Evaluation of Suspicious Breast Lesions

##### Lesions with Microcalcifications

Three studies reported results of MRI examination of 474 lesions with microcalcifications (Table 17). The data were not hetereogeneous (I^2^ = 28%). Because there were only three studies, we did not compute a SROC. Instead, we separately combined the test characteristics from these three studies using meta-analysis (Table 47, in Appendix E. Evidence Tables). The pooled sensitivity was 85.9% (81.5% to 90.4%), and the pooled specificity was 75.5% (70.1% to 80.9%), as is shown in Figure 17. The pooled positive predictive value is 77.3% and the pooled negative predictive value is 84.7%. The prevalence of disease in this population was 49.3%. The evidence base is of moderate quality (median score 7.8), but the summary test characteristics were not stable as tested by cumulative meta-analysis. Therefore the estimates of diagnostic test performance are of low stability.

Table 17 Studies of MRI for Lesions with Microcalcifications

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Bluemke et al. 2004 ^130^ | 300 | 7.8 | 83.5% (75.8 to 89.5) | 75.7% (68.6 to 81.9) | 71.6% (63.6 to 78.7) | 86.2% (79.7 to 91.2) | 3.44 (3.18 to 3.71) | 0.22 (0.15 to 0.33)
Del Maschio et al. 2002 ^135^ | 134 | 6.5 | 88.5% (80.1% to 93.6%) | 66.7% (52.5% to 78.3%) | 82.8% (73.8% to 89.1%) | 76.2% (61.4% to 86.4%) | 2.66 (2.46 to 2.86) | 0.17 (0.09 to 0.32)
Nakahara et al. 2001 ^136^ | 40 | 7.9 | 90.0% (69.7% to 97.0%) | 95.0% (76.1% to 98.9%) | 94.7% (75.1% to 98.8%) | 90.5% (70.9% to 97.1%) | 18.00 (15.55 to 20.83) | 0.11 (0.03 to 0.39)
3 studies | 474 lesions | median 7.8 Moderate | Summary estimate 85.9% (81.5 to 90.4) | Summary estimate 75.5% (70.1 to 80.9) | Summary estimate 77.3% (71.9 to 82/7) | Summary estimate 84.7% (80.1 to 89.2) | Heterogeneous, no summary estimate calculated | Summary estimate 0.20 (0.15 to 0.25)

Figure 17. Sensitivity and Specificity of MRI for Lesions with Microcalcifications

We calculated the summary likelihood ratios from the three studies of patients with lesions with microcalcifications. The results of the analysis are shown in Figure 18. The data for the positive likelihood ratio were heterogenous (I2 = 81.4%) and therefore were not directly combined. However, all three of the positive likelihood ratios (100%) were within the possibly clinically useful range (2 or larger). The data for the negative likelihood ratio were not heterogeneous (I2 = 0.0%). The summary negative likelihood ratio is 0.20 (0.15 to 0.25). This evidence base is of moderate quality, but the summary negative likelihood estimate was not stable by cumulative meta-analysis, and therefore the estimate of the summary negative likelihood ratio is of low stability.

Figure 18. Likelihood Ratios of MRI for Lesions with Microcalcifications

##### Lesions Scored BIRADS 4 or 5 after Mammography

Three studies reported outcomes for 201 lesions scored as BIRADS 4 or 5 after mammography (Table 18). The data were heterogeneous (I^2^ = 70%) and therefore we did not combine them (Table 48, in Appendix E. Evidence Tables). Because there are only three studies, meta-regression cannot be performed to explore the heterogeneity. Therefore the evidence is unacceptably weak for calculating summary diagnostic test characteristics. All three studies reported a positive likelihood ratio within the possibly clinically useful range (2 or larger). However, only one of these studies reported a negative likelihood ratio that was within the possibly clinically useful range (0.5 or less). From this, we can conclude that MRI may be possibly clinically useful for detecting cancer when evaluating lesions scoring a BIRADS 4 or 5 after mammography, but the evidence is unacceptably weak to support a conclusion as to whether MRI may be clinically useful for ruling out cancer when evaluating lesions scoring a BIRADS 4 or 5.

Table 18 Studies of MRI for Lesions of BIRADS 4 or 5

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Malich et al. 2001 ^137^ | 90 | 7.9 | 98.1% (90.1% to 99.6%) | 80.6% (64.9% to 90.1%) | 88.3% (77.7% to 94.1%) | 96.7% (83.1% to 99.3%) | 5.05 (4.87 to 5.24) | 0.02 (0.00 to 0.16)
Knopp et al. 2003^138^ | 61 | 8.3 | 70.8% (56.8% to 81.7%) | 76.9% (49.6% to 91.6%) | 91.9% (78.5% to 97.1%) | 41.7% (24.6% to 61.2%) | 3.07 (2.56 to 3.68) | 0.38 (0.22 to 0.65)
Huange et al. 2004 ^139^ | 50 | 7.1 | 100.0% (82.0% to 99.8%) | 62.5% (45.2% to 77.0%) | 60.0% (42.3% to 75.3%) | 100.0% (83.5% to 99.8%) | 2.57 (2.39 to 2.77) | 0.04 (0.00 to 0.66)
3 studies | 201 lesions | median 7.9 Moderate | Heterogeneous, no summary estimates calculated.

##### Other Patient Groups

Two or fewer studies reported results for other patient subgroups (see Table 14 and Table 45 in Appendix E. Evidence Tables). For all of these subgroups, the evidence bases were unacceptably weak for evaluation of test performance due to their small sizes.

#### Key Question 3. Are there other factors that affect the accuracy or acceptability of the test?

The following narrative review identifies and discusses key factors that experts in the field believe may affect the performance of MRI of the breast.

##### Equipment Differences

The capability of MRI technology is constantly being improved. Apart from the room and the magnet itself, most other MRI components can be replaced and upgraded without major disruptions to service. However, an upgrade can entail considerable cost, and the long useful lifespan of MRI equipment can discourage frequent upgrading of core equipment. Therefore, age of an MRI installation is not necessarily an indicator of outdated equipment. A wide range of equipment performance exists between MRI installations.

Comparing equipment specification and performance is not straightforward in MRI due to the complex relationship between the factors that control image quality. ^140^ The following equipment-related factors potentially affect the performance of an MRI system used in breast imaging: magnet field strength, temporal and spatial resolution, surface coils, fat suppression, and contrast media.

##### Magnet Strength

Magnet strength varies from 0.5T to 3.0T. The primary reason for using higher field strength is to increase the signal available. Increasing the signal allows higher spatial resolution images or faster image acquisition times. However, the magnet strength also modifies the magnetic relaxation properties and therefore the contrast in images. Therefore image acquisition parameters must be significantly adjusted when using different field strengths. Also, these factors must be recognized when comparing the diagnostic performances as a function of field strength. MRI systems that use field strengths below 1 T are usually open gantries and are primarily used for patients who cannot be accommodated inside the bores of higher field strength magnets. Another advantage of the open magnets is the easier access when performing invasive procedures, such as biopsies. So, despite the drawbacks of lower field strength (reduced signal to noise ratio, longer imaging times, and unavailability of fat suppression), there is considerable interest in using low field-strength systems. ^141^ Overall, the use of 1.5 T and 1.0 T systems for breast MRI is well established, but lower field strength systems are not.

##### Temporal and Spatial Resolution

Once detected on MRI, two aspects of a breast lesion are of interest to a radiologist: the dynamics of the contrast agent in the lesion and its morphology. Therefore, both temporal and spatial resolution are important. Since MRI entails a tradeoff between acquisition time and spatial resolution, determining the most effective tradeoff is necessary. ^142^

Of interest in the dynamic study is the rate of contrast enhancement and subsequent wash-out. The time scale for this process is about eight minutes, with the first minute containing important information. Specificity is improved if the temporal resolution is increased from two-minutes to one-minute acquisitions. ^143^ Even more information would be available if the first tens of seconds after contrast enhancement could be captured. ^144^

Commercial MRI systems today can achieve a one to two minute image acquisition time (i.e., temporal resolution) in bilateral breast studies. ^145^ – ^147^ To achieve this a 3D image T1 weighted gradient echo pulse sequence with contiguous 2 to 3 mm slices is used. Two dimensional acquisition would be faster, except the slices would not be contiguous. ^145^ Therefore, the ability to acquire 3D images is required for breast MRI. To obtain this level of temporal resolution requires rapid pulse sequences, which necessitate high specification field gradients (i.e., power and slew rate). ^144^ The precise specification is not crucial. Instead, it is preferred that a system can acquire full 3D (3mm slice width) images sets of both breasts (i.e., either axial or coronal views) with medium resolution (256 x 256 acquisition matrix) with a temporal resolution of two minutes, or faster. ^144^

Also, in addition to the T1 weighted dynamic acquisition, a high spatial resolution T2 weighted image is useful to help distinguish morphology and improve overall interpretation. ^146,^ ^148^ – ^150^ Since the acquisition time is not critical for this, most MR equipment is capable of this type of acquisition.

##### Surface Coils

Surface coils are routinely used in MRI to increase the efficiency of signal detection and, by extension, the image quality. Dedicated breast coils have been available for some time and are considered a prerequisite for breast imaging. ^151^ The dedicated breast coils allow the patient to lie prone with her breasts in close proximity with the coils. Some coils contain some means to immobilize the breasts with compression. The compression reduces the volume to be imaged (and therefore reduces image acquisition time) and moves the coils closer to the tissue and helps prevent patient movement (so image quality is improved). ^145,^ ^152^

Most dedicated breast coils enable bilateral imaging without having to reposition the patient and repeat the contrast administration. Bilateral imaging allows radiologists to compare each breast. ^146^ Therefore, bilateral breast coils are preferred.

The number of individual elements within a coil affects signal to noise ratio. In general, increasing the number of elements improves signal to noise ratio. ^145,^ ^153,^ ^154^ However, the possible gain in signal to noise ratio is limited because the coils must get smaller as the number of elements is increased. In breast coils, a two element (per breast) phased array is preferred. ^145^ Phased array coils are standard for modern dedicated breast coils. Also, multiple elements combined with multiple channel processing enables parallel imaging techniques to be used, which enable faster imaging. However, in breast imaging parallel imaging is not widely used. ^155^

##### Fat Suppression

In contrast-enhanced breast MRI the issue of fat suppression is particularly important due to the fact that the signals from fat and the contrast enhanced lesions can be similar. ^145^ The fat signal can be suppressed by simple image subtraction or with a fat-suppressing pulse sequence. The image subtraction technique simply uses a pre-contrast image to subtract the fat signal from the subsequent images. The difficulty with this approach is the susceptibility to artifacts caused by patient motion. Breast compression can be used to ameliorate the problem. Fat-suppression pulse sequences rely on either a saturation pulse, which prolongs the image time, or on a spectrally selective inversion technique. ^156^ The availability and effectiveness of a fat-suppression methodology will depend on the MRI system. For example, pulse sequence-based fat suppression requires high field homogeneity, which is compromised on open MRI systems. ^157^ So, pulse sequence derived fat suppression is not always possible, and the subtraction method must be used. The subtraction method is acceptable providing the patient can remain motionless for ten to fifteen minutes.

##### Contrast Media

A number of non-specific contrast agents have been used widely in MRI since the mid 1980s. Despite molecular differences, the resulting contrast enhancement and safety profile is similar for the commonly used gadolinium chelates. ^158^ However, a recently approved agent, gadobenate dimeglumine (MultiHance), has also been used. Gadobenate dimeglumine has approximately double the T1 relaxivity of standard gadolinium chelates, which, theoretically, translates to higher contrast enhancement. ^138^ A multi-center comparison of gadobenate dimeglumine and gadopentetate dimeglumine found that gadobenate dimeglumine may have advantages when assessing the contrast intensity time curves. ^138^ However, the authors point to the need for further studies due to an imbalance in the number of malignant and nonmalignatant lesions in each patient group. In another comparison of gadopentetate dimeglumine (0.1 mmol/kg) to gadobenate dimeglumine (0.05 to 0.2 mmol/kg), the authors found significantly higher radiologist image quality scores of breast vascularity for the gadobenate dimeglumine. ^159^ Therefore, whereas traditional contrast agents can be regarded as interchangeable and functionally equivalent, newer agents may be advantageous. Additional clinical trials are required to confirm these findings.

##### Effect of Operator and Image Interpreter on MRI

MR images are susceptible to a number of artifacts that could cause image distortion and false interpretations. In particular, breast MR images are prone to artifacts caused by sternal wires and prosthesis filling valves. ^160^ Also, respiratory motion can be a problem, although when the patient is prone the effect is reduced. ^160^ Technologists conducting MRI breast studies must be aware of the potential problems and be able to compensate accordingly.

Breast imaging is a specialized area for radiologists. Breast MR image interpretation is not simply a matter of characterizing the contrast enhancement curve. ^161^ Since breast MR images should be interpreted in conjunction with other imaging studies, familiarity with those images is required. ^146^

Studies have shown that automating the analysis can complement the interpretation and increase accuracy and efficiency. ^162^ – ^165^ For example, one factor that helps decrease variability is the automatic positioning of the region used to calculate the contrast dynamics. ^166^ Various automated approaches are commercially available to aid radiologists. These computer-based tools may prove useful for a number of reasons; they could save radiologist time, reduce subjectivity, and decrease inter- and intra-observer variability. So, the use of automatic image analysis reduces the MRI-specific experience necessary to interpret exams accurately and reproducibly in a shorter time. ^163^

##### Protocol Selection

While all suppliers of MRI equipment provide suggested protocols for different examination types, it is common for users to customize these. The degree of protocol customization largely depends on the clinical users, both radiologists and technologists. Even in tightly controlled studies with a limited number of institutions all using equipment supplied by the same manufacturer, differences in technique were observed. ^167^ Therefore, standardization of protocols can be difficult. Sometimes protocols should be slightly modified to accommodate differences in patients.

##### Patient Position

Using dedicated breast coils helps optimize the positioning of the patient. However, it is important that the breast is pulled away from the chest wall and, if compression is used, that contrast enhancement is not impaired by impeded blood flow. ^156,^ ^168^

##### Contrast Media Administration

When contrast is taken up by a lesion, one of three characteristic enhancement and wash-out curves are usually observed: continuous enhancement, rapid enhancement followed by a plateau, or rapid enhancement followed by rapid wash-out. Rapid wash-out is indicative of malignancy. ^161^ However, there is no clear division between the three responses. A prolonged administration or poor synchronization between the injection and image acquisition of contrast media may affect the contrast enhancement versus time curve. ^156^ So, minimizing the number of variables is preferred. Standardization of contrast injection and synchronization with image acquisition is best achieved with a powered injector. ^146^ Also, the operator must ensure that all preparation is carried out before the contrast administration. For example, all patient-specific tuning and shimming must be made before administering the bolus of contrast agent to avoid delays. ^145^

MRI does not directly visualize the contrast agent; instead the effects of the contrast agent on the magnetic properties of the tissue are visualized. Therefore, the relationship between contrast concentration and image quality is complex. ^138,^ ^169^ When using conventional gadolinium contrast agents, the dose does not appear to be a major factor when used in the normal range (0.1 to 0.2 mmol/kg). However, more data is required for newer contrast agents.

##### Patient Characteristics

In premenopausal women, the normal parenchyma can demonstrate enhancement that can decrease the specificity of breast MRI studies. ^170,^ ^171^ The amount of enhancement depends on the stage in the menstrual cycle. Therefore, an MRI study should be scheduled during the second week of the menstrual cycle when proliferative changes are at their lowest level and operators should verify this.

##### Patient Safety and Comfort

The fact that MRI does not use any ionizing radiation is one of the reasons for its widespread use. However, the magnetic field can cause problems and most exams require the patient to lie still for extended periods in a confined and loud environment. Also, all breast MRI exams require the administration of contrast media, but the gadolinium-based contrast agents used in MR imaging have been demonstrated to be safe and well tolerated. ^144,^ ^172^

A number of hazards exist when a patient is undergoing an MRI exam. Examples include: patient heating, pacemaker malfunction, dislodgment of metallic implants, peripheral nerve stimulation, acoustic noise, and radio frequency induced burns. ^173^ – ^178^ Precautions are already taken at MRI facilities to routinely screen patients for possible contraindications. Patients are routinely asked to wear earplugs and are given an emergency call button. Technologists are trained to avoid situations in which burns may occur. Also, the FDA 510(k) guidelines for MRI equipment require that known hazards (e.g., patient heating) are accounted for in the system's design. However, it is important that users maintain up-to-date information as new devices and implants are used, and as MRI systems develop. ^179,^ ^180^ There is no reason to suspect that MR breast imaging is any different from other MRI exams with respect to safety.

Some aspects of the MRI environment, such as the safety of static magnetic fields and radio frequency radiation, remain issues of some debate. However, at the levels to which patients are exposed during routine MRI scanning, no conclusively determined serious adverse long-term effects have been identified. ^181^ – ^184^ Therefore, so long as routine precautions are followed, breast MRI can be considered a safe exam for most patients.

The requirement for a large-volume homogenous magnetic field for fat suppression means that closed-bore systems are preferred. Therefore, extreme claustrophobia and patient body habitus may prevent a small percentage of patients from undergoing breast MRI studies. ^146^ Dedicated breast coils allow most patients to be positioned comfortably. A search for reports of patient discomfort did not find any reports of severe discomfort. In fact, in order to decrease patient motion, it is important that the patient be as comfortable as possible. ^160^ Breast compression does increase the level of discomfort, but the amount is not significant, particularly when compared to the compression that is exerted during x-ray mammography exams.

##### Accreditation Factors

General-purpose MRI systems are cleared for marketing by United States Food and Drug Administration (FDA) under the 510(k) process. Accessories such as breast coils are cleared separately, also under the 510(k) process. Imaging devices are usually not cleared for specific indications; they are cleared for marketing for all indications in the entire body or in specified parts of the body.

There is no nationwide compulsory accreditation for MRI facilities. The American College of Radiology does administer a voluntary accreditation program. ^185^ However, the quality, capability, and performance of MRI systems varies widely. For example, when the American College of Radiology first started its voluntary MRI accreditation program, it reported that “59% of facilities failed to qualify (for accreditation) at their first try” due to poor image quality. ^185^ The failures were attributed to poor homogeneity and calibration. The daily tests used by some manufacturers are not sufficient to ensure acceptable image quality. Therefore, the ACR accreditation can help ensure acceptable image quality.

### Ultrasound

Ultrasound waves are high-frequency sound waves that reflect at boundaries between tissues with different acoustic properties. Ultrasound is commonly used to distinguish between solid breast lesions and cysts and to guide biopsy needles; ^186^ these two uses are outside the scope of this report, and are not addressed here. Here, we address the use of ultrasound to examine solid lesions for signs of malignancy.

#### Summary

We found that for suspicious lesions in general, the sensitivity of ultrasound examination was 86.1%, the specificity was 66.4%, and the negative predictive value was 93.3% (for a population with a prevalence of disease of 25.7%). The stability of these estimates is moderate, indicating a small chance that publication of new evidence could substantially change these estimates.

Our analysis found that the negative likelihood ratio of ultrasound to evaluate women referred for suspicious breast lesions was 0.21. This result indicates that if a woman with a suspicious lesion is diagnosed as not having cancer by ultrasound, her chance of actually having cancer drops from 20% ^4^ to 5.0%.

A woman in the general screening population who has a positive finding on mammography and/or physical examination has an approximately 20% chance of having breast cancer.

The studies, patients, and analyses used to reach these conclusions are described in the text that follows this section. The performance of ultrasound in evaluating women with suspicious breast lesions is summarized in Table 19. The estimates of summary diagnostic test characteristics are of moderate or low stability, indicating that there is a small (moderate stability) to reasonable (low stability) chance that the magnitude of the estimate could substantially change as a result of the publication of new evidence. Therefore regular monitoring of the literature is recommended.

Table 19 Summary Test Performance of Ultrasound

Patient subgroup | N studies | N lesions | Sensitivity (95% CI) | Specificity (95% CI) | Prevalence (95% CI) | PPV (95%CI) | NPV (95% CI) | + LHR (95% CI) | - LHR (95% CI)
Suspicious breast lesion | 3 | 3,258 | 86.1% (83.8% to 88.5%) | 66.4% (64.5% to 68.3%) | 25.7% (24.2% to 27.2%) | 47.0% (43.5% to 50.4%) | 93.3% (92.3% to 94.3%) | Possibly clinically useful | 0.21 (0.19 to 0.24)
| | | Stability of estimate: Moderate | Stability of estimate: Moderate | | Stability of estimate: Moderate | Stability of estimate: Moderate | Strength of evidence: Moderate | Stability of estimate: Low
Palpable lesion | 5 | 2,090 | Not calculated due to heterogeneity | | 23.7% to 73.1% | Not calculated due to heterogeneity | Not calculated due to heterogeneity | Possibly clinically useful | Possibly clinically useful
| | | | | | | | Strength of evidence: Moderate | Strength of evidence: Moderate
Lesions ≤10 mm | 1 | 135 | The body of evidence is unacceptably weak for evaluation of test performance.
Lesions >10 mm | 1 | 1,068 | The body of evidence is unacceptably weak for evaluation of test performance.
Patients >65 yrs of age | 0 | 0 | No evidence
Patients <65 years of age | 0 | 0 | No evidence

PPV = positive predictive value NPV = negative predictive value LHR = likelihood ratioTable 20. Studies of Ultrasound for Evaluation of Suspicious Breast Lesions

#### Analysis and Results for Key Questions 1. and 2. Diagnostic Test Characteristics, Predictive Values, and Likelihood Ratios of Ultrasound

##### Previously Published Technology Assessments

Flobbe et al. published a decision analysis model comparing different strategies for managing patients presenting with palpable breast masses in 2004. ^187^ Their decision model was based entirely on data from a single clinical study they previously authored (Flobbe et al. ^188^ ). This particular clinical study by Flobbe et al. was excluded from the current report because it was confounded. Findings from the ultrasound exams influenced the way each patient was managed, including whether the patient was evaluated by biopsy. Therefore the data from Flobbe et al. can not be used to accurately estimate the diagnostic characteristics of ultrasound. Because the decision model developed by Flobbe et al. was based entirely upon this confounded study, the results of the decision model are also suspect and will not be discussed here.

##### Studies

Eight diagnostic cohort studies of ultrasound met the inclusion criteria. Characteristics of the studies and included patients are summarized in Table 49, in Appendix E. Evidence Tables. The quality of the studies was moderate (median score of 7.4, range 6.9 to 7.9). Despite the fact that the accuracy of ultrasound has been reported to be very operator- dependent, only one study (Hachiya et al. ^133^ ) accounted for inter-operator differences in its design. Other common flaws in these studies were not reporting whether readers of tests were blinded to patient information or the results of other tests, not reporting sources of funding, and not reporting details about patient selection (whether the patients were consecutively enrolled or not).

The enrolled patients were incompletely described. Inclusion criteria were often incompletely described, and no demographic information aside from age was reported by any of the studies. Five of the eight studies included only women with palpable lesions. The patients ranged in age from 14 to 98. Reported mean ages range from 38.7 to 54, suggesting that the patient populations studied are younger than the typical breast cancer population. None of the studies reported information about the percentage of patients 65 years of age or older.

The diagnostic test characteristics we computed from data on each of these studies are summarized by study in Table 51, in Appendix E. Evidence Tables.

##### Patients Referred for Evaluation of Suspicious Breast Lesions

Three studies reported results for 3,258 lesions in patients referred for further evaluation of suspicious breast lesions (abnormal mammogram and/or physical examination), listed in Table 20. The data were not heterogeneous (I^2^ = 47%) but, because there are only three studies, we did not derive a SROC curve. Instead, we seperately combined the sensitivities and specificities from these studies (see Table 52 in Appendix E. Evidence Tables). The pooled sensitivity was 86.1% (83.8% to 88.5%) and the pooled specificity 66.4% (64.5% to 68.3%), as shown in Figure 19. The pooled positive predictive value is 47% and the negative predictive value is 93.3%. The prevalence in this population was 25.7%. This evidence base is of moderate quality, and the summary test characteristics were stable as tested by cumulative meta-analysis. Therefore the stability of the estimate of diagnostic test performance is moderate.

Table 20 Studies of Ultrasound for Evaluation of Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Meyberg-Solomayer et al. 2004 ^189^ | 65 | 7.4 | 100.0% (91.4 to 99.9) | 56.5% (36.8 to 74.3) | 80.8% (68.0 to 89.1) | 100.0% (76.7 to 99.8) | 2.3 2.3 | 0.02 (0.00 to 0.33)
Malich et al. 2001 ^137^ | 100 | 7.9 | 77.4% (65.5 to 86.0) | 89.5% (75.7 to 95.7) | 92.3% (81.7 to 96.9) | 70.8% (56.8 to 81.7) | 7.4 (6.4 to 8.4) | 0.25 (0.16 to 0.41)
Chao et al.1999 ^190^ | 3,093 | 7.5 | 86.1% (83.4 to 88.4) | 66.1% (64.2 to 68.0) | 44.1% (41.5 to 46.7) | 93.9% (92.6 to 94.9) | 2.5 (2.5 to 2.6) | 0.21 (0.18 to 0.25)
3 studies | 3,258 lesions | median 7.6 Moderate | Summary estimate 86.1% (83.8 to 88.5) | Summary estimate 66.4% (64.5 to 68.2) | Summary estimate 47.0% (43.6 to 50.4) | Summary estimate 93.3% (92.3 to 94.2) | Heterogeneous, no summary estimate calculated | Summary estimate 0.21 (0.24 to 0.19)

Figure 19. Sensitivity and Specificity of Ultrasound for Evaluating Suspicious Breast Lesions

We calculated the summary likelihood ratios from the three studies of patients referred for suspicious breast lesions (see Figure 20). The data for the positive likelihood ratio were heterogenous (I^2^ = 67%) and, therefore, we did not perform a meta-analysis. All three of the reported positive likelihood ratios were within the possibly/clinically useful range (2 or greater). The data for the negative likelihood ratio were not heterogenous (I^2^ = 38%), and the summary negative likelihood ratio is 0.21 (0.24 to 0.19). However, the summary estimate was not stable by cumulative meta-analysis, so the stability of the estimate is low.

Figure 20. Likelihood Ratios of Ultrasound for Evaluating Suspicious Breast Lesions

##### Patients Referred After Detection of Palpable Lesions

Five studies reported results for patients referred for further evaluation after discovery of 2,090 palpable breast lesions (listed in Table 21). The data were heterogeneous (I^2^ = 90%) and therefore not directly combinable (Table 53, in Appendix E. Evidence Tables). We performed a meta-regression of the diagnostic odds ratio in order to identify possible causes of the heterogeneity. The results of the meta-regression, including the variables we examined, are summarized in Table 54, in Appendix E. Evidence Tables. None of the variables tested had a statistically significant correlation with the diagnostic odds ratio. Because the heterogeneity could not be explained, we did not compute a summary estimate of diagnostic test performance. The individual study estimates of diagnostic test performance are shown in Figure 21.

Table 21 Studies of Ultrasound for Palpable Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Chen et al. 2004 ^191^ | 1,203 | 6.9 | 79.3% (75.0 to 83.0) | 89.3% (87.0 to 91.2) | 78.1% (73.8 to 81.9) | 90% (87.7 to 91.8) | 7.4 (7.1 to 7.8) | 0.23 (0.19 to 0.28)
Perre et al. 1994 ^192^ | 400 | 7.4 | 97.7% (94.2 to 99.1) | 93.4% (89.3 to 95.9) | 91.9% (87.0 to 95.0) | 98.1% (95.3 to 99.2) | 14.7 (14.4 to 15.1) | 0.02 (0.01 to 0.06)
van Oord 1991 ^193^ | 232 | 7.2 | 98.7% (92.8 to 99.7) | 67.3% (59.6 to 74.2) | 59.5% (50.8 to 67.7) | 99.1% (94.8 to 99.8) | 3.0 (2.9 to 3.1) | 0.02 (0.00 to 0.14)
McNicholas 1993 ^194^ | 203 | 7.8 | 88.9% (77.7 to 94.7) | 87.2% (80.9 to 91.6) | 71.6% (59.9 to 81.0) | 95.6% (90.7 to 97.9) | 7.0 (6.3 to 7.7) | 0.13 (0.06 to 0.27)
Hachiya 1991 ^133^ | 52 | 7.1 | 97.4% (86.3 to 99.4) | 100.0% (78.0 to 99.8) | 100.0% (90.3 to 99.9) | 93.3% (69.9 to 98.6) | 28.9 (27.1 to 30.7) | 0.04 (0.01 to 0.19)
5 studies | 2,090 lesions | median 7.2 Moderate | Heterogeneous, no summary estimates calculated.

Figure 21. Diagnostic Test Characteristics of Ultrasound Examination of Palpable Lesions

The likelihood ratios from the five studies are shown in Figure 22. Due to the heterogeneity of the data, we did not attempt to pool the likelihood ratios. All of the data points and confidence intervals for both the positive and negative likelihood ratios are within the possibly/clinically useful ranges (2 or greater for the positive likelihood ratio, 0.5 or less for the negative likelihood ratio), suggesting that ultrasound may possibly be clinically useful for evaluating palpable lesions. The median quality of the studies is moderate, and the data are qualitatively robust, therefore the strength of the evidence is moderate.

Figure 22. Likelihood Ratios of Ultrasound for Palpable Lesions

##### Patients with Specific Lesion Sizes

Only one study reported results for lesions of different sizes. Because only one study of moderate quality reported data on these subgroups, the evidence was unacceptably weak for evaluation of test performance.

##### Patients Older than 65 Years of Age

None of the studies reported information on the percentage of patients older than 65, nor did any of the studies report diagnostic test characteristics for subgroups defined by age. No studies reported outcomes for any other subgroups of patients.

#### Key Question 3. Are there other factors which affect the accuracy or acceptability of ultrasound?

The following narrative review identifies and discusses key factors that experts in the field believe may affect the performance of ultrasound imaging of the breast.

##### Equipment Differences

The quality of a breast ultrasound image depends on the specifications of the ultrasound scanner; in particular, the type of transducer and the transducer's frequency. Breast ultrasound requires a 7 MHz or higher-frequency linear transducer and electronic adjustment of focal zones(s) is recommended. ^195,^ ^196^ Transducers producing higher frequencies improve resolution. The transducer should be manufactured specifically for use in superficial imaging and a frequency of 10 MHz or 12 MHz is preferred. ^197^ Transducers with frequencies up to 12 MHz are available for breast imaging on most modern ultrasound scanners.

Linear array transducers are used for breast studies because they generate rectangular images. Compared with transducer configurations that produce sector, wedge-shaped images, linear array transducers produce images with a large field-of-view of areas close to the skin surface.

##### Effect of Operator and Image Interpreter on Ultrasound Imaging

The accuracy of ultrasound strongly depends on the skill of the sonographer/mammographer. Operators must continuously and carefully alter scanning parameters including transducer orientation, pressure, and instrument controls to avoid artifacts in ultrasound images, which can significantly degrade image quality and possibly lead to an incomplete or incorrect diagnosis. ^197^ – ^199^

Ultrasound images are susceptible to a number of artifacts that could cause image distortion and false interpretations. Sonographers performing ultrasound breast imaging studies must be aware of the potential problems and be able to compensate accordingly. Two common types of artifacts are shadowing and reverberation.

Breast ultrasound images are prone to a form of shadowing caused by the complex combination of absorption and refraction along the border of a mass. ^198^ This edge shadowing can obscure the mass's lateral margins. Another shadowing form - acoustic shadowing - can completely conceal the posterior margin of a mass, making size measurements problematic. ^200^ Although posterior acoustic shadowing is a feature most commonly associated with malignancy, this feature may also be seen with benign breast lesions. ^201^ Shadowing could also be caused by poor contact between the transducer and the skin ^198^

Reverberation, which is the display of parallel echogenic lines caused by reflection of the ultrasound beam back and forth between the transducer and tissue interface, can give the false appearance of solid or complex material along the wall of a cyst. ^198^

Aside from artifacts, a number of operator-controlled settings affect the diagnosis from a breast ultrasound study. Dynamic range settings determine the range of echo amplitudes detected and displayed. A low dynamic range setting increases image contrast but may cause the echoes in a solid mass to be absent from the display, thus mimicking a normally anechoic (echo-free) simple cyst. A high dynamic range setting results in an image with little contrast, which hinders differentiation of fat lobules from subtle masses. ^198^

The focal zone is the location where the width of the ultrasound beam is narrowest and where the spatial resolution is greatest. Image characteristics outside the focal zone may cause a subtle mass to be less visible, sharp edges to appear ill-defined, and an anechoic simple cyst to have internal echoes. ^198^

Settings of gray-scale gain determine the amplification of the returning echo signals. Inappropriately high gain settings could cause spurious echoes to be displayed in a simple cyst resulting in the appearance of a complex cyst or solid mass. ^198,^ ^202,^ ^203^

Studies of inter-observer variability indicate a high degree of agreement when determining the shape of a mass while moderate agreement among observers is found when the degree of posterior acoustic transmission is described. ^200^ However, when the margins of lesions are poorly defined, or when shadowing is present, measurements of masses are difficult. Interobserver agreement is very high when ultrasound breast imaging is performed as adjunct to physical examination and mammography and with full knowledge of the mammographic findings. ^204,^ ^205^

Several computer-aided diagnosis (CAD) systems have been developed to provide quantitative assessments and to eliminate variability among observers. The use of computer tools is expected to diminish operator dependency and to aid in diagnosis. Because the use of these systems is not widespread, diagnosis is still based on a subjective evaluation of the findings. ^199,^ ^206^ This further supports the need for well qualified interpreters.

##### Patient and Lesions Characteristics

Ultrasound is reported to function well in imaging breasts with dense tissue, which are often problematic to evaluate with x-ray mammography. ^207,^ ^208^ However, ultrasound has been reported to have a poor ability to detect microcalcifications in breast tissue. ^207^ Microcalcifications may be an important early indication of breast cancer.

##### Patient Safety and Comfort

During a typical ultrasound breast imaging study, the patient is placed in a supine oblique position, with a pillow under the shoulder and the arm extended behind the head. ^209^ Because taut compression is not required, ultrasound is advantageous, particularly when evaluating a painful breast.

A review of the literature has not revealed risks to the patient. As long as routine practices are followed, ultrasound breast imaging can be considered a safe exam for most patients.

##### Accreditation Factors

The American College of Radiology (ACR) has instituted a voluntary breast ultrasound accreditation program that offers facilities the opportunity for peer review of their staff's qualifications, equipment, and quality control and quality assurance programs. ^196^

A physician supervising and interpreting breast ultrasound examinations is required to meet specific minimum experience and education requirements in order for their facility to be accredited by the ACR.

The accreditation program requires sonographers/mammographers to be certified by the American Registry of Diagnostic Medical Sonography (ARDMS), or post-primary certification (“advanced registry”) in breast sonography by the American Registry of Radiologic Technologists (ARRT), or certification by the ARRT or unrestricted state license and qualified to do mammography under Mammography Quality Standards Act (MQSA). The physician is not required to be present during breast ultrasound examinations performed by ARDMS sonographers or ARRT technologists with certification in breast sonography. However, the physician must be in the department during breast ultrasound examinations performed by ARRT technologists without an advanced registry in breast sonography. In all situations, the physician is ultimately responsible to see that the appropriate images are obtained.