# Analysis

## Strength and Stability of Evidence Assessment

We rated the strength and stability of the evidence using an algorithm that we developed. This algorithm provides systematic, reproducible, transparent, and a priori decision rules for rating the strength of the evidence. It extends the recommendations made in the AHRQ report, “Systems to Rate the Strength of Scientific Evidence,” which concluded that the strength of evidence depends on the quality, quantity, and consistency of the available data. ^37^ The algorithm distinguishes between qualitative questions (Does it work?) and quantitative questions (How well does it work?) and, as shown in Table 2, assigns a separate rating of the evidence for these two kinds of questions. Evidence underpinning the answers to qualitative questions is rated according to its strength, and evidence underpinning the answers to quantitative questions is rated according to the stability of the evidence. Qualitative conclusions backed by strong evidence are less likely than weaker conclusions to be overturned by new evidence, and the quantitative estimates provided by answers to quantitative questions that are backed by stable estimates are less likely to exhibit much change upon the publication of new estimates. These definitions are similar to those proposed by the GRADE working group. ^38^ The algorithm itself is shown in Appendix B. Study Quality and Strength of Evidence Evaluation.

Table 2 Definitions of Strength and Stability of Evidence

Strength of Evidence Rating | Interpretation
Qualitative Conclusion
Strong Evidence | Evidence supporting the qualitative conclusion is convincing. It is highly unlikely that new evidence will lead to a change in this conclusion.
Moderate Evidence | Evidence supporting the qualitative conclusion is somewhat convincing. There is a small chance that new evidence will overturn or strengthen our conclusion. Regular monitoring of the relevant literature is recommended at this time.
Weak Evidence | Although some evidence supports the qualitative conclusion, this evidence is tentative and perishable. There is a reasonable chance that new evidence will overturn or strengthen our conclusions. Frequent monitoring of the relevant literature is recommended at this time.
Unacceptably Weak Evidence | The available evidence that exists is not of sufficient strength to warrant drawing an evidence-based conclusion from it. Frequent monitoring of the relevant literature is recommended at this time.
Quantitative Conclusion
High Stability | The estimate of diagnostic test performance in the conclusion is stable. It is highly unlikely that the magnitude of this estimate will substantially change as a result of the publication of new evidence.
Moderate Stability | The estimate of diagnostic test performance in the conclusion is somewhat stable. There is a small chance that the magnitude of this estimate will substantially change as a result of the publication of new evidence. Regular monitoring of the relevant literature is recommended at this time.
Low Stability | The estimate of diagnostic test performance in the conclusion is likely to be unstable. There is a reasonable chance that the magnitude of this estimate will substantially change as a result of the publication of new evidence. Frequent monitoring of the relevant literature is recommended at this time.
Unacceptably Low Stability | Estimates of the diagnostic test performance are too unstable to allow a quantitative conclusion to be drawn at this time. Frequent monitoring of the relevant literature is recommended.

In the context of diagnostics, answers to the qualitative questions of whether the diagnostic test works (i.e., whether it performs better than chance), are often not of particular interest. Answers to quantitative questions are typically of greater interest, and are provided by summary estimates of test performance. Where possible, we addressed semi-qualitative questions of whether the diagnostic test works sufficiently well to be clinically useful by direct examination of summary estimates of test performance; however, such questions can only be fully addressed by decision analyses, which are outside the scope of this report.

To aid in assessing the quality of each of the studies included in this assessment, we used a quality assessment instrument developed by ECRI, shown in Appendix B. Study Quality and Strength of Evidence Evaluation. This instrument examines different factors of diagnostic study design that have the potential to reduce the validity of the conclusions that can be drawn from a trial. In brief, the tool was designed so that a study attribute that, in theory, protects a study from bias receives a “Yes” response. If the study clearly does not contain that attribute it receives a “No” response. If poor reporting precludes assigning a “Yes” or “No” response for an attribute, then “NR” is recorded (NR = not reported).

To estimate the quality of an individual study, we computed a normalized score so that a perfect study received a score of 10, a study for which the answers to all items was “No” received a score of 0, and a study for which the answers to all questions was “NR” was 2.5.

We then classified the overall quality of the evidence base by taking the median quality score. Quality scores were converted to categories as shown below. The definitions for what constitutes low, moderate, or high quality evidence were determined a priori by a committee of four ECRI methodologists.

less than 5.0: Unacceptable (exclude study or entire evidence base)

less than 7.0: Low quality

less than 9.0: Medium quality

9.0 +: High quality

The consistency of the strength of evidence was addressed differently for quantitative and qualitative conclusions. The consistency of the evidence base for quantitative conclusions was measured with statistical tests of heterogeneity. We used the heterogeneity statistic I^2^. Typically we use a threshold for I^2^ of 0.5 because, according to Higgins and Thompson, this value represents moderate heterogeneity. ^39,^ ^40^ I^2^ tends to be a more useful test than the Q statistic in most situations because of the low statistical power of Q. If the data were found to be consistent, a summary effect size was calculated; if not, meta-regression (described further below) was used to explore the reasons for heterogeneity.

We tested the consistency of the evidence base for semi-qualitative conclusions drawn from likelihood ratios by an informal vote-counting method. If the 95% confidence intervals of 80% or more of the effect sizes were within the “possibly clinically useful” range of likelihood ratios (2 or greater for positive likelihood ratios, 0.5 or less for negative likelihood ratios), then the conclusion of “clinically useful” was defined to be robust and consistent.

The quantity of the overall strength of evidence rating was addressed by measuring the stability of summary estimates. A stable summary estimate indicates that the accumulated body of evidence is large enough to have accurately measured the “true” effect size. The stability of summary estimates was tested with cumulative meta-analysis. ^41,^ ^42^ Studies were sequentially added in order of decreasing size into a meta-analysis, and summary estimates calculated for each step. We defined the summary estimate as stable if the 95% confidence intervals of the last three summary estimates calculated by cumulative meta-analysis were within 5% of the final summary estimate. The stability of summary estimates was only measured if the data were found to not be heterogeneous (consistent). If the data are not consistent (hetereogeneous), no summary estimate was calculated.

## Data Synthesis

If more than two studies reported relevant data, we calculated and tested the diagnostic odds ratios from these studies for heterogeneity with the I^2^ test described above. ^39,^ ^40^ If the data were found to not be heterogeneous, we pooled the data. If data from five or more studies were available, meta-analysis of diagnostic test performance was performed by constructing summary receiver operating characteristic (SROC) curves that depict the true positive rate of the test on the y-axis and the false positive rate on the x-axis. We used the method of Moses and Littenberg to construct these curves. ^43^ The actual curves are shown in the body of the report. To summarize the information in a format that is commonly used in the literature, two points on each curve were selected and used to describe the SROC curves in tables and text; these two points are the sensitivity and specificity on the SROC curve at the mean reported sensitivity for the articles included in the meta-analysis, and at 95% sensitivity. The latter point was used as a standard reporting convention for SROC curves and does not imply that this is the actual sensitivity of the tests. If data from fewer than five studies were available, we did not construct a SROC, and instead directly pooled the sensitivity and specificity reported by the studies. ^44^ Directly pooling the diagnostic test characteristics in this fashion ignores any variability of the diagnostic threshold and may lead to an underestimation of diagnostic performance. ^44^ However, a SROC derived from fewer than five studies is unlikely to be an accurate representation of the test's performance. ^43^

To aid in clinical interpretation, we also analyzed the data using fixed-effects meta-analytical pooling of likelihood ratios, as described by Stengel et al. ^45^ The summary negative likelihood ratios and Bayes theorem were used to calculate the post-test probability of disease and estimate the number of missed cases of cancer for women at the average risk of cancer of those being referred to a biopsy in the U.S. These results were included in the discussion and summary results to place the diagnostic accuracy of these diagnostic tests into a meaningful clinical context. We chose to use the summary negative likelihood ratios for these calculations rather than negative predictive values estimated from the SROC results because they were more directly applicable; the likelihood ratio produces a single result, already at the threshold most likely to be used in clinical settings. Conclusions drawn from the SROC results are essentially identical to the results drawn from the summary negative likelihood ratios; any apparent differences are within the range of error.

We used the odds ratio form of Bayes theorem to estimate the number of cancer cases missed if a diagnostic test is negative. This form of Bayes theorem, for the probability of cancer given that the test is negative, is expressed by the formula:

Post - Test Odds = Pre - Test Odds × LR -

Where:

Post - Test Odds = Prevalence/1 - Prevalence

and:

Posterior probability = Post - Test Odds/ 1+ Post - Test Odds

In this case, the posterior probability represents the probability that a woman has cancer given that the diagnostic test was negative. We used a prevalence of cancer of 20% to represent the average probability of cancer in women undergoing a decision of biopsy or non-invasive test, based on Banks et al. reported prevalence of breast cancer of 11.6% to 24.4%, depending on age, for more than 100,000 unselected patients with positive mammograms. ^46^ The results have been expressed in two different ways in the report: as an individual woman's chance of having disease after a negative test result (simply the post-test probability), and as a the number of missed cases of cancer. If 1,000 women test negative for cancer, and each woman's chance of having cancer is the post-test probability, the number of missed cases of cancer in this cohort of 1,000 women can be estimated by multiplying the post-test probability by 1,000. The posterior probability can readily be converted to a negative predictive value (NPV) by the formula:

NPV = 1 - Posterior probability.

We used meta-regression to attempt to explain heterogeneity when it was detected. To avoid an ecological fallacy, we included only study-level covariates in the meta-regression. Such covariates may have included (but not be limited to) study quality items from the study quality scale, and reported variations in imaging methods. All meta-regressions were performed using the permutation method by Higgins and Thompson. ^47^ This method counters the well-known Type I error inflation rate associated with the covariates entered in standard meta-regressions. Meta-regressions were performed using restricted maximum likelihood (REML) as computed by the Stata statistical software package. ^48^

The third preliminary Key Question was addressed using a narrative review. This review was conducted by ECRI's Health Devices Group, which has conducted laboratory and hospital-based testing of medical devices for over 30 years. The health devices group consists of experts with experience in using and evaluating most of the technology used to diagnose and treat patients, including diagnostic imaging. This requires an understanding of the physical principles that govern a device, and how the device is used clinically. For most diagnostic imaging equipment, this is achieved by observing the equipment in use and interviewing routine users, including radiologists and technologists.

## Peer Review

We requested peer review of the draft of this report from seven content or methodology experts and one patient advocacy organization. Their comments were reviewed, and where possible, incorporated into the final document. See Appendix D. Peer Reviewers for a list of the reviewers.