# Introduction

Since the advent of mammography and clinical breast examination, many asymptomatic women have had an abnormal finding. Typically, suspicious lesions are evaluated with tissue biopsy, either by excision or by needle sampling. However, only a low percentage of women undergoing biopsy actually have cancer, suggesting that many of them could avoid biopsy if a non-invasive diagnostic test were available that could, with high sensitivity, rule out malignancy. Several technologies have been proposed for this purpose, yet the outcomes of using these non-invasive diagnostic technologies remains unclear. The ultimate purpose of this evaluation is to help patients, policymakers, and clinicians determine when it is appropriate to use these non-invasive technologies.

## Background

Breast cancer is the second most common malignancy of women. ^1^ The American Cancer Society estimates that in the U.S. in 2005, 212,930 women will be newly diagnosed as having breast cancer, and there will be 40,870 deaths due to this disease. ^2^ White women are more likely to develop breast cancer than women of other ethnic/racial groups, but black women are more likely to die from breast cancer. ^3^ Asian and third-world countries have much lower prevalences of breast cancer than does the U.S., U.K., and western Europe. ^4^ Breast cancer incidence was stable in the United States through the 1990s, but deaths due to breast cancer have been declining since 1995. ^5^ Forty to sixty percent of patients diagnosed with breast cancer will ultimately die from the disease. ^6^

The majority of breast cancers develop from the epithelial lining of the milk ducts or lobules. Initial detection of breast cancer is usually the result of lumps noticed upon physical examination or areas of abnormal density identified by x-ray screening mammography. Survival rates depend on the stage of disease at diagnosis. At stage 0 (carcinoma in situ) the five-year survival rate is 100%. Five-year survival rates for women with stage IV (cancer has spread beyond the breast) are only 16%. ^7^ These observations suggest that breast cancer mortality rates can be significantly reduced by identifying cancers at earlier stages. Because early breast cancer is asymptomatic, the only way to detect it is through population-wide screening. Mammography is a widely accepted method for breast cancer screening. ^8,^ ^9^

Mammography uses x-rays to examine the breast for calcifications, masses, or other abnormal structures. Currently most professional organizations recommend that women older than fifty years of age receive a yearly mammogram. ^10^ Some professional organizations recommend that routine breast cancer screening begin earlier, though mammography screening is less effective in younger women. ^8^

The American College of Radiology has created a standardized system for reporting the results of mammography, the Breast Imaging Reporting and Data System (BIRADS). ^11^ – ^13^ There are seven categories of assessment and recommendation:

0 Assessment is incomplete, and additional imaging evaluation is needed.
1 Negative. There is no appreciable abnormality to report.
2 Benign finding. Benign finding such as benign calcifications, intramammary lymph nodes and calcified fibroadenomas.
3 Probably benign finding. An abnormality that has a high probability of being benign.
4 Suspicious abnormality. Biopsy should be considered.
5 Highly suggestive of malignancy. Biopsy is very strongly recommended.
6 Confirmed diagnosis of malignancy.

Often, a woman receives a biopsy after discovery of a suspicious lesion by mammography or physical examination (BIRADS score 4 or 5). However, only a low percentage of women undergoing biopsy actually have cancer-- the positive predictive value of mammography has been estimated to be less than 30%, possibly as low as 15%. ^14,^ ^15^ If a non-invasive diagnostic test were available that could accurately rule out malignancy, many women could safely avoid biopsy. Several technologies—magnetic resonance imaging (MRI), ultrasonography (US), scintimammography, positron emission tomography (PET) scanning—have been proposed for this purpose.

Mammography often leads to identification of a “probably benign” lesion (BIRADS score 3), or an uninformative mammography (BIRADS score 0). Clinicians may be reluctant to refer such a patient for a biopsy; they may also be reluctant to do nothing. Often such patients are referred for frequent repeat mammography examinations. If an accurate non-invasive diagnostic test were available to examine these women, many women could avoid these repeat mammography exams, with their attendant discomfort, inconvenience, x-ray exposure, and emotional distress.

The ultimate goal of this evaluation is to determine when it is clinically appropriate to use these non-invasive technologies to evaluate breast abnormalities. In order for clinicians to decide upon “clinical appropriateness” for any particular patient, an accurate estimate of the negative and positive predictive values of the non-invasive tests for women with a variety of demographic and clinical risk factors must be available. Because women with a previous history of breast cancer and women known to carry BRCA1 and BRCA2 mutations have a very different risk profile than the rest of the population, we will not evaluate the use of non-invasive technologies for such women in this report. Instead, we will focus on the use of non-invasive imaging technology for women considered to be at “normal” risk of breast cancer who present with an abnormal finding by mammography or physical examination. We will also examine the influence of age; the morphological characteristics of the lesion; BIRADS status; the presence of calcifications, and other key clinical risk factors.

## Methods

### Scope and Key Questions

This report addresses three questions. We address the first two employing a systematic review, and the third as a narrative overview. The questions we address are:

Key Question 1. For the following diagnostic tests as applied to the breast (positron emission tomography (PET) scanning, scintimammography (SC), magnetic resonance imaging (MRI), and ultrasonography (US)) what are the sensitivity and specificity of the tests for diagnosis of breast cancer in women presenting with:

a) An abnormal mammogram, overall and by BIRADS classification or other relevant clinical classification (e.g., presence or absence of calcification, well circumscribed lesions, etc.)
b) A palpable breast abnormality
c) What percentage of women in the studies in this question were age 65 or older, and do sensitivity and specificity vary by older vs. younger than age 65?

Key Question 2. For women with relevant demographic risk factors (e.g., age, family history) and clinical risk factors (e.g., BIRADS status or morphologic characteristics of the lesion), what are the positive and negative predictive values of the above diagnostic tests?

Key Question 3. Are there other factors that affect the accuracy or acceptability of the tests considered in Questions 1 and 2? Our answer to this question is a narrative overview of device- and operator- specific factors that may affect diagnostic accuracy, such as timing of administration of contrast agents and scan, interpretation of images, and settings of the devices. We also review potentials for harm from the test, including issues such as radiation exposure or excessive discomfort associated with the test. To address this question, we used information from review articles, experts, and other sources.

Other diagnostic and imaging technologies are outside the scope of this report, as are any other issues, outcomes, patient categories, or questions about breast cancer diagnosis not explicitly mentioned in the three Key Questions. Evaluations of women known to have susceptibility mutations in either the BRCA1 or BRCA2 genes are outside the scope of this report, as are women known to have a prior history of breast cancer. This report focuses on specific technologies, specific uses of these technologies, and specific patient populations. The focus of this report does not imply that other uses of these technologies for other purposes and other patient populations are not important or valid.

### Outcomes

The outcomes of interest in this report are diagnostic test characteristics. Diagnostic test characteristics are measures of how well the diagnostic test performs. In published studies, the results of the relevant tests are determined to be correct or incorrect as measured by histopathological examination of a biopsy specimen. In other words, published studies use biopsy as a “gold standard” to determine whether the patient truly has or does not have breast cancer, and the performance of the test of interest is compared to that of the gold standard. Four important measures of a diagnostic test's performance can be calculated. These are the test's sensitivity, specificity, positive predictive value (PPV), and negative predictive value (NPV). These diagnostic test characteristics are briefly explained below. For further details see Appendix E.

Sensitivity and specificity are properties of a test that are useful when deciding whether to use a test. Sensitivity is the proportion of people with the disease who have a positive test for the disease. A test with high sensitivity will rarely misclassify people with the disease as not having the disease (the test has a low rate of false-negatives). Specificity is the proportion of people without the disease who have a negative test. A test with high specificity will rarely misclassify people without the disease as diseased (a low rate of false-positives).

There is a tradeoff between the sensitivity and specificity of a test. The test threshold, above which patients are sent for biopsy, is essentially an arbitrary decision (in that it is not biologically fixed, but can assume any value that meets the needs of patients and clinicians). As a consequence, for any given image of a breast lesion, sensitivity can only be increased by decreasing specificity. For example, if a clinician decides that only patients with extremely abnormal images will be sent for biopsy, the test will become extremely specific but not very sensitive. One consequence of this is that the clinician will falsely diagnose many patients as not having breast cancer. On the other hand, a clinician may not want to miss any cases of breast cancer. In this case, the clinician decides that patients with borderline abnormal images will be sent for biopsy, so the test will become more sensitive but less specific. One consequence of this is that the clinician will send many patients who do not have breast cancer for an unnecessary biopsy. A graphical method of diagnostic test analysis that illustrates the tradeoff between sensitivity and specificity at each threshold is called a receiver operating characteristic curve (ROC curve).

Two other important measures of diagnostic test performance are the positive and negative predictive values. The positive predictive value of a test is the probability of a patient having the disease following a positive test result. The negative predictive value is the probability of a patient not having the disease following a negative test result. Unlike sensitivity and specificity, predictive values are influenced by the prevalence of the disease in the population of patients being tested.

Because sensitivity and specificity are difficult to directly apply to clinical situations, and predictive values vary markedly as a function of disease prevalence (i.e., may be different for each patient subpopulation) a combined measure of diagnostic performance, the likelihood ratio, is a clinically useful diagnostic test performance measure. ^16,^ ^17^ Negative likelihood ratios measure the ability of the test to accurately “rule out” disease, and positive likelihood ratios measure the ability of the test to accurately detect disease. Likelihood ratios can be directly used in Bayes'theorem to calculate posttest odds of having a disease from the pretest suspicion of the patient's odds of having that disease. In general, a positive likelihood ratio greater than 10, or a negative likelihood ratio less than 0.1, may have a very substantial impact on clinical decision-making through meaningful revision of disease probability (commonly referred to as ‘clinically useful’). A positive likelihood ratio of less than 2 or a negative likelihood ratio of greater than 0.5, has a clinically insignificant impact on decision-making (commonly referred to as ‘not clinically useful’). Likelihood ratios in between these two extremes may or may not have an impact on clinical decision-making, depending upon the context; likelihood ratios in this in-between category are commonly referred to as ‘possibly clinically useful’. ^18^

Determining whether a ‘possibly clinically useful’ likelihood ratio has a significant impact on decision-making requires consideration of each clinical context. For example, a patient presents with symptoms that lead the clinician to believe there is a 50% chance of a bacterial infection of the heart valves. The clinician orders a diagnostic test that has a negative likelihood ratio of 0.2. The test comes back negative for bacterial infection of the heart valves. Applying Bayes' theorem, the physician now believes there is a 17% chance of a bacterial infection of the heart valves. However, the physician may decide to treat with antibiotics anyway, because there is little chance of side effects from treatment, and very unpleasant possibilities if an infection of the heart valves is left untreated. However, what if the suspected disease was a brain tumor? It is unlikely the physician would proceed with surgery on only a 17% suspicion. In complicated clinical situations, a full cost-benefit decision analysis may be necessary to decide whether a diagnostic test has sufficient accuracy (estimated through likelihood ratios) to guide clinical decision-making. ^19^

To help readers put the findings of this report into perspective, we have listed some published negative and positive likelihood ratios for common diagnostic tests relevant to breast cancer in Table 1.

Table 1 Published likelihood ratios for common diagnostic tests relevant to breast cancer

Diagnostic test | Positive likelihood ratio | Negative likelihood ratio
Sentinel lymph node biopsy to rule out metastatic disease in the axilla | | 0.086^20^
Large core needle biopsy to rule out or rule in breast cancer in a suspicious lesion | 16.2^21^ | 0.03^21^
Fine needle aspiration, performed by an experienced cytologist, to rule out breast cancer in a suspicious lesion | | 0.02 to 0.11^22^
Diagnostic mammography of a palpable lump, to rule out or rule in breast cancer | 5.6^22^ | 0.15^22^
Screening mammography of asymptomatic women to detect breast cancer | 2.2 to 2200^22,23^