# Evidence Tables

## Diagnostic Test Characteristics

No diagnostic test is perfect. Studies of diagnostic test performance compare test results on a group of patients, some of whom have the disease and some of whom do not. Each patient undergoes the experimental test as well as a second “gold standard” reference test to determine “true” disease status. The relationship between the diagnostic test results and disease status is described using diagnostic test characteristics. It is important that the “gold standard” test is very accurate in measuring “true” disease status, or else the performance of the experimental diagnostic test will be poorly estimated.

### Sensitivity and specificity

The results of the experimental and “gold standard” test and their relationship are commonly presented as 2X2 tables (see Table 27). From the 2X2 table, sensitivity and specificity are readily calculated:

Evidence Table 27. Example of a 2X2 Table

| | Disease
| | Present | Absent
Test Results | Positive | True positives (TP) | False positives (FP)
| Negative | False negatives (FN) | True negatives (TN)

Sensitivity = TP/(TP+F)

Specificity = TN/(FP+TN)

### Predictive values and likelihood ratios

To make sense of a diagnostic investigation, a clinician needs to be able to make an inference regarding the probability that a patient has the disease in question according to the result obtained from the test. Sensitivity and specificity do not directly provide this information. The predictive values and likelihood ratios can also be directly calculated from a 2X2 table:

Positive predictive value = TP/(TP+FP)

Negative predictive value = TN/(FN+TN)

Positive likelihood ratio = (TP/(TP+FN))/(FP/(FP+TN))

Negative likelihood ratio = (FN/(TP+FN))/(TN/(FP+TN))

Predictive values describe the probabilities that positive or negative results are correct for an individual patient. However, predictive values depend on the prevalence of disease in the population. A study that enrolled a patient population with a disease prevalence of 70% may report a positive predictive value of 80%. If a clinician tests a patient from a population with a disease prevalence of 70%, and the test comes back positive, the clinician knows the patient has an 80% chance of having the disease in question. However, if the patient comes from a population with a disease prevalence of 20%, the clinician cannot apply the results of the study directly to this patient.

Likelihood ratios are independent of prevalence and can be directly applied in the clinic to update an individual's estimated chances of disease according to their test result using Bayes' theorem. Clinicians may be familiar with simple nonograms that allow a direct visualization of post-test chances of disease given a positive or negative test result, without the need to go through the tedious calculations of Bayes' theorem.

## Studies of Positron Emisson Tomography (PET) Scanning

Evidence Table 28. Included Studies of PET Scanning

Study | N patients | Quality score | PET parameters | Tracer FDG parameters | Patients | Age | % 65 or older | % Female | % Post-menopausal | % Black
Hienisch et al. 2003 ^56^ | 36 | 7.4 | Whole-body scanner, patient prone, 70 minutes after tracer | 120 to 180 MBq, fast of 12 hours or longer | Women with suspicious breast lesions detected by physical exam, mammography, and/or ultrasound, scheduled for biopsy, referred when there was time on the scanners. Pregnant women were excluded. | Mean 48.3 | Not reported | 100% | Not reported | Not reported
| | | | | | Range 25 to 77
Walter et al. 2003 ^57^ | 44 | 7.9 | Whole-body scanner, patient prone, 40 to 60 minutes after tracer | 300 to 370 MBq, fast of 12 hours or longer | Patients referred to the clinic for biopsy of suspicious lesions on the basis of mammography, ultrasound, or physical examination. Referred patients were chosen randomly from 550 possible patients to fill restricted scanner time. | Mean 52 | Not reported | Not reported | Not reported | Not reported
| | | | | | Range 21 to 77
Brix et al. 2001 ^52^ | 14 | 8.3 | Whole-body scanner, patient prone, 60 minutes after tracer | 138 to 248 MBq, fast of 6 hours or longer | Women with suspicious breast lesions detected by physical exam, mammography, and/or ultrasound, scheduled for biopsy, referred when there was time on the scanners. Women with lesions smaller than 10 mm, elevated blood glucose, younger than age 18, pregnant, or had metal implants were excluded. | Mean 49 | Not reported | 100% | Not reported | Not reported
| | | | | | Range 35 to 66
Yutani et al. 2000 ^55^ | 40 | 7.9 | Whole-body scanner, patient supine, 60 minutes after tracer | 370 MBq, fast of 4 hours or longer | Patients with suspicious lesions (detected by mammography, ultrasound, or physical exam) scheduled for excisional biopsy. | Mean 51 | 15% | 100% | Not reported | Not reported
| | | | | | Range 25 to 86
Yutani et al. 1999 ^54^ | 30 | 8.8 | Whole-body scanner, patient supine, 60 minutes after tracer; and gamma camera, patient supine, 3 hours after tracer | 370 MBq, fast of 4 hours or longer | Women referred to the clinic because of suspicion of breast cancer after mammography and physical examination, selected randomly from 84 possible patients on the basis of availability of PET. | Mean 50.9 | 20% | 100% | Not reported | Not reported
| | | | | | Median 49
| | | | | | Range 32 to 78
Palmedo et al. 1997 ^58^ | 20 | 7.9 | Whole-body scanner, patient prone, 45 to 60 minutes after tracer | 370 MBq, fast overnight | Patients with suspicious lesions (detected by mammography or physical exam) scheduled for excisional biopsy. | Mean 58.4 | Not reported | 100% | Not reported | Not reported
| | | | | | Range 28 to 84
Holle et al. 1996 ^51^ | 50 | 7.9 | Gamma camera, patient prone, 50 minutes after tracer | 500 to 1,000 MBq, fast overnight | Women with breast lesions of unknown histology, identified by mammography or ultrasound, who presented when there was time on the scanner. | Mean 57 | 38% | 100% | Not reported | Not reported
| | | | | | Range 20 to 82
Crowe et al. 1994 ^53^ | 28 | 7.5 | Whole-body scanner, 40 minutes after tracer | 200 uCi/kg body mass, fast 4 hours or longer | Patients attending the clinic who had a breast lesion 1 cm or greater in diameter, detected by palpation, mammography, or both, which, in the opinion of the surgeon, required definitive pathological diagnosis. Pregnant or diabetic women were excluded. | Mean 55 | Not reported | 92.90% | 53.60% | 35.70%
| | | | | | Range 35 to 79
Tse et al. 1992 ^59^ | 14 | 7.9 | Whole-body scanner, 40 minutes after tracer | 10 mCi, fast length not reported | Women with a history of a mammographic abnormality or palpable breast mass, who were candidates for surgical resection. | Not reported | Not reported | 100% | Not reported | Not reported

PET = positron emission tomography

FDG = 18-fluorodeoxyglucose

Evidence Table 29. Quality Assessment of Studies of PET

Question | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16 | 17 | 18 | score
Study | consecutive | consistent | prospective | Case control | funding | valid reference | gold standard | interreader | blinding | blinding | blinding | blinding | full testing | threshold | intervening | attrition | conclusions | discrepancy | standardized
Hienisch et al. 2003 ^56^ | r | y | y | y | r | y | y | r | y | r | n | r | y | y | y | y | y | y | 7.4
Walter et al. 2003 ^57^ | y | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.9
Brix et al. 2001 ^52^ | y | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 8.3
Yutani et al. 2000 ^54^ | y | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.9
Yutani et al. 1999 ^55^ | y | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.8
Palmedo et al. 1997 ^58^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Holle et al. 1996 ^51^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Crowe et al. 1994 ^53^ | r | y | y | y | r | y | y | r | y | r | y | r | y | r | y | y | y | y | 7.5
Tse et al. 1992 ^59^ | r | y | y | y | y | y | y | r | y | r | y | r | y | r | y | y | y | y | 7.9

y = yes

n = no

r = not reported

Evidence Table 30. Diagnostic Test Characteristics of PET

Study | N lesions | Type of scanner | Patient subgroup | Prevalence | True positive | False negative | False positive | True negative | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Hienisch et al. 2003 ^56^ | 40 | Whole-body | All | 62.5% | 17 | 8 | 4 | 11 | 68.0% (48.4% to 82.7%) | 73.3% (48.0% to 88.9%) | 81.0% (59.9% to 92.1%) | 57.9% (36.3 to 76.7) | 2.55 (1.95 to 3.34) | 0.44 (0.23 to 0.83)
Walter et al. 2003 ^57^ | 42 | Whole-body | All | 45.2% | 12 | 7 | 2 | 21 | 63.2% (41.0% to 80.7%) | 91.3% (73.0% to 97.4%) | 85.7% (59.8% to 95.7%) | 75.0% (56.6 to 87.2) | 7.26 (5.15 to 10.24) | 0.40 (0.22 to 0.74)
Brix et al. 2001 ^52^ | 13 | Whole-body | Lesions 1.0 cm or larger | 69.2% | 8 | 1 | 2 | 2 | 88.9% (56.2% to 97.6%) | 50.0% (15.4% to 84.6%) | 80.0% (48.9% to 94.0%) | 66.7% (21.0% to 93.3%) | 1.78 (1.41 to 2.24) | 0.22 (0.03 to 1.80)
Yutani et al. 2000 ^55^ | 40 | Whole-body | All | 95.0% | 30 | 8 | 0 | 2 | 78.9% (63.6% to 88.8%) | 100.0% (34.0% to 99.3%) | 100.0% (88.4% to 99.9%) | 20.0% (6.0% to 51.1%) | 4.69 (3.98 to 5.54) | 0.26 (0.12 to 0.57)
| 30 | Whole-body | BIRADS 5 | 93.3% | 26 | 2 | 0 | 2 | 92.9% (77.1% to 97.9%) | 100.0% (34.0% to 99.3%) | 100.0% (86.8% to 99.9%) | 50.0% (15.4% to 84.6%) | 5.48 (4.90 to 6.13) | 0.10 (0.03 to 0.38)
| 29 | Whole-body | Lesion 1.5 cm or larger | 96.6% | 27 | 1 | 0 | 1 | 96.4% (82.0% to 99.2%) | 100.0% (20.8% to 99.2%) | 100.0% (87.2% to 99.9%) | 50.0% (10.0% to 90.0%) | 3.79 (3.48 to 4.13) | 0.07 (0.01 to 0.40)
| 37 | Whole-body | Palpable lesion | 97.3% | 29 | 7 | 0 | 1 | 80.6% (64.9% to 90.1%) | 100.0% (20.8% to 99.2%) | 100.0% (88.0% to 99.9%) | 12.5% (2.6% to 47.4%) | 3.19 (2.71 to 3.75) | 0.27 (0.10 to 0.75)
| 34 | Whole-body | Younger than 65 | 94.1% | 25 | 7 | 0 | 2 | 78.1% (61.2% to 88.8%) | 100.0% (34.0% to 99.3%) | 100.0% (86.3% to 99.9%) | 22.2% (6.7% to 47.74%) | 4.64 (3.85 to 5.58) | 0.27 (0.12 to 0.61)
Yutani et al. 1999 ^54^ | 30 | Whole-body | All | 86.7% | 26 | 0 | 2 | 2 | 100.0% (86.8% to 99.9%) | 50.0% (15.4% to 84.6%) | 92.9% (77.1% to 97.9%) | 100.0% (34.0% to 99.3%) | 1.96 (1.86 to 2.07) | 0.04 (0.00 to 0.66)
| 19 | Whole-body | BIRADS 5 | 94.7% | 18 | 0 | 0 | 1 | 100.0% (82.0% to 99.8%) | 100.0% (20.8% to 99.2%) | 100.0% (82.0% to 99.8%) | 100.0% (20.8% to 99.2%) | 3.89 (3.62 to 4.19) | 0.04 (0.00 to 0.61)
| 29 | Whole-body | Palpable lesion | 89.7% | 26 | 0 | 2 | 1 | 100.0% (86.8% to 99.9%) | 33.3% (6.7% to 79.0%) | 92.9% (77.1% to 97.9%) | 100.0% (20.8% to 99.2%) | 1.57 (1.49 to 1.65) | 0.05 (0.00 to 1.02)
| 24 | Whole-body | Younger than 65 | 83.3% | 20 | 0 | 2 | 2 | 100.0% (83.5% to 99.8%) | 50.0% (15.4% to 84.6%) | 90.9% (72.0% to 97.3%) | 100.0% (34.0% to 99.3%) | 1.95 (1.83 to 2.09) | 0.05 (0.00 to 0.84)
| 30 | Gamma camera | All | 86.7% | 22 | 4 | 2 | 2 | 84.6% (66.3% to 93.7%) | 50.0% (15.4% to 84.6%) | 91.7% (73.9% to 97.5%) | 33.3% (10.1% to 69.9%) | 1.69 (1.44 to 1.99) | 0.31 (0.08 to 1.17)
| 19 | Gamma camera | BIRADS 5 | 94.7% | 16 | 2 | 0 | 1 | 88.9% (67.0% to 96.7%) | 100.0% (20.8% to 99.2%) | 100.0% (80.2% to 99.8%) | 33.3% (6.7% to 79.0%) | 3.47 (2.92 to 4.14) | 0.18 (0.04 to 0.72)
| 29 | Gamma camera | Palpable lesion | 89.7% | 22 | 4 | 2 | 1 | 84.6% (66.3% to 93.7%) | 33.3% (6.7% to 79.0%) | 91.7% (73.9% to 97.5%) | 20.0% (4.1% to 62.6%) | 1.27 (1.08 to 1.50) | 0.46 (0.07 to 2.90)
| 24 | Gamma camera | Younger than 65 | 83.3% | 18 | 2 | 2 | 2 | 90.0% (69.7% to 97.0%) | 50.0% (15.4% to 84.6%) | 90.0% (69.7% to 97.0%) | 50.0% (15.4% to 84.6%) | 1.80 (1.56 to 2.08) | 0.20 (0.04 to 1.03)
Palmedo et al. 1997 ^58^ | 20 | Whole-body | All | 65.0% | 12 | 1 | 1 | 6 | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 6.46 (5.52 to 7.56) | 0.09 (0.01 to 0.60)
Holle et al. 1996 ^51^ | 50 | Gamma camera | All | 54.0% | 18 | 9 | 4 | 19 | 66.7% (47.8% to 81.2%) | 82.6% (62.7% to 92.8%) | 81.8% (61.3% to 92.5%) | 67.9% (49.3% to 82.0%) | 3.83 (2.94 to 5.01) | 0.40 (0.23 to 0.71)
| 31 | Gamma camera | Younger than 65 | 32.3% | 8 | 2 | 4 | 17 | 80.0% (48.9% to 94.0%) | 81.0% (59.9% to 92.1%) | 66.7% (39.0% to 86.0%) | 89.5% (68.4% to 96.8%) | 4.20 (3.08 to 5.73) | 0.25 (0.07 to 0.87)
| 19 | Gamma camera | 65 or older | 89.5% | 10 | 7 | 0 | 2 | 58.8% (36.0% to 78.3%) | 100.0% (34.0% to 99.3%) | 100.0% (71.7% to 99.7%) | 22.2% (6.7% to 54.9%) | 3.50 (2.37 to 5.17) | 0.50 (0.24 to 1.05)
Crowe et al. 1994 ^53^ | 37 | Whole-body | Lesions 1.0 cm or larger | 62.2% | 23 | 0 | 0 | 10 | 100.0% (85.3% to 99.9%) | 100.0% (71.7% to 99.7%) | 100.0% (85.3% to 99.9%) | 100.0% (71.7% to 99.7%) | 21.54 (20.32 to 22.84) | 0.02 (0.00 to 0.34)
| 24 | Whole-body | Palpable lesions 1.0 cm or larger | 79.2% | 19 | 0 | 0 | 5 | 100.0% (82.8% to 99.8%) | 100.0% (56.0% to 99.6%) | 100.0% (82.8% to 99.8%) | 100.0% (56.0% to 99.6%) | 11.70 (10.91 to 12.55) | 0.03 (0.00 to 0.43)
| 18 | Whole-body | BIRADS 3, lesions 1.0 cm or larger | 44.4% | 8 | 0 | 0 | 10 | 100.0% (67.0% to 99.7%) | 100.0% (71.7% to 99.7%) | 100.0% (67.0% to 99.7%) | 100.0% (71.7% to 99.7%) | 20.78 (17.73 to 24.35) | 0.06 (0.00 to 0.86)
| 14 | Whole-body | BIRADS 4–5, lesions 1.0 cm or larger | 100.0% | 14 | 0 | 0 | 0 | 100.0% (78.0% to 99.8%) | Could not calculate | 100.0% (78.0% to 99.8%) | Could not calculate | 1.93 (1.76 to 2.12) | 0.07 (0.00 to 1.91)
Tse et al. 1992 ^59^ | 14 | Whole-body | All | 71.4% | 8 | 2 | 0 | 4 | 80.0% (48.9% to 94.0%) | 100.0% (50.5% to 99.5%) | 100.0% (67.0% to 99.7%) | 66.7% (30.1% to 89.9%) | 7.73 (5.61 to 10.65) | 0.25 (0.08 to 0.78)

Evidence Table 31. Meta-analysis of Studies of PET for Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Hienisch et al. 2003 ^56^ | 40 | 7.4 | 68.0% (48.4% to 82.7%) | 73.3% (48.0% to 88.9%) | 81.0% (59.9% to 92.1%) | 57.9% (36.3% to 76.7%) | 2.55 (1.95 to 3.34) | 0.44 (0.23 to 0.83)
Walter et al. 2003 ^57^ | 42 | 7.9 | 63.2% (41.0% to 80.7%) | 91.3% (73.0% to 97.4%) | 85.7% (59.8% to 95.7%) | 75.0% (56.6% to 87.2%) | 7.26 (5.15 to 10.24) | 0.40 (0.22 to 0.74)
Yutani et al. 2000 ^55^ | 40 | 7.9 | 78.9% (63.6% to 88.8%) | 100.0% (34.0% to 99.3%) | 100.0% (88.4% to 99.9%) | 20.0% (6.0% to 51.1%) | 4.69 (3.98 to 5.54) | 0.26 (0.12 to 0.57)
Yutani et al. 1999 ^54^ | 30 | 8.8 | 100.0% (86.8% to 99.9%) | 50.0% (15.4% to 84.6%) | 92.9% (77.1% to 97.9%) | 100.0% (34.0% to 99.3%) | 1.96 (1.86 to 2.07) | 0.04 (0.00 to 0.66)
Palmedo et al. 1997 ^58^ | 20 | 7.9 | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 6.46 (5.52 to 7.56) | 0.09 (0.01 to 0.60)
Tse et al. 1992 ^59^ | 14 | 7.9 | 80.0% (48.9% to 94.0%) | 100.0% (50.5% to 99.5%) | 100.0% (67.0% to 99.7%) | 66.7% (30.1% to 89.9%) | 7.73 (5.61 to 10.65) | 0.25 (0.08 to 0.78)
6 studies | 186 lesions | Median 7.9 Moderate | At mean threshold 82.2% | At mean threshold 78.3% At 95% sensitivity 46.7% | At mean threshold 90.0% At 95% sensitivity 80.9% | At mean threshold 64.8% At 95% sensitivity 79.7% | Heterogeneous, no summary estimate calculated | 0.33 (0.24 to 0.46)
Heterogeneity tests | | Cumulative meta-analysis: last three studies
[underlined: D] | | New study | D 95% CI | Within 5% limits? | -LHR 95% CI | Within 5% limits?
I^2^ = 0.0% | | Yutani et al. 1999 ^54^ | 2.62 to 3.01 | No | 0.25 to 0.52 | No
Q = 3.37
p of Q = 0.64287
[underlined: +lnLHR] | | Palmedo et al. 1997 ^58^ | 2.78 to 3.10 | No | 0.24 to 0.49 | No
I^2^ = 73.1%
Q = 364.0
p of Q = 0.00000001
[underlined: -lnLHR] | | Tse et al. 1992 ^59^ | 2.88 to 3.17 | Yes | 0.24 to 0.46 | No
I^2^ = 12.3%
Q = 5.70
p of Q = 0.3363 | | | 5% limits 2.88 to 3.18 | Not stable | 5% limits 0.31 to 0.35 | Not stable

D = ln of diagnostic odds ratio

-LHR = negative likelihood ratio

-lnLHR- ln of negative likelihood ratio

+lnLHR = ln of positive likelihood ratio

## Studies of Scintimammography

Evidence Table 32. Included Studies of Scintimammography

Study | N patients | Quality score | Scintimammography parameters | Patients | Age (Range) | % 65 or older | % Female | % Post-menopausal | Ethnic makeup
Bekis et al. 2004 ^111^ | 35 | 8.3 | Planar, patient prone, 15 minutes after 740 MBq tracer, 256x256 | Women with suspicious non-palpable lesions detected by mammography. | Mean 51 (35 to 72) | Not reported | 100% | Not reported | Not reported
Fondrinier et al. 2004 ^113^ | 41 | 7.2 | Planar, patient prone, 5–10 minutes after 740 MBq tracer, 256x256 | Women with non-palpable microcalcifications, detected by mammography, that warranted biopsy. | Not reported | Not reported | 100% | Not reported | Not reported
Bone et al. 2003 ^461^ | 90 | 8.2 | Planar, patient prone and supine, 10 minutes after 700 MBq tracer, 256x256 | Patients scheduled for surgery after physical exam, mammography, and fine needle aspiration. | Mean 54 (33 to 81) | Not reported | Not reported | Not reported | Not reported
Krishnaiah et al. 2003 ^89^ | 95 | 7.4 | Planar, patient prone, 740 to 1,100 MBq tracer | Patients presenting with palpable lesions and/or abnormal mammograms who were scheduled for biopsy. Pregnant women were excluded. | Median 44 (28 to 86) | Not reported | 99% | Not reported | Not reported
Maunda et al. 2003 ^462^ | 38 | 7.8 | Planar, patient prone, 5 and 60 minutes after 740 to 1110 MBq tracer, 256x256 | Nonpregnant woman with a palpable breast lesion that was indeterminate on mammography (BIRADS 1–3). Women who had previous surgery for a breast lesion or prior chemotherapy or radiotherapy to the breast were excluded. | Median 28 (22 to 38) | 0% | 100% | Not reported | 100% African
Sampalis et al. 2003 ^82^ | 1734 | 6.0 | Planar, patient prone, 5 minutes after 740 to 1,100 MBq tracer, 128x128 | No inclusion criteria were reported. Pregnant women and patients younger than 18 were excluded. | Mean 56 (19 to 94) | Not reported | 100% | 40% | Not reported
Sanidas et al. 2003 ^100^ | 32 | 8.3 | Planar, patient prone, 15 minutes after 740 MBq tracer, 256x256 | Women with clinically and mammographically suspected breast cancer. | Mean 56 (36 to 86) | Not reported | 100% | 50% | Not reported
Wilczek et al. 2003 ^88^ | 96 | 8.6 | Planar, patient prone, 10 minutes after 700 MBq tracer, 256x256 | Age 30 years or older, scheduled for breast surgery. | Mean 54.4 (34 to 82) | Not reported | Not reported | Not reported | Not reported
Brem et al. 2002 ^463^ | 50 | 8.6 | Planar, patient prone, 5 to 10 minutes after 925 MBq tracer | All nonpregnant patients who were 18 years or older, with a palpable lesion with no mammographic correlate; or a possible multicentric tumor as seen by mammography or ultrasound; or asymmetric breast tissue shown on mammography, with no corresponding clinical or sonographic findings. | Mean 53 (30 to 80) | Not reported | Not reported | Not reported | Not reported
Khalkhali et al. 2002 ^83^ | 554 | 8.3 | Planar, patient prone, 5 minutes after 740 to 1,100 MBq tracer, 128x128 | Women scheduled for biopsy after mammography and/or physical examination. | Mean 52.2 | 20.3% | 100% | 61.6% | 69.3% White 15.0% Hispanic 14.2% Black 1.5% Asian
Leidenius et al. 2002 ^97^ | 46 | 7.9 | Planar, patient prone, 20 minutes after 740 MBq tracer, 128x128 | Consecutive patients referred to the hospital because of abnormal findings in clinical breast examination, mammography, or ultrasonography. | Median 58 (46 to 76) | Not reported | Not reported | Not reported | Not reported
Aguilar et al. 2001 ^110^ | 36 | 8.2 | Planar, patient prone, 10 minutes after 740 to 925 MBq tracer | All patients with nonpalpable lesions of the breast referred consecutively from a screening campaign. | (50 to 64) | Not reported | Not reported | 94.4% | Not reported
Alonso et al. 2001 ^103^ | 238 | 7.9 | Planar, patient prone, 10 minutes after 740 to 1,100 MBq tracer, 256x256 | Woman with a palpable breast lesion. Patients were excluded for pregnancy, previous surgery for a palpable breast lesion in the affected breast, or prior chemotherapy or radiation treatment to the affected breast. | Median 50 (19 to 84) | Not reported | 100% | 52% | Not reported
Gutfilen et al. 2001 ^101^ | 32 | 6.9 | Planar, patient prone, 15 minutes after 370 MBq tracer | Women with breast masses. Patients were excluded if they were pregnant, nursing, or had a history of prior breast surgery, or prior chemotherapy/radiotherapy to the breast. | (17 to 79) | Not reported | 100% | Not reported | Not reported
Imbriaco et al. 2001 ^98^ | 49 | 7.6 | Planar, patient prone and supine, 10 minutes after 555 MBq tracer, 256x256 | Patients with a suspicious breast lesion detected either by physical examination or by mammography and ultrasound. Patients were excluded if they were pregnant or lactating; younger than 18 years of age; or had a history of previous breast cancer. | Mean 49 (20 to 72) | 8.1% | Not reported | Not reported | Not reported
Koukouraki et al. 2001 ^91^ | 86 | 7.5 | Planar, patient prone, 15 minutes after 740 MBq tracer, 256x256 | Women with palpable lumps or women with negative physical examination and abnormal findings on mammography. | (25 to 78) | Not reported | 100% | 60.3% | Not reported
Lumachi et al. 2001 ^248^ | 134 | 7.5 | SPECT or planar, patient prone, 10 minutes after 750 MBq tracer | Women with breast masses 2 cm or less in diameter who had been selected for open breast biopsy. | Median 52 (32 to 78) | Not reported | 100% | Not reported | Not reported
Lumachi et al. 2001 ^250^ | 239 | 7.5 | SPECT or planar, patient prone, 10 minutes after 750 MBq tracer | Women with breast lesions who had been selected for breast biopsy on the basis of mammography findings and/or fine needle aspiration cytology. | Median 55 (32 to 87) | Not reported | 100% | 66.5% | Not reported
Papantoniou et al. 2001 ^99^ | 41 | 7.9 | Planar, patient prone, 10 to 20 minutes after 740 to 925 MBq tracer, 256x256 | Women, older than 21 years of age, presence of a suspicious breast lesion detected by palpation or mammography, recommended for biopsy. Patients with a history of previous breast cancer, previous mastectomy, a medically unstable condition due to severe arrhythmias, heart failure, or recent surgery were excluded, as were pregnant women. | Mean 55 | Not reported | 100% | Not reported | Not reported
Chen et al. 2000 ^108^ | 35 | 8.8 | Planar, patient prone and supine, 10 to 20 minutes after 740 MBq tracer | Women with suspicious breast lesions on clinical examination. | Mean 47.3 (27 to 80) | Not reported | 100% | Not reported | 100% Asian
Yutani et al. 2000 ^55^ | 40 | 8.8 | SPECT, patient supine, 5 minutes after 740 MBq tracer, 64x64 | Patients with suspicious lesions (detected by mammography, ultrasound, or physical exam) scheduled for excisional biopsy. | Mean 51 (25 to 86) | 15% | 100% | Not reported | Not reported
Danielsson et al. 1999 ^87^ | 96 | 8.6 | Planar, patient prone, 10 minutes after 700 MBq tracer, 256x256 | Age 30 years or older, scheduled for breast surgery. | Mean 54.4 (34 to 82) | Not reported | Not reported | Not reported | Not reported
Danielsson et al. 1999 ^464^ | 26^a^ | 8.6 | SPECT, patient supine, 40 minutes after 700 MBq tracer, 128x128 | Age 30 years or older, scheduled for breast surgery. | Mean 57 (35 to 82) | Not reported | Not reported | Not reported | Not reported
Obwegeser et al. 1999 ^90^ | 101 | 7.4 | SPECT, patient prone, immediately after 555 to 650 MBq tracer, 128x128; also planar, patient supine, 5 minutes after 555 to 560 MBq tracer | Women aged 40 or older selected for surgery by the outpatient breast unit. Pregnant women were excluded. | Not reported | Not reported | 100% | Not reported | Not reported
Tofani et al. 1999 ^85^ | 300 | 8.3 | Planar, patient prone and supine, 10 minutes after 740 MBq tracer, 256x256 | Women with suspicious breast masses on mammography or physical examination scheduled for surgery. | Mean 51.7 (27 to 78) | Not reported | 100% | 56.3% | Not reported
De Vincentis et al. 1998 ^465^ | 18 | 7.9 | Planar, patient prone, 60 minutes after 740 MBq tracer, 128x128 | Patients with breast masses detected by examination, including mammography. | Mean 71 | 100% | Not reported | Not reported | Not reported
Mekhmandarov et al. 1998 ^86^ | 140 | 8.8 | Planar, patient prone and supine, 10 to 20 minutes after 740 MBq tracer, 256x256 | Patients with a clinically palpable mass in the breast and/or suspicious mammographic finding. | Mean 61.4 (29 to 87) | Not reported | 99% | Not reported | Not reported
Uriarte et al. 1998 ^466^ | 78 | 7.9 | Planar, patient prone, 10 minutes after 740 MBq tracer | Women scheduled for biopsy after mammography. | (35 to 81) | Not reported | 100% | Not reported | Not reported
Alonso et al. 1997 ^467^ | 18 | 7.2 | Planar, patient prone, 5 minutes after 740 MBq tracer, 256x256 | Women with clinical suspicion of breast cancer and nonconclusive mammographic findings. | Not reported | Not reported | 100% | Not reported | Not reported
Ambrus et al. 1997 ^104^ | 51 | 7.5 | Planar, patient prone and supine, 5 minutes after 900 MBq tracer, 256x256 | Women with a palpable breast lesion, scheduled for surgery. | Mean 55 (19 to 77) | 33% | 100% | Not reported | Not reported
Carril et al. 1997 ^109^ | 41 | 7.9 | Planar, patient prone, 10 minutes after 740 MBq tracer | Women with non-palpable breast lesions, detected by mammography, that warranted biopsy. | (35 to 81) | Not reported | 100% | Not reported | Not reported
Chen et al. 1997 ^94^ | 61 | 8.3 | Planar, patient prone, 10 minutes after 740 MBq tracer | Patients referred for a suspicious breast lesion after clinical examination. | Mean 48.8 | Not reported | 98% | Not reported | 100% Asian
Palmedo et al. 1997 ^58^ | 20 | 7.9 | Planar and SPECT, patient prone, immediately to 10 minutes after 740 MBq tracer, 256x256 | Patients with suspicious lesions (detected by mammography or physical exam) scheduled for excisional biopsy. | Mean 58.4 (28 to 84) | Not reported | 100% | Not reported | Not reported
Schillaci et al. 1997 ^92^ | 63 | 8.8 | Planar, patient prone and supine, immediately after 370 MBq tracer, 128x128; and SPECT, patient supine, immediately after 370 MBq tracer, 64x64 | Female patients with suspicious lesions on mammography. | Mean 57 | Not reported | 100% | Not reported | Not reported
Scopinaro et al. 1997 ^84^ | 420 | 8.3 | Planar, patient prone, 60 to 120 minutes after 740 MBq tracer | Patients with a focal lesion or microcalcification detected on mammography. Patients were excluded if breasts were too dense to get an accurate mammography reading, and patients with advanced cancers were also excluded. | Mean 52 (26 to 79) | Not reported | Not reported | Not reported | Not reported
Scopinaro et al. 1997 ^468^ | 85 | 8.3 | Planar, patient prone, 60 minutes after 740 MBq tracer, 128x128 | Patients with mammographic results suspicious or highly suspicious (BIRADS 4-5), scheduled for biopsy or surgery. | Mean 53 (30 to 72) | Not reported | Not reported | Not reported | Not reported
Tiling et al. 1997 ^95^ | 56 | 8.3 | Planar, patient prone, 5 minutes after 740 MBq tracer, 256x256 | Women with abnormal findings on mammography and/or physical examination who were scheduled for surgery. | Mean 53 (22 to 80) | Not reported | 100% | Not reported | Not reported
Tiling et al. 1997 ^469^ | 82 | 7.9 | Planar, patient prone, 5 minutes after 740 MBq tracer, 256x256 | Women with indeterminate mammograms and/or physical exams. | Mean 50 (22 to 80) | Not reported | 100% | 46.4% | Not reported
Maffioli et al. 1996 ^112^ | 24 | 7.5 | Planar, patient prone, 30 to 40 minutes after 740 MBq tracer, 256x256 | Non-palpable suspicious lesions detected on mammography. | Mean 49.8 (39 to 67) | 8.3% | 100% | Not reported | Not reported
Palmedo et al. 1996 ^96^ | 56 | 7.9 | SPECT and planar, patient prone, 5 to 30 minutes after 740 MBq tracer, 256x256 | Women with a suspicious lesion detected by physical examination or by mammography. Patients with prior or concurrent breast cancer were excluded. | Mean 58 (22 to 81) | Not reported | 100% | Not reported | Not reported
Palmedo et al. 1996 ^106,^ ^107^ | 68 | 8.3 | SPECT and planar, patient prone, 5 to 30 minutes after 740 MBq tracer, 256x256 (planar), 64x64 (SPECT) | Women with suspicious lesions detected by physical examination or mammography. | Mean 54 (22 to 81) | Not reported | 100% | Not reported | Not reported
Villanueva-Meyer et al. 1996 ^93^ | 66 | 8.6 | Planar, patient prone, 15 minutes after 740 MBq tracer | 19 years or older, with a mammographic abnormality, and a candidate for surgical biopsy. Pregnant women and women with severe medical conditions were excluded. | Mean 52 (35 to 80) | Not reported | 100% | 66.6% | Not reported
Yuen-Green et al. 1996 ^102^ | 18 | 7.9 | Planar, patient prone, 5 minutes after 740 MBq tracer, 128x128 | Women with either a palpable breast mass and/or an abnormal mammograph for which biopsies were recommended. | Mean 53.9 | Not reported | 100% | Not reported | Not reported
Burak et al. 1994 ^105^ | 41 | 7.9 | Planar, 10 minutes after 720 MBq tracer | Women with palpable breast masses. | Mean 51 (29 to 73) | 9.7% | 100% | Not reported | Not reported

a. These patients were also included in Danielsson et al. 1999 ^87^

Evidence Table 33. Quality Assessment of Studies of Scintimammography

Question | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16 | 17 | 18 | score
Study | consecutive | consistent | prospective | Case control | funding | valid reference | gold standard | interreader | blinding | blinding | blinding | blinding | full testing | threshold | intervening | attrition | conclusions | discrepancy | standardized
Bekis et al. 2004 ^111^ | r | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.3
Fondrinier et al. 2004 ^113^ | r | y | y | y | r | y | y | n | y | r | n | r | y | y | y | y | y | y | 7.2
Bone et al. 2003 ^461^ | y | y | y | y | r | y | y | n | y | r | y | r | y | y | y | y | y | y | 8.2
Krishnaiah et al. 2003 ^89^ | r | y | y | y | r | y | y | n | y | r | r | r | y | y | y | y | y | y | 7.4
Maunda et al. 2003 ^462^ | r | y | y | y | n | y | y | y | y | r | r | r | y | y | y | y | y | y | 7.8
Sampalis et al. 2003 ^82^ | r | y | y | y | r | y | y | r | y | r | r | r | y | r | y | n | y | n | 6.0
Sandidas et al. 2003 ^100^ | r | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.3
Wilczek et al. 2003 ^88^ | y | y | y | y | y | y | y | n | y | r | y | r | y | y | y | y | y | y | 8.6
Brem et al. 2002 ^463^ | y | y | y | y | n | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.6
Khalkhali et al. 2002 ^83^ | r | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.3
Leidenius et al. 2002 ^97^ | y | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.9
Aguilar et al. 2001 ^110^ | y | y | y | y | r | y | y | n | y | r | y | r | y | y | y | y | y | y | 8.2
Alonso et al. 2001 ^467^ | r | y | y | y | r | y | y | y | y | r | y | r | y | y | y | r | y | y | 7.9
Gutfilen et al. 2001 ^101^ | r | y | y | y | r | y | y | r | y | r | r | r | y | y | y | n | y | y | 6.9
Imbriaco et al. 2001 ^98^ | y | y | y | y | r | y | y | n | y | r | n | r | y | y | y | y | y | y | 7.6
Koukouraki et al. 2001 ^91^ | r | r | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.5
Lumachi et al. 2001 ^248^ | r | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.5
Lumachi et al. 2001 ^250^ | r | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.5
Papantoniou et al. 2001 ^99^ | r | y | y | y | r | y | y | y | y | r | r | r | y | y | y | y | y | y | 7.9
Chen et al. 2000 ^108^ | y | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.8
Yutani et al. 2000 ^55^ | y | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.8
Danielsson et al. 1999 ^87^ | y | y | y | y | y | y | y | n | y | r | y | r | y | y | y | y | y | y | 8.6
Danielsson et al. 1999 ^464^ | y | y | y | y | y | y | y | n | y | r | y | r | y | y | y | y | y | y | 8.6
Obwegeser et al. 1999 ^90^ | r | n | y | y | r | y | y | y | y | r | r | r | y | y | y | y | y | y | 7.4
Tofani et al. 1999 ^85^ | y | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 8.3
De Vincentis et al. 1998 ^465^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Mekhmandarov et al. 1998 ^86^ | y | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.8
Uriarte et al. 1998 ^466^ | r | y | y | y | r | y | y | y | y | r | r | r | y | y | y | y | y | y | 7.9
Alonso et al. 1997 ^103^ | r | y | y | y | n | y | y | y | y | r | y | r | y | r | y | n | y | y | 7.2
Ambrus et al. 1997 ^104^ | r | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.5
Carril et al. 1997 ^109^ | r | y | y | y | r | y | y | y | y | r | r | r | y | y | y | y | y | y | 7.9
Chen et al. 1997 ^94^ | y | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 8.3
Palmedo et al. 1997 ^58^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Schillaci et al. 1997 ^92^ | r | y | y | y | y | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.8
Scopinaro et al. 1997 ^84^ | r | y | y | y | y | y | y | y | y | r | y | r | y | y | y | r | y | y | 8.3
Scopinaro et al. 1997 ^468^ | r | y | y | y | y | y | y | y | y | r | y | r | y | r | y | y | y | y | 8.3
Tiling et al. 1997 ^95^ | r | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.3
Tiling et al. 1997 ^469^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Maffioli et al. 1996 ^112^ | y | y | y | y | r | y | y | r | y | r | r | r | y | r | y | y | y | y | 7.5
Palmedo et al. 1996 ^96^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Palmedo et al. 1996 ^106^ and ^107^ | r | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.3
Villanueva-Meyer et al. 1996 ^93^ | y | y | y | y | n | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.6
Yuen-Green et al. 1996 ^102^ | r | y | y | y | r | y | y | y | y | r | y | r | y | r | y | y | y | y | 7.9
Burak et al. 1994 ^105^ | r | y | y | y | r | y | y | y | y | r | r | r | y | y | y | y | y | y | 7.9

y = yes

n = no

r = not reported

Evidence Table 34. Diagnostic Test Characteristics of Scintimammography

Study | N lesions | Patient subgroup | Prevalence | True positive | False negative | False positive | True negative | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Planar Imaging
Bekis et al. 2004 ^111^ | 35 | Non-palpable lesions | 37.1% | 11 | 2 | 4 | 18 | 84.6% (57.6% to 95.4%) | 81.8% (61.3% to 92.5%) | 73.3% (48.0% to 88.9%) | 90.0% (69.7% to 97.0%) | 4.65 (3.69 to 5.87) | 0.19 (0.05 to 0.68)
| 13 | Non-palpable lesions, with microcalcifications | 46.2% | 4 | 2 | 0 | 7 | 66.7% (30.1% to 89.9%) | 100.0% (64.0% to 99.6%) | 100.0% (50.5% to 99.5%) | 77.8% (45.1% to 93.3%) | 10.29 (5.92 to 17.87) | 0.38 (0.14 to 1.05)
Fondrinier et al. 2004 ^113^ | 45 | Non-palpable lesions, with microcalcifications | 53.3% | 14 | 10 | 4 | 17 | 58.3% (38.8% to 75.4%) | 81.0% (59.9% to 92.1%) | 77.8% (54.7% to 90.8%) | 63.0% (44.2% to 78.4%) | 3.06 (2.18 to 4.29) | 0.51 (0.31 to 0.86)
| 13 | Non-palpable lesions, with microcalcifications, larger than 10 mm | 66.6% | 6.8 | 1.86 | 1.24 | 3.1 | 78.5% (45.2% to 93.8%) | 71.4% (28.9% to 93.4%) | 84.6% (49.8% to 96.4%) | 62.5% (24.8% to 89.1%) | 2.75 (1.94 to 3.89) | 0.30 (0.07 to 1.23)
| 32 | Non-palpable lesions, with microcalcifications, 10 mm or smaller | 36.4% | 2.91 | 8.73 | 2.91 | 17.41 | 25.0% (9.0% to 53.7%) | 85.7% (64.7% to 94.9%) | 50.0% (18.7% to 81.3%) | 66.6% (47.4% to 81.4%) | 1.75 (0.65 to 4.72) | 0.88 (0.60 to 1.28)
Bone et al. 2003 ^461^ | 111 | Positive by FNA | 71.2% | 65 | 14 | 8 | 24 | 82.3% (72.4% to 89.1%) | 75.0% (57.8% to 86.6%) | 89.0% (79.8% to 94.3%) | 63.2% (47.3% to 76.5%) | 3.29 (2.97 to 3.65) | 0.24 (0.14 to 0.40)
| 40 | Positive by FNA, 10 mm or smaller | 50.0% | 10 | 10 | 3 | 17 | 50.0% (30.0% to 70.0%) | 85.0% (63.8% to 94.6%) | 76.9% (49.6% to 91.6%) | 63.0% (44.2% to 78.4%) | 3.33 (2.15 to 5.17) | 0.59 (0.37 to 0.95)
| 71 | Positive by FNA, larger than 10 mm | 83.1% | 55 | 4 | 5 | 7 | 93.2% (83.7% to 97.2%) | 58.3% (32.0% to 80.5%) | 91.7% (81.8% to 96.3%) | 63.6% (35.4% to 84.6%) | 2.24 (2.09 to 2.40) | 0.12 (0.04 to 0.34)
Krishnaiah et al. 2003 ^89^ | 104 | All | 23.1% | 20 | 4 | 14 | 66 | 83.3% (64.0% to 93.1%) | 82.5% (72.7% to 89.2%) | 58.8% (42.2% to 73.6%) | 94.3% (86.1% to 97.7%) | 4.76 (3.98 to 5.69) | 0.20 (0.08 to 0.50)
| 59 | Palpable lesions | 27.1% | 14 | 2 | 9 | 34 | 87.5% (63.7% to 96.3%) | 79.1% (64.7% to 88.5%) | 60.9% (40.8% to 77.7%) | 94.4% (81.7% to 98.3%) | 4.18 (3.47 to 5.03) | 0.16 (0.04 to 0.58)
| 45 | Non-palpable lesions | 17.8% | 6 | 2 | 5 | 32 | 75.0% (40.8% to 92.5%) | 86.5% (71.9% to 94.0%) | 54.5% (28.1% to 78.6%) | 94.1% (80.7% to 98.2%) | 5.55 (3.72 to 8.28) | 0.29 (0.09 to 0.97)
Maunda et al. 2003 ^462^ | 38 | Palpable lesion that scored BIRADS 1 to 3 on mammography | 5.3% | 2 | 0 | 0 | 36 | 100.0% (34.0% to 99.3%) | 100.0% (90.1% to 99.9%) | 100.0% (34.0% to 99.3%) | 100.0% (90.1% to 99.9%) | 61.67 (37.18 to 102.29) | 0.17 (0.01 to 2.12)
Sampalis et al. 2003 ^82^ | 1243 | All | 16.2% | 186 | 15 | 136 | 906 | 92.5% (88.0% to 95.4%) | 86.9% (84.8% to 88.9%) | 57.8% (52.3% to 63.0%) | 98.4% (97.3% to 99.0%) | 7.09 (6.82 to 7.37) | 0.09 (0.05 to 0.14)
| 696 | BIRADS 1 or 2 | 1.9% | 10 | 3 | 84 | 599 | 76.9% (49.6% to 91.6%) | 87.7% (85.0% to 89.9%) | 10.6% (5.9% to 18.5%) | 99.5% (98.5% to 99.8%) | 6.25 (4.64 to 8.42) | 0.26 (0.10 to 0.71)
| 348 | BIRADS 3 or 4 | 21.3% | 65 | 9 | 24 | 250 | 87.8% (78.4% to 93.4%) | 91.2% (87.3% to 94.0%) | 73.0% (63.0% to 81.1%) | 96.5% (93.5% to 98.1%) | 10.03 (9.21 to 10.92) | 0.13 (0.07 to 0.25)
| 199 | BIRADS 5 | 57.3% | 111 | 3 | 28 | 57 | 97.4% (92.5% to 99.1%) | 67.1% (56.5% to 76.1%) | 79.9% (72.4% to 85.6%) | 95.0% (86.2% to 98.2%) | 2.96 (2.87 to 3.05) | 0.04 (0.01 to 0.12)
Sanidas et al. 2003 ^100^ | 33 | All | 86.1% | 28 | 3 | 1 | 4 | 90.3% (74.9% to 96.5%) | 80.0% (37.4% to 95.9%) | 96.6% (82.6% to 99.2%) | 57.1% (25.2% to 83.9%) | 4.52 (4.02 to 5.07) | 0.12 (0.04 to 0.39)
Wilczek et al. 2003 ^88^ | 119 | All | 69.7% | 71 | 12 | 9 | 27 | 85.5% (76.3% to 91.5%) | 75.0% (58.9% to 86.1%) | 88.8% (79.9% to 93.9%) | 69.2% (53.5% to 81.3%) | 3.42 (3.13 to 3.74) | 0.19 (0.11 to 0.34)
| 65 | Palpable lesions | 70.8% | 42 | 4 | 7 | 12 | 91.3% (79.5% to 96.5%) | 63.2% (41.0% to 80.7%) | 85.7% (73.2% to 92.8%) | 75.0% (50.4% to 89.6%) | 2.48 (2.27 to 2.71) | 0.14 (0.05 to 0.37)
| 54 | Non-palpable lesions | 68.5% | 29 | 8 | 2 | 15 | 78.4% (62.7% to 88.5%) | 88.2% (65.4% to 96.5%) | 93.5% (79.1% to 98.1%) | 65.2% (44.9% to 81.1%) | 6.66 (5.62 to 7.89) | 0.25 (0.13 to 0.46)
Brem et al. 2002 ^463^ | 58 | Palpable and BIRADS 1, or non-palpable and BIRADS 4 or 5 | 48.3% | 18 | 10 | 2 | 28 | 64.3% (45.8% to 79.2%) | 93.3% (78.5% to 98.0%) | 90.0% (69.7% to 97.0%) | 73.7% (57.9% to 84.9%) | 9.64 (7.32 to 12.71) | 0.38 (0.23 to 0.63)
Khalkhali et al. 2002 ^83^ | 580 | All | 39.9% | 153 | 61 | 67 | 255 | 71.5% (65.1% to 77.1%) | 79.2% (74.4% to 83.3%) | 69.5% (63.2% to 75.2%) | 80.7% (76.0% to 84.7%) | 3.44 (3.16 to 3.74) | 0.36 (0.29 to 0.45)
| 276 | Dense breast tissue | 38.6% | 69 | 29 | 34 | 122 | 70.4% (60.7% to 78.5%) | 78.2% (71.1% to 83.9%) | 67.0% (57.4% to 75.3%) | 80.8% (73.7% to 86.3%) | 3.23 (2.84 to 3.67) | 0.38 (0.28 to 0.52)
| 304 | Fatty breast tissue | 41.1% | 84 | 32 | 33 | 133 | 72.4% (63.6% to 79.7%) | 80.1% (73.4% to 85.5%) | 71.8% (63.0% to 79.1%) | 80.6% (73.9% to 85.9%) | 3.64 (3.26 to 4.08) | 0.34 (0.25 to 0.47)
Leidenius et al. 2002 ^97^ | 49 | All | 63.3% | 24 | 7 | 7 | 11 | 77.4% (60.1% to 88.5%) | 61.1% (38.6% to 79.6%) | 77.4% (60.1% to 88.5%) | 61.1% (38.6% to 79.6%) | 1.99 (1.65 to 2.41) | 0.37 (0.17 to 0.78)
Aguilar et al. 2001 ^110^ | 37 | Non-palpable lesions | 51.4% | 15 | 4 | 5 | 13 | 78.9% (56.5% to 91.3%) | 72.2% (49.1% to 87.3%) | 75.0% (53.0% to 88.6%) | 76.5% (52.6% to 90.2%) | 2.84 (2.25 to 3.58) | 0.29 (0.12 to 0.73)
Alonso et al. 2001 ^103^ | 245 | Palpable lesions | 77.1% | 157 | 32 | 13 | 43 | 83.1% (77.1% to 87.7%) | 76.8% (64.2% to 85.8%) | 92.4% (87.3% to 95.4%) | 57.3% (46.0% to 67.9%) | 3.58 (3.36 to 3.82) | 0.22 (0.16 to 0.31)
Gutfilen et al. 2001 ^101^ | 30 | All | 76.7% | 22 | 1 | 4 | 3 | 95.7% (78.7% to 99.0%) | 42.9% (16.1% to 74.8%) | 84.6% (66.3% to 93.7%) | 75.0% (30.1% to 94.9%) | 1.67 (1.53 to 1.83) | 0.10 (0.01 to 0.83)
| 22 | Younger than 65 | 72.7% | 15 | 1 | 4 | 2 | 93.8% (71.4% to 98.6%) | 33.3% (10.1% to 69.9%) | 78.9% (56.5% to 91.3%) | 66.7% (21.0% to 93.3%) | 1.41 (1.24 to 1.60) | 0.19 (0.02 to 1.71)
| 23 | Lesions larger than 10 mm | 87.0% | 20 | 0 | 2 | 1 | 100.0% (83.5% to 99.8%) | 33.3% (6.7% to 79.0%) | 90.9% (72.0% to 97.3%) | 100.0% (20.8% to 99.2%) | 1.56 (1.46 to 1.67) | 0.06 (0.00 to 1.30)
| 27 | Palpable lesions | 85.2% | 22 | 1 | 2 | 2 | 95.7% (78.7% to 99.0%) | 50.0% (15.4% to 84.6%) | 91.7% (73.9% to 97.5%) | 66.7% (21.0% to 93.3%) | 1.91 (1.75 to 2.09) | 0.09 (0.01 to 0.75)
Imbriaco et al. 2001 ^98^ | 49 | All | 52.0% | 21 | 5 | 3 | 21 | 80.8% (62.0% to 91.3%) | 87.5% (68.8% to 95.5%) | 87.5% (68.8% to 95.5%) | 80.8% (62.0% to 91.3%) | 6.46 (5.36 to 7.79) | 0.22 (0.10 to 0.49)
| 45 | Younger than 65 | 54.3% | 20 | 5 | 3 | 18 | 80.0% (60.7% to 91.0%) | 85.7% (65.2% to 94.8%) | 87.0% (67.7% to 95.3%) | 78.3% (58.0% to 90.2%) | 5.60 (4.60 to 6.81) | 0.23 (0.10 to 0.52)
| 23 | Lesions 10 mm or smaller | 39.1% | 6 | 3 | 1 | 13 | 66.7% (35.4% to 87.7%) | 92.9% (68.2% to 98.5%) | 85.7% (48.4% to 97.0%) | 81.3% (56.8% to 93.2%) | 9.33 (5.88 to 14.81) | 0.36 (0.14 to 0.91)
| 26 | Lesions larger than 10 mm | 61.5% | 14 | 2 | 2 | 8 | 87.5% (63.7% to 96.3%) | 80.0% (48.9% to 94.0%) | 87.5% (63.7% to 96.3%) | 80.0% (48.9% to 94.0%) | 4.38 (3.64 to 5.27) | 0.16 (0.04 to 0.59)
Koukouraki et al. 2001 ^91^ | 86 | All | 74.1% | 80 | 6 | 5 | 25 | 93.0% (85.5% to 96.7%) | 83.3% (66.3% to 92.5%) | 94.1% (86.9% to 97.4%) | 80.6% (63.6% to 90.7%) | 5.58 (5.27 to 5.91) | 0.08 (0.04 to 0.18)
| 78 | Palpable lesions | 85.9% | 63 | 4 | 3 | 8 | 94.0% (85.5% to 97.6%) | 72.7% (43.4% to 90.0%) | 95.5% (87.4% to 98.4%) | 66.7% (39.0% to 86.0%) | 3.45 (3.25 to 3.66) | 0.08 (0.03 to 0.23)
| 38 | Non-palpable lesions | 50.0% | 17 | 2 | 2 | 17 | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 8.50 (7.29 to 9.92) | 0.12 (0.03 to 0.44)
Papantoniou et al. 2001 ^99^ | 41 | All | 63.4% | 23 | 3 | 1 | 14 | 88.5% (70.8% to 95.8%) | 93.3% (69.9% to 98.6%) | 95.8% (79.5% to 99.1%) | 82.4% (58.8% to 93.6%) | 13.27 (11.55 to 15.25) | 0.12 (0.04 to 0.36)
Chen et al. 2000 ^108^ | 38 | Palpable lesions | 51.4% | 14 | 4 | 2 | 15 | 77.8% (54.7% to 90.8%) | 88.2% (65.4% to 96.5%) | 87.5% (63.7% to 96.3%) | 78.9% (56.5% to 91.3%) | 6.61 (5.16 to 8.46) | 0.25 (0.10 to 0.61)
Danielsson et al. 1999 ^87^ | 121 | All | 71.1% | 72 | 14 | 9 | 26 | 83.7% (74.5% to 90.0%) | 74.3% (57.9% to 85.7%) | 88.9% (80.1% to 94.0%) | 65.0% (49.5% to 77.8%) | 3.26 (2.97 to 3.57) | 0.22 (0.13 to 0.37)
Obwegeser et al. 1999 ^90^ | 103^a^ | All | 54.4% | 26 | 30 | 6 | 41 | 46.4% (34.0% to 59.3%) | 87.2% (74.7% to 93.9%) | 81.3% (64.6% to 91.0%) | 57.7% (46.1% to 68.5%) | 3.64 (2.75 to 4.82) | 0.61 (0.47 to 0.80)
Tofani et al. 1999 ^85^ | 300 | All | 72.7% | 194 | 24 | 14 | 68 | 89.0% (84.1% to 92.5%) | 82.9% (73.3% to 89.5%) | 93.3% (89.0% to 95.9%) | 73.9% (64.1% to 81.8%) | 5.21 (4.97 to 5.46) | 0.13 (0.09 to 0.20)
| 43 | Lesion 1 cm or smaller | 67.4% | 14 | 15 | 0 | 14 | 48.3% (31.4% to 65.5%) | 100.0% (78.0% to 99.8%) | 100.0% (78.0% to 99.8%) | 48.3% (31.4% to 65.5%) | 14.50 (10.02 to 20.99) | 0.53 (0.37 to 0.77)
| 257 | Lesion larger than 1 cm | 73.5% | 180 | 9 | 14 | 54 | 95.2% (91.2% to 97.4%) | 79.4% (68.3% to 87.3%) | 92.8% (88.2% to 95.6%) | 85.7% (74.9% to 92.2%) | 4.63 (4.48 to 4.78) | 0.06 (0.03 to 0.11)
| 140 | Post-menopausal | 78.6% | 103 | 7 | 4 | 26 | 93.6% (87.4% to 96.8%) | 86.7% (70.2% to 94.5%) | 96.3% (90.7% to 98.5%) | 78.8% (62.2% to 89.2%) | 7.02 (6.69 to 7.37) | 0.07 (0.04 to 0.15)
| 117 | Pre- menopausal | 67.5% | 77 | 2 | 10 | 28 | 97.5% (91.1% to 99.2%) | 73.7% (57.9% to 84.9%) | 88.5% (80.1% to 93.6%) | 93.3% (78.5% to 98.0%) | 3.70 (3.57 to 3.84) | 0.03 (0.01 to 0.14)
De Vincentis et al. 1998 ^465^ | 18 | 65 or older | 88.9% | 11 | 5 | 0 | 2 | 68.8% (44.4% to 85.6%) | 100.0% (34.0% to 99.3%) | 100.0% (73.6% to 99.7%) | 28.6% (8.6% to 64.1%) | 4.06 (2.92 to 5.64) | 0.39 (0.17 to 0.91)
Mekhmandarov et al. 1998 ^86^ | 140 | All | 60.7% | 71 | 14 | 8 | 47 | 83.5% (74.2% to 89.9%) | 85.5% (73.8% to 92.4%) | 89.9% (81.2% to 94.7%) | 77.0% (65.0% to 85.7%) | 5.74 (5.23 to 6.31) | 0.19 (0.12 to 0.31)
| 85 | Palpable | 71.8% | 58 | 3 | 6 | 18 | 95.1% (86.4% to 98.2%) | 75.0% (55.0% to 87.8%) | 90.6% (80.9% to 95.5%) | 85.7% (65.2% to 94.8%) | 3.80 (3.59 to 4.03) | 0.07 (0.02 to 0.20)
| 55 | Non-palpable | 43.6% | 13 | 11 | 2 | 29 | 54.2% (35.1% to 72.0%) | 93.5% (79.1% to 98.1%) | 86.7% (61.9% to 96.0%) | 72.5% (57.1% to 83.8%) | 8.40 (5.81 to 12.13) | 0.49 (0.31 to 0.76)
| 31 | Lesion 1 to 1.5 cm | 74.2% | 18 | 5 | 2 | 6 | 78.3% (58.0% to 90.2%) | 75.0% (40.8% to 92.5%) | 90.0% (69.7% to 97.0%) | 54.5% (28.1% to 78.6%) | 3.13 (2.52 to 3.88) | 0.29 (0.12 to 0.69)
| 58 | Lesion 1.5 cm or larger | 100.0% | 52 | 6 | 0 | 0 | 89.7% (79.1% to 95.1%) | #DIV/0! | 100.0% (92.9% to 99.9%) | 0.0% (0.4% to 39.6%) | 1.78 (1.63 to 1.95) | 0.22 (0.03 to 1.78)
Uriarte et al. 1998 ^466^ | 78 | BIRADS 3 to 5 | 52.6% | 38 | 3 | 19 | 18 | 92.7% (80.4% to 97.4%) | 48.6% (33.5% to 64.1%) | 66.7% (53.7% to 77.5%) | 85.7% (65.2% to 94.8%) | 1.80 (1.66 to 1.97) | 0.15 (0.05 to 0.47)
| 28 | BIRADS 5 | 85.7% | 22 | 2 | 0 | 4 | 91.7% (73.9% to 97.5%) | 100.0% (50.5% to 99.5%) | 100.0% (84.8% to 99.8%) | 66.7% (30.1% to 89.9%) | 9.00 (7.90 to 10.26) | 0.11 (0.03 to 0.37)
| 30 | BIRADS 4 | 43.3% | 12 | 1 | 8 | 9 | 92.3% (66.4% to 98.3%) | 52.9% (31.0% to 73.7%) | 60.0% (38.7% to 78.0%) | 90.0% (59.3% to 97.9%) | 1.96 (1.68 to 2.29) | 0.15 (0.02 to 1.01)
| 20 | BIRADS 3 | 20.0% | 4 | 0 | 11 | 5 | 100.0% (50.5% to 99.5%) | 31.3% (14.4% to 55.6%) | 26.7% (11.1% to 52.0%) | 100.0% (56.0% to 99.6%) | 1.33 (0.99 to 1.78) | 0.31 (0.02 to 4.68)
Alonso et al. 1997 ^467^ | 18 | Clinically suspicious lesions with non­conclusive mammo­graphy findings | 55.6% | 8 | 2 | 2 | 6 | 80.0% (48.9% to 94.0%) | 75.0% (40.8% to 92.5%) | 80.0% (48.9% to 94.0%) | 75.0% (40.8% to 92.5%) | 3.20 (2.35 to 4.36) | 0.27 (0.07 to 0.98)
Ambrus et al. 1997 ^104^ | 51 | Palpable lesions | 78.4% | 20 | 20 | 1 | 10 | 50.0% (35.2% to 64.8%) | 90.9% (61.9% to 98.1%) | 95.2% (77.0% to 99.0%) | 33.3% (19.3% to 51.3%) | 5.50 4.03 to 7.50) | 0.55 (0.38 to 0.79)
| 17 | Palpable lesions, 65 or older | 94.1% | 8 | 8 | 0 | 1 | 50.0% (28.1% to 71.9%) | 100.0% (20.8% to 99.2%) | 100.0% (67.0% to 99.7%) | 11.1% (2.4% to 43.8%) | 2.00 (1.24 to 3.22) | 0.67 (0.26 to 1.69)
| 33 | Palpable lesions, younger than 65 | 72.7% | 12 | 12 | 1 | 8 | 50.0% (31.5% to 68.5%) | 88.9% (56.2% to 97.6%) | 92.3% (66.4% to 98.3%) | 40.0% (22.0% to 61.3%) | 4.50 (3.02 to 6.71) | 0.56 (0.35 to 0.89)
Carril et al. 1997 ^109^ | 41 | Non-palpable lesions | 53.7% | 19 | 3 | 8 | 11 | 86.4% (66.5% to 95.1%) | 57.9% (36.3% to 76.7%) | 70.4% (51.5% to 84.0%) | 78.6% (52.3% to 92.2%) | 2.05 (1.74 to 2.42) | 0.24 (0.08 to 0.72)
| 17 | Non-palpable lesions, BIRADS 5 | 94.1% | 14 | 2 | 0 | 1 | 87.5% (63.7% to 96.3%) | 100.0% (20.8% to 99.2%) | 100.0% (78.0% to 99.8%) | 33.3% (6.7% to 79.0%) | 3.41 (2.80 to 4.16) | 0.20 (0.05 to 0.79)
| 15 | Non-palpable lesions, BIRADS 4 | 26.7% | 3 | 1 | 4 | 7 | 75.0% (30.1% to 94.9%) | 63.6% (35.4% to 84.6%) | 42.9% (16.1% to 74.8%) | 87.5% (52.6% to 97.4%) | 2.06 (1.17 to 3.63) | 0.39 (0.07 to 2.27)
Chen et al. 1997 ^94^ | 63 | All | 50.8% | 25 | 7 | 3 | 28 | 78.1% (61.2% to 88.8%) | 90.3% (74.9% to 96.5%) | 89.3% (72.6% to 96.1%) | 80.0% (64.0% to 89.8%) | 8.07 (6.72 to 9.70) | 0.24 (0.12 to 0.47)
Palmedo et al. 1997 ^58^ | 20^b^ | All | 65.0% | 12 | 1 | 1 | 6 | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 6.46 (5.52 to 7.56) | 0.09 (0.01 to 0.60)
Schillaci et al. 1997 ^92^ | 66^c^ | All | 63.6% | 36 | 6 | 2 | 22 | 85.7% (72.0% to 93.2%) | 91.7% (73.9% to 97.5%) | 94.7% (82.5% to 98.4%) | 78.6% (60.4% to 89.6%) | 10.29 (9.09 to 11.64) | 0.16 (0.07 to 0.33)
Scopinaro et al. 1997 ^84^ | 449 | All | 79.1% | 301 | 54 | 9 | 85 | 84.8% (80.7% to 88.1%) | 90.4% (82.7% to 94.8%) | 97.1% (94.5% to 98.4%) | 61.2% (52.8% to 68.8%) | 8.86 (8.47 to 9.25) | 0.17 (0.13 to 0.22)
| 283 | Palpable lesions | 79.5% | 219 | 6 | 6 | 52 | 97.3% (94.3% to 98.7%) | 89.7% (79.1% to 95.1%) | 97.3% (94.3% to 98.7%) | 89.7% (79.1% to 95.1%) | 9.41 (9.21 to 9.61) | 0.03 (0.01 to 0.07)
| 166 | Non-palpable lesions | 78.3% | 81 | 49 | 3 | 33 | 62.3% (53.7% to 70.2%) | 91.7% (78.0% to 97.0%) | 96.4% (89.9% to 98.7%) | 40.2% (30.3% to 51.1%) | 7.48 (6.54 to 8.55) | 0.41 (0.32 to 0.52)
Scopinaro et al. 1997 ^468^ | 91 | BIRADS 4 or 5 | 57.1% | 43 | 9 | 4 | 35 | 82.7% (70.2% to 90.5%) | 89.7% (76.3% to 95.8%) | 91.5% (79.9% to 96.5%) | 79.5% (65.4% to 88.7%) | 8.06 (7.12 to 9.13) | 0.19 (0.11 to 0.35)
Tiling et al. 1997 ^95^ | 56 | All | 58.9% | 29 | 4 | 4 | 19 | 87.9% (72.5% to 95.0%) | 82.6% (62.7% to 92.8%) | 87.9% (72.5% to 95.0%) | 82.6% (62.7% to 92.8%) | 5.05 (4.45 to 5.74) | 0.15 (0.06 to 0.37)
Tiling et al. 1997 ^469^ | 82 | Indeterminate mammograms and/or physical findings | 35.4% | 23 | 6 | 16 | 37 | 79.3% (61.5% to 90.0%) | 69.8% (56.4% to 80.4%) | 59.0% (43.4% to 72.9%) | 86.0% (72.6% to 93.3%) | 2.63 (2.18 to 3.16) | 0.30 (0.14 to 0.62)
Maffioli et al. 1996 ^112^ | 24 | Non-palpable | 58.3% | 7 | 7 | 1 | 9 | 50.0% (26.9% to 73.1%) | 90.0% (59.3% to 97.9%) | 87.5% (52.6% to 97.4%) | 56.3% (33.2% to 76.8%) | 5.00 (2.96 to 8.44) | 0.56 (0.32 to 0.98)
| 22 | Non-palpable, younger than 65 years | 59.1% | 7 | 6 | 1 | 8 | 53.8% (29.2% to 76.7%) | 88.9% (56.2% to 97.6%) | 87.5% (52.6% to 97.4%) | 57.1% (32.6% to 78.5%) | 4.85 (2.93 to 8.02) | 0.52 (0.28 to 0.98)
| 21 | Non-palpable, microcalcifications | 61.9% | 7 | 6 | 1 | 7 | 53.8% (29.2% to 76.7%) | 87.5% (52.6% to 97.4%) | 87.5% (52.6% to 97.4%) | 53.8% (29.2% to 76.7%) | 4.31 (2.60 to 7.13) | 0.53 (0.28 to 1.00)
Palmedo et al. 1996 ^106,^ ^107^ | 54^d^ | All | 44.4% | 21 | 3 | 4 | 26 | 87.5% (68.8% to 95.5%) | 86.7% (70.2% to 94.5%) | 84.0% (65.2% to 93.4%) | 89.7% (73.4% to 96.3%) | 6.56 (5.64 to 7.63) | 0.14 (0.05 to 0.42)
| 14^d^ | Non-palpable | 28.6% | 1 | 3 | 0 | 10 | 25.0% (5.1% to 69.9%) | 100.0% (71.7% to 99.7%) | 100.0% (20.8% to 99.2%) | 76.9% (49.6% to 91.6%) | 6.60 (1.73 to 25.18) | 0.73 (0.41 to 1.32)
| 40^d^ | Palpable | 51.3% | 20 | 0 | 4 | 15 | 100.0% (83.5% to 99.8%) | 78.9% (56.5% to 91.3%) | 83.3% (64.0% to 93.1%) | 100.0% (79.2% to 99.8%) | 4.34 (4.06 to 4.64) | 0.03 (0.00 to 0.48)
Villanueva-Meyer et al. 1996 ^93^ | 66 | All | 53.0% | 29 | 6 | 2 | 29 | 82.9% (67.2% to 91.8%) | 93.5% (79.1% to 98.1%) | 93.5% (79.1% to 98.1%) | 82.9% (67.2% to 91.8%) | 12.84 (11.05 to 14.93) | 0.18 (0.09 to 0.38)
Yuen-Green et al. 1996 ^102^ | 21 | All | 28.6% | 5 | 1 | 1 | 14 | 83.3% (43.5% to 96.5%) | 93.3% (69.9% to 98.6%) | 83.3% (43.5% to 96.5%) | 93.3% (69.9% to 98.6%) | 12.50 (8.74 to 17.88) | 0.18 (0.03 to 1.07)
Burak et al. 1994 ^105^ | 41 | Palpable lesions | 65.9% | 24 | 3 | 2 | 12 | 88.9% (71.8% to 96.0%) | 85.7% (59.8% to 95.7%) | 92.3% (75.6% to 97.7%) | 80.0% (54.7% to 92.7%) | 6.22 (5.45 to 7.11) | 0.13 (0.04 to 0.38)
| 37 | Palpable lesions, younger than 65 | 62.2% | 20 | 3 | 2 | 12 | 87.0% (67.7% to 95.3%) | 85.7% (59.8% to 95.7%) | 90.9% (72.0% to 97.3%) | 80.0% (54.7% to 92.7%) | 6.09 (5.20 to 7.13) | 0.15 (0.05 to 0.45)
SPECT imaging
Yutani et al. 2000 ^55^ | 40 | All | 95.0% | 29 | 9 | 1 | 1 | 76.3% (60.7% to 86.9%) | 50.0% (10.0% to 90.0%) | 96.7% (83.1% to 99.3%) | 10.0% (2.1% to 40.7%) | 1.53 (1.28 to 1.82) | 0.47 (0.11 to 2.12)
| 34 | Younger than 65 | 94.1% | 25 | 7 | 1 | 1 | 78.1% (61.2% to 88.8%) | 50.0% (10.0% to 90.0%) | 96.2% (80.8% to 99.2%) | 12.5% (2.6% to 47.4%) | 1.56 (1.30 to 1.88) | 0.44 (0.09 to 2.03)
| 29 | Lesion 1.5 cm or larger | 96.6% | 24 | 4 | 1 | 0 | 85.7% (68.4% to 94.1%) | 0.0% (0.8% to 79.2%) | 96.0% (80.2% to 99.1%) | 0.0% (0.5% to 49.5%) | 1.13 (0.96 to 1.32) | 0.62 (0.05 to 7.92)
| 37 | Palpable lesion | 97.3% | 27 | 9 | 1 | 0 | 75.0% (58.9% to 86.1%) | 0.0% (0.8% to 79.2%) | 96.4% (82.0% to 99.2%) | 0.0% (0.3% to 30.5%) | 0.99 (0.82 to 1.20) | 1.03 (0.09 to 12.05)
| 30 | BIRADS 5 | 93.3% | 24 | 4 | 1 | 1 | 85.7% (68.4% to 94.1%) | 50.0% (10.0% to 90.0%) | 96.0% (80.2% to 99.1%) | 20.0% (4.1% to 62.6%) | 1.71 (1.47 to 1.99) | 0.29 (0.05 to 1.50)
Danielsson et al. 1999 ^464^ | 34 | All | 67.6% | 14 | 9 | 4 | 7 | 60.9% (40.8% to 77.7%) | 63.6% (35.4% to 84.6%) | 77.8% (54.7% to 90.8%) | 43.8% (23.2% to 66.8%) | 1.67 (1.21 to 2.32) | 0.61 (0.31 to 1.21)
Obwegeser et al. 1999 ^90^ | 103^a^ | All | 54.4% | 39 | 17 | 10 | 37 | 69.6% (56.6% to 80.0%) | 78.7% (65.0% to 87.9%) | 79.6% (66.3% to 88.4%) | 68.5% (55.2% to 79.3%) | 3.27 (2.75 to 3.89) | 0.39 (0.25 to 0.59)
Palmedo et al. 1997 ^58^ | 20^b^ | All | 65.0% | 12 | 1 | 2 | 5 | 92.3% (66.4% to 98.3%) | 71.4% (35.9% to 91.4%) | 85.7% (59.8% to 95.7%) | 83.3% (43.5% to 96.5%) | 3.23 (2.76 to 3.78) | 0.11 (0.02 to 0.75)
Schillaci et al. 1997 ^92^ | 66^c^ | All | 63.6% | 39 | 3 | 3 | 21 | 92.9% (80.8% to 97.4%) | 87.5% (68.8% to 95.5%) | 92.9% (80.8% to 97.4%) | 87.5% (68.8% to 95.5%) | 7.43 (6.83 to 8.08) | 0.08 (0.03 to 0.25)
Palmedo et al. 1996 ^106,^ ^107^ | 54^d^ | All | 44.4% | 20 | 4 | 5 | 25 | 83.3% (64.0% to 93.1%) | 83.3% (66.3% to 92.5%) | 80.0% (60.7% to 91.0%) | 86.2% (69.3% to 94.3%) | 5.00 (4.18 to 5.98) | 0.20 (0.08 to 0.50)
| 14^d^ | Non-palpable | 28.6% | 0 | 4 | 1 | 9 | 0.0% (0.5% to 49.5%) | 90.0% (59.3% to 97.9%) | 0.0% (0.8% to 79.2%) | 69.2% (42.3% to 87.1%) | 0.73 (0.05 to 10.17) | 1.04 (0.72 to 1.52)
| 40^d^ | Palpable | 51.3% | 20 | 0 | 4 | 15 | 100.0% (83.5% to 99.8%) | 78.9% (56.5% to 91.3%) | 83.3% (64.0% to 93.1%) | 100.0% (79.2% to 99.8%) | 4.34 (4.06 to 4.64) | 0.03 (0.00 to 0.48)
Data from planar and SPECT imaging combined
Lumachi et al. 2001 ^248^ | 134 | Lesions 2 cm or less in diameter | 79.9% | 87 | 20 | 2 | 25 | 81.3% (72.8% to 87.5%) | 92.6% (76.4% to 97.8%) | 97.8% (92.1% to 99.3%) | 55.6% (41.2% to 69.0%) | 10.98 (10.02 to 12.02) | 0.20 (0.13 to 0.30)
| 51 | Lesions 1 cm or less in diameter | 62.7% | 25 | 7 | 1 | 18 | 78.1% (61.2% to 88.8%) | 94.7% (75.1% to 98.8%) | 96.2% (80.8% to 99.2%) | 72.0% (52.4% to 85.6%) | 14.84 (12.36 to 17.83) | 0.23 (0.12 to 0.45)
Lumachi et al. 2001 ^250^ | 239 | All | 86.6% | 182 | 25 | 2 | 30 | 87.9% (82.8% to 91.7%) | 93.8% (79.7% to 98.1%) | 98.9% (96.1% to 99.7%) | 54.5% (41.5% to 66.9%) | 14.07 (13.37 to 14.80) | 0.13 (0.09 to 0.19)
Palmedo et al. 1996 ^96^ | 56 | All | 48.2% | 23 | 4 | 10 | 19 | 85.2% (67.4% to 93.9%) | 65.5% (47.3% to 80.0%) | 69.7% (52.6% to 82.5%) | 82.6% (62.7% to 92.8%) | 2.47 (2.11 to 2.89) | 0.23 (0.09 to 0.58)
| 43 | Palpable | 51.2% | 20 | 2 | 8 | 13 | 90.9% (72.0% to 97.3%) | 61.9% (40.9% to 79.1%) | 71.4% (52.9% to 84.6%) | 86.7% (61.9% to 96.0%) | 2.39 (2.09 to 2.72) | 0.15 (0.04 to 0.57)
| 13 | Non-palpable | 38.5% | 3 | 2 | 2 | 6 | 60.0% (23.3% to 87.9%) | 75.0% (40.8% to 92.5%) | 60.0% (23.3% to 87.9%) | 75.0% (40.8% to 92.5%) | 2.40 (1.17 to 4.91) | 0.53 (0.17 to 1.68)
Palmedo et al. 1996 ^106,^ ^107^ | 68^d^ | All | 42.6% | 24 | 5 | 7 | 32 | 82.8% (65.3% to 92.3%) | 82.1% (67.2% to 90.9%) | 77.4% (60.1% to 88.5%) | 86.5% (71.9% to 94.0%) | 4.61 (3.91 to 5.44) | 0.21 (0.09 to 0.47)

FNA = fine needle aspiration

a. The same patients studied by both SPECT and planar imaging.

b. The same patients studied by both SPECT and planar imaging.

c. The same patients studied by both SPECT and planar imaging.

d. The same patients studied by both SPECT and planar imaging.

Evidence Table 35. Meta-analysis of Studies of Scintimammography for Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Sampalis et al. 2003 ^82^ | 1,243 | 6 | 92.5% (88.0% to 95.4%) | 86.9% (84.8% to 88.9%) | 57.8% (52.3% to 63.0%) | 98.4% (97.3% to 99.0%) | 7.09 (6.82 to 7.37) | 0.09 (0.05 to 0.14)
Khalkhali et al. 2002 ^83^ | 580 | 8.3 | 71.5% (65.1% to 77.1%) | 79.2% (74.4% to 83.3%) | 69.5% (63.2% to 75.2%) | 80.7% (76.0% to 84.7%) | 3.44 (3.16 to 3.74) | 0.36 (0.29 to 0.45)
Scopinaro et al. 1997 ^84^ | 449 | 8.3 | 84.8% (80.7% to 88.1%) | 90.4% (82.7% to 94.8%) | 97.1% (94.5% to 98.4%) | 61.2% (52.8% to 68.8%) | 8.86 (8.47 to 9.25) | 0.17 (0.13 to 0.22)
Tofani et al. 1999 ^85^ | 300 | 8.3 | 89.0% (84.1% to 92.5%) | 82.9% (73.3% to 89.5%) | 93.3% (89.0% to 95.9%) | 73.9% (64.1% to 81.8%) | 5.21 (4.97 to 5.46) | 0.13 (0.09 to 0.20)
Mekhmandarov et al. 1998 ^86^ | 140 | 8.8 | 83.5% (74.2% to 89.9%) | 85.5% (73.8% to 92.4%) | 89.9% (81.2% to 94.7%) | 77.0% (65.0% to 85.7%) | 5.74 (5.23 to 6.31) | 0.19 (0.12 to 0.31)
Danielsson et al. 1999 ^87^ | 121 | 8.6 | 83.7% (74.5% to 90.0%) | 74.3% (57.9% to 85.7%) | 88.9% (80.1% to 94.0%) | 65.0% (49.5% to 77.8%) | 3.26 (2.97 to 3.57) | 0.22 (0.13 to 0.37)
Wilczek et al. 2003 ^88^ | 119 | 8.6 | 85.5% (76.3% to 91.5%) | 75.0% (58.9% to 86.1%) | 88.8% (79.9% to 93.9%) | 69.2% (53.5% to 81.3%) | 3.42 (3.13 to 3.74) | 0.19 (0.11 to 0.34)
Krishnaiah et al. 2003 ^89^ | 104 | 7.4 | 83.3% (64.0% to 93.1%) | 82.5% (72.7% to 89.2%) | 58.8% (42.2% to 73.6%) | 94.3% (86.1% to 97.7%) | 4.76 (3.98 to 5.69) | 0.20 (0.08 to 0.50)
Obwegeser et al. 1999 ^90^ | 103 | 7.4 | 46.4% (34.0% to 59.3%) | 87.2% (74.7% to 93.9%) | 81.3% (64.6% to 91.0%) | 57.7% (46.1% to 68.5%) | 3.64 (2.75 to 4.82) | 0.61 (0.47 to 0.80)
Koukouraki et al. 2001 ^91^ | 86 | 7.5 | 93.0% (85.5% to 96.7%) | 83.3% (66.3% to 92.5%) | 94.1% (86.9% to 97.4%) | 80.6% (63.6% to 90.7%) | 5.58 (5.27 to 5.91) | 0.08 (0.04 to 0.18)
Schillaci et al. 1997 ^92^ | 66 | 8.8 | 85.7% (72.0% to 93.2%) | 91.7% (73.9% to 97.5%) | 94.7% (82.5% to 98.4%) | 78.6% (60.4% to 89.6%) | 10.29 (9.09 to 11.64) | 0.16 (0.07 to 0.33)
Villanueva-Meyer et al. 1996 ^93^ | 66 | 8.6 | 82.9% (67.2% to 91.8%) | 93.5% (79.1% to 98.1%) | 93.5% (79.1% to 98.1%) | 82.9% (67.2% to 91.8%) | 12.84 (11.05 to 14.93) | 0.18 (0.09 to 0.38)
Chen et al. 1997 ^94^ | 63 | 8.1 | 78.1% (61.2% to 88.8%) | 90.3% (74.9% to 96.5%) | 89.3% (72.6% to 96.1%) | 80.0% (64.0% to 89.8%) | 8.07 (6.72 to 9.70) | 0.24 (0.12 to 0.47)
Tiling et al. 1997 ^95^ | 56 | 8.3 | 87.9% (72.5% to 95.0%) | 82.6% (62.7% to 92.8%) | 87.9% (72.5% to 95.0%) | 82.6% (62.7% to 92.8%) | 5.05 (4.45 to 5.74) | 0.15 (0.06 to 0.37)
Palmedo et al. 1996 ^96^ | 54 | 7.9 | 87.5% (68.8% to 95.5%) | 86.7% (70.2% to 94.5%) | 84.0% (65.2% to 93.4%) | 89.7% (73.4% to 96.3%) | 6.56 (5.64 to 7.63) | 0.14 (0.05 to 0.42)
Leidenius et al. 2002 ^97^ | 49 | 7.9 | 77.4% (60.1% to 88.5%) | 61.1% (38.6% to 79.6%) | 77.4% (60.1% to 88.5%) | 61.1% (38.6% to 79.6%) | 1.99 (1.65 to 2.41) | 0.37 (0.17 to 0.78)
Imbriaco et al. 2001 ^98^ | 49 | 7.6 | 80.8% (62.0% to 91.3%) | 87.5% (68.8% to 95.5%) | 87.5% (68.8% to 95.5%) | 80.8% (62.0% to 91.3%) | 6.46 (5.36 to 7.79) | 0.22 (0.10 to 0.49)
Papantoniou et al. 2001 ^99^ | 41 | 7.9 | 88.5% (70.8% to 95.8%) | 93.3% (69.9% to 98.6%) | 95.8% (79.5% to 99.1%) | 82.4% (58.8% to 93.6%) | 13.27 (11.55 to 15.25) | 0.12 (0.04 to 0.36)
Sanidas et al. 2003 ^100^ | 33 | 8.3 | 90.3% (74.9% to 96.5%) | 80.0% (37.4% to 95.9%) | 96.6% (82.6% to 99.2%) | 57.1% (25.2% to 83.9%) | 4.52 (4.02 to 5.07) | 0.12 (0.04 to 0.39)
Gutfilen et al. 2001 ^101^ | 30 | 6.9 | 95.7% (78.7% to 99.0%) | 42.9% (16.1% to 74.8%) | 84.6% (66.3% to 93.7%) | 75.0% (30.1% to 94.9%) | 1.67 (1.53 to 1.83) | 0.10 (0.01 to 0.83)
Yuen-Green et al. 1996 ^102^ | 21 | 7.9 | 83.3% (43.5% to 96.5%) | 93.3% (69.9% to 98.6%) | 83.3% (43.5% to 96.5%) | 93.3% (69.9% to 98.6%) | 12.50 (8.74 to 17.88) | 0.18 (0.03 to 1.07)
Palmedo et al. 1997 ^58^ | 20 | 7.9 | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 92.3% (66.4% to 98.3%) | 85.7% (48.4% to 97.0%) | 6.46 (5.52 to 7.56) | 0.09 (0.01 to 0.60)
22 studies | 3,793 lesions | Median 8.0 Moderate | Heterogeneous, no summary estimates calculated.
Heterogeneity tests of D | | | I^2^ = 69%
| | | Q = 67.23
| | | p of Q = 0.0000000009

D= ln of the diagnostic odds ratio

Evidence Table 36. Meta-regression of Studies of Scintimammography for Suspicious Breast Lesions

Study | D | Standard error of D | Year of publication | Quality score | Size of study | Prevalence of disease % | S | Tracer | Time elapsed
Sampalis et al. 2003 ^82^ | 4.38 | 2.09 | 2003 | 6 | 1243 | 16.17% | 0.59 | 740 to 1,100 | 5
Khalkhali et al. 2002 ^83^ | 2.25 | 1.50 | 2002 | 8.3 | 580 | 39.93% | -0.42 | 740 to 1,100 | 5
Scopinaro et al. 1997 ^84^ | 3.91 | 1.98 | 1997 | 8.3 | 449 | 79.06% | -0.49 | 740 | 90
Tofani et al. 1999 ^85^ | 3.62 | 1.90 | 1999 | 8.3 | 300 | 72.67% | 0.52 | 740 | 10
Mekhmandarov et al. 1998 ^86^ | 3.32 | 1.82 | 1998 | 8.8 | 140 | 60.71% | -0.13 | 740 | 15
Danielsson et al. 1999 ^87^ | 2.64 | 1.62 | 1999 | 8.6 | 121 | 71.07% | 0.58 | 700 | 10
Wilczek et al. 2003 ^88^ | 2.81 | 1.68 | 2003 | 8.6 | 119 | 69.75% | 0.68 | 700 | 10
Krishnaiah et al. 2003 ^89^ | 3.04 | 1.74 | 2003 | 7.4 | 104 | 23.08% | -0.01 | 740 to 1,100 | 1
Obwegeser et al. 1999 ^90^ | 1.71 | 1.31 | 1999 | 7.4 | 103 | 54.37% | -1.99 | 555 to 650 | 1
Koukouraki et al. 2001 ^91^ | 4.05 | 2.01 | 2001 | 7.5 | 86 | 74.14% | 0.98 | 740 | 15
Schillaci et al. 1997 ^92^ | 3.92 | 1.98 | 1997 | 8.8 | 66 | 63.64% | -0.47 | 370 | 1
Villanueva-Meyer et al. 1996 ^93^ | 3.98 | 2.00 | 1996 | 8.6 | 66 | 53.03% | -0.96 | 740 | 15
Chen et al. 1997 ^94^ | 3.32 | 1.82 | 1997 | 8.1 | 63 | 50.79% | -0.87 | 740 | 10
Tiling et al. 1997 ^95^ | 3.35 | 1.83 | 1997 | 8.3 | 56 | 58.93% | 0.41 | 740 | 5
Palmedo et al. 1996 ^96^ | 3.59 | 1.89 | 1996 | 7.9 | 54 | 44.44% | 0.04 | 740 | 17
Leidenius et al. 2002 ^97^ | 1.61 | 1.27 | 2002 | 7.9 | 49 | 63.27% | 0.76 | 740 to 1,100 | 20
Imbriaco et al. 2001 ^98^ | 3.18 | 1.78 | 2001 | 7.6 | 49 | 52.00% | -0.45 | 555 | 10
Papantoniou et al. 2001 ^99^ | 4.17 | 2.04 | 2001 | 7.9 | 41 | 63.41% | -0.36 | 740 to 925 | 15
Sanidas et al. 2003 ^100^ | 3.20 | 1.79 | 2003 | 8.3 | 33 | 86.11% | 1.00 | 740 | 15
Gutfilen et al. 2001 ^101^ | 2.46 | 1.57 | 2001 | 6.9 | 30 | 76.67% | 2.96 | 370 | 15
Yuen-Green et al. 1996 ^102^ | 3.57 | 1.89 | 1996 | 7.9 | 21 | 28.57% | -0.97 | 740 | 5
Palmedo et al. 1997 ^58^ | 3.59 | 1.89 | 1997 | 7.9 | 20 | 65.00% | 0.65 | 740 | 5
p value | | | 0.167 | 0.745 | 0.428 | 0.781 | 0.951 | 0.433 to 0.518 | 0.442
No model could be fitted with these variables that explained the heterogeneity.

D = ln of diagnostic odds ratio

SE = standard error

S = ln of measure of threshold

Evidence Table 37. Meta-analysis of Studies of Scintimammography for Palpable Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Scopinaro et al. 1997 ^84^ | 283 | 8.3 | 97.3% (94.3% to 98.7%) | 89.7% (79.1% to 95.1%) | 97.3% (94.3% to 98.7%) | 89.7% (79.1% to 95.1%) | 9.41 (9.21 to 9.61) | 0.03 (0.01 to 0.07)
Alonso et al. 2001 ^103^ | 245 | 7.9 | 83.1% (77.1% to 87.7%) | 76.8% (64.2% to 85.8%) | 92.4% (87.3% to 95.4%) | 57.3% (46.0% to 67.9%) | 3.58 (3.36 to 3.82) | 0.22 (0.16 to 0.31)
Mekhmandarov et al. 1998 ^86^ | 85 | 8.8 | 95.1% (86.4% to 98.2%) | 75.0% (55.0% to 87.8%) | 90.6% (80.9% to 95.5%) | 85.7% (65.2% to 94.8%) | 3.80 (3.59 to 4.03) | 0.07 (0.02 to 0.20)
Koukouraki et al. 2001 ^91^ | 78 | 7.5 | 94.0% (85.5% to 97.6%) | 72.7% (43.4% to 90.0%) | 95.5% (87.4% to 98.4%) | 66.7% (39.0% to 86.0%) | 3.45 (3.25 to 3.66) | 0.08 (0.03 to 0.23)
Wilczek et al. 2003 ^88^ | 65 | 8.6 | 91.3% (79.5% to 96.5%) | 63.2% (41.0% to 80.7%) | 85.7% (73.2% to 92.8%) | 75.0% (50.4% to 89.6%) | 2.48 (2.27 to 2.71) | 0.14 (0.05 to 0.37)
Krishnaiah et al. 2003 ^89^ | 59 | 7.4 | 87.5% (63.7% to 96.3%) | 79.1% (64.7% to 88.5%) | 60.9% (40.8% to 77.7%) | 94.4% (81.7% to 98.3%) | 4.18 (3.47 to 5.03) | 0.16 (0.04 to 0.58)
Ambrus et al. 1997 ^104^ | 51 | 7.5 | 50.0% (35.2% to 64.8%) | 90.9% (61.9% to 98.1%) | 95.2% (77.0% to 99.0%) | 33.3% (19.3% to 51.3%) | 5.50 4.03 to 7.50) | 0.55 (0.38 to 0.79)
Burak et al. 1994 ^105^ | 41 | 7.9 | 88.9% (71.8% to 96.0%) | 85.7% (59.8% to 95.7%) | 92.3% (75.6% to 97.7%) | 80.0% (54.7% to 92.7%) | 6.22 (5.45 to 7.11) | 0.13 (0.04 to 0.38)
Palmedo et al. 1996 ^106^ ^107^ | 40 | 7.9 | 100.0% (83.5% to 99.8%) | 78.9% (56.5% to 91.3%) | 83.3% (64.0% to 93.1%) | 100.0% (79.2% to 99.8%) | 4.34 (4.06 to 4.64) | 0.03 (0.00 to 0.48)
Chen et al. 2000 ^108^ | 38 | 8.8 | 77.8% (54.7% to 90.8%) | 88.2% (65.4% to 96.5%) | 87.5% (63.7% to 96.3%) | 78.9% (56.5% to 91.3%) | 6.61 (5.16 to 8.46) | 0.25 (0.10 to 0.61)
Gutfilen et al. 2001 ^101^ | 27 | 6.9 | 95.7% (78.7% to 99.0%) | 50.0% (15.4% to 84.6%) | 91.7% (73.9% to 97.5%) | 66.7% (21.0% to 93.3%) | 1.91 (1.75 to 2.09) | 0.09 (0.01 to 0.75)
11 studies | 1,012 lesions | median 7.9 Moderate | Heterogeneous, no summary estimates calculated.
Heterogeneity tests of D | | | I^2^ = 57%
| | | Q = 23.46 p
| | | p of Q = 0.00916

D = ln of the diagnostic odds ratio

Evidence Table 38. Meta-regression of Studies of Scintimammography for Palpable Lesions

Study | D | Standard error of D | Year of publication | Quality score | Size of study | Prevalence of disease % | S | Tracer | Time elapsed
Scopinaro et al. 1997 ^84^ | 5.61 | 0.58 | 1997 | 8.30 | 283 | 79.51% | 1.43 | 740 | 90
Alonso et al. 2001 ^103^ | 2.75 | 0.37 | 2001 | 7.90 | 245 | 77.14% | 0.41 | 740 to 1100 | 10
Mekhmandarov et al. 1998 ^86^ | 3.86 | 0.71 | 1998 | 8.80 | 85 | 71.76% | 1.77 | 740 | 15
Koukouraki et al. 2001 ^91^ | 3.53 | 0.80 | 2001 | 7.50 | 78 | 85.90% | 1.76 | 740 | 15
Wilczek et al. 2003 ^88^ | 2.76 | 0.68 | 2003 | 8.60 | 65 | 70.77% | 1.73 | 700 | 10
Krishnaiah et al. 2003 ^89^ | 3.05 | 0.78 | 2003 | 7.40 | 59 | 27.12% | 0.47 | 740 to 1100 | 1
Ambrus et al. 1997 ^104^ | 1.95 | 0.93 | 1997 | 7.50 | 51 | 78.43% | -1.95 | 900 | 5
Burak et al. 1994 ^105^ | 3.56 | 0.90 | 1994 | 7.90 | 41 | 65.85% | 0.34 | 720 | 10
Palmedo et al. 1996 ^106^ ^107^ | 4.95 | 1.53 | 1996 | 7.90 | 40 | 51.28% | 2.48 | 740 | 18
Chen et al. 2000 ^108^ | 2.99 | 0.87 | 2000 | 8.80 | 38 | 51.43% | -0.65 | 740 | 15
Gutfilen et al. 2001 ^101^ | 2.71 | 1.23 | 2001 | 6.90 | 27 | 85.19% | 2.71 | 370 | 15
p value | | | 0.1910 | 0.4640 | 0.1770 | 0.809 | 0.177 | 0.422 to 0.961 | 0.0040
D = 2.81 + 0.033 time elapsed, p = 0.0040
95% confidence intervals: constant (2.18 to 3.43), coefficient (0.012 to 0.054)

D = ln of diagnostic odds ratio

SE = standard error

S = ln of measure of threshold

Evidence Table 39. Meta-analysis of Studies of Scintimammography for Non-palpable Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Scopinaro et al. 1997 ^84^ | 166 | 8.3 | 62.3% (53.7% to 70.2%) | 91.7% (78.0% to 97.0%) | 96.4% (89.9% to 98.7%) | 40.2% (30.3% to 51.1%) | 7.48 (6.54 to 8.55) | 0.41 (0.32 to 0.52)
Mekhmandarove et al. 1998 ^86^ | 55 | 8.8 | 54.2% (35.1% to 72.0%) | 93.5% (79.1% to 98.1%) | 86.7% (61.9% to 96.0%) | 72.5% (57.1% to 83.8%) | 8.40 (5.81 to 12.13) | 0.49 (0.31 to 0.76)
Wilczek et al. 2003 ^88^ | 54 | 8.6 | 78.4% (62.7% to 88.5%) | 88.2% (65.4% to 96.5%) | 93.5% (79.1% to 98.1%) | 65.2% (44.9% to 81.1%) | 6.66 (5.62 to 7.89) | 0.25 (0.13 to 0.46)
Krishnaiah et al. 2003 ^89^ | 45 | 7.4 | 75.0% (40.8% to 92.5%) | 86.5% (71.9% to 94.0%) | 54.5% (28.1% to 78.6%) | 94.1% (80.7% to 98.2%) | 5.55 (3.72 to 8.28) | 0.29 (0.09 to 0.97)
Carril et al. 1997 ^109^ | 41 | 7.9 | 86.4% (66.5% to 95.1%) | 57.9% (36.3% to 76.7%) | 70.4% (51.5% to 84.0%) | 78.6% (52.3% to 92.2%) | 2.05 (1.74 to 2.42) | 0.24 (0.08 to 0.72)
Koukouraki et al. 2001 ^91^ | 38 | 7.5 | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 89.5% (68.4% to 96.8%) | 8.50 (7.29 to 9.92) | 0.12 (0.03 to 0.44)
Aguilar et al. 2001 ^110^ | 37 | 8.2 | 78.9% (56.5% to 91.3%) | 72.2% (49.1% to 87.3%) | 75.0% (53.0% to 88.6%) | 76.5% (52.6% to 90.2%) | 2.84 (2.25 to 3.58) | 0.29 (0.12 to 0.73)
Bekis et al. 2004 ^111^ | 35 | 8.3 | 84.6% (57.6% to 95.4%) | 81.8% (61.3% to 92.5%) | 73.3% (48.0% to 88.9%) | 90.0% (69.7% to 97.0%) | 4.65 (3.69 to 5.87) | 0.19 (0.05 to 0.68)
Maffioli et al. 1996 ^112^ | 24 | 7.5 | 50.0% (26.9% to 73.1%) | 90.0% (59.3% to 97.9%) | 87.5% (52.6% to 97.4%) | 56.3% (33.2% to 76.8%) | 5.00 (2.96 to 8.44) | 0.56 (0.32 to 0.98)
Palmedo et al. 1996 ^106^ ^107^ | 14 | 8.3 | 25.0% (5.1% to 69.9%) | 100.0% (71.7% to 99.7%) | 100.0% (20.8% to 99.2%) | 76.9% (49.6% to 91.6%) | 6.60 (1.73 to 25.18) | 0.73 (0.41 to 1.32)
10 studies | 509 lesions | Median 8.3 Moderate | At mean threshold 68.7% | At mean threshold 84.8% At 95% sensitivity 39.2% | At mean threshold 85.7% At 95% sensitivity 67.4% | At mean threshold 67.2% At 95% sensitivity 54.1% | Heterogeneous, no summary estimate calculated | 0.41 (0.34 to 0.49)
Heterogeneity tests | Cumulative meta-analysis, last three studies
[underlined: D] | New study | D 95% CI | Within 5% limits? | -LHR 95% CI | Within 5% limits?
I^2^ = 0% | Bekis et al. 2004 ^111^ | 2.60 to 2.48 | Yes | 0.31 to 0.45 | No
Q = 4.03
p of Q = 0.90925
[underlined: -LHR] | Maffioli et al. 1996 ^112^ | 2.60 to 2.49 | Yes | 0.32 to 0.47
I^2^ = 38.5%
Q = 14.6
p of Q = 0.10165
[underlined: +LHR] | Palmedo et al. 1996 ^106^ ^,^ ^107^ | 2.57 to 2.47 | Yes | 0.34 to 0.49 | No
I^2^ = 57.2%
Q = 229.1
p of Q = 0.0000001 | | 5% limits2.68 to 2.42 | Robust | 5% limits 0.39 to 0.43 | Not robust

D = ln of diagnostic odds ratio

-LHR = negative likelihood ratio

-lnLHR = ln of negative likelihood ratio

+lnLHR = ln of positive likelihood ratio

Evidence Table 40. Meta-analysis of Studies of Scintimammography for Non-palpable Lesions with Microcalcifications

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Fondrinier et al. 2004 ^113^ | 45 | 7.2 | 58.3% (38.8% to 75.4%) | 81.0% (59.9% to 92.1%) | 77.8% (54.7% to 90.8%) | 63.0% (44.2% to 78.4%) | 3.06 (2.18 to 4.29) | 0.51 (0.31 to 0.86)
Maffioli et al. 1996 ^112^ | 21 | 7.5 | 53.8% (29.2% to 76.7%) | 87.5% (52.6% to 97.4%) | 87.5% (52.6% to 97.4%) | 53.8% (29.2% to 76.7%) | 4.31 (2.60 to 7.13) | 0.53 (0.28 to 1.00)
Bekis et al. 2004 ^111^ | 13 | 8.3 | 66.7% (30.1% to 89.9%) | 100.0% (64.0% to 99.6%) | 100.0% (50.5% to 99.5%) | 77.8% (45.1% to 93.3%) | 10.29 (5.92 to 17.87) | 0.38 (0.14 to 1.05)
3 studies | 79 lesions | Median 7.5 Moderate | 58.1% (43.3% to 72.9%) | 86.1% (74.8% to 97.4%) | 83.3% (72.2% to 94.5%) | 63.3% (47.6% to 79.0%) | 4.27 (3.47 to 5.26) | 0.50 (0.32 to 0.78)
Heterogeneity tests | Cumulative meta-analysis, last three studies
[underlined: D] | New study | Sensitivity 95% CI | Within 5% limits? | Specificity 95% CI | Within 5% limits? | pLHR 95% CI | nLHR 95% CI | Within 5% limits?
I^2^ = 0% | Fondrinier et al. 2004 ^113^ | 38.6% to 78.1% | No | 64.2% to 97.7% | No | 2.2 to 4.2 | 0.27 to 0.97 | No
Q = 0.83
p of Q = 0.66001
[underlined: -LHR] | Maffioli et al. 1996 ^112^ | 40.8% to 72.7% | No | 69.0% to 96.5% | No | 2.6 to 4.4 | 0.32 to 0.86 | No
I^2^ = 0%
Q = 0.317
p of Q = 0.8535
[underlined: +LHR] | Bekis et al. 2004 ^111^ | 43.4% to 72.9% | No | 74.8% to 97.4% | No | 3.5 to 5.3 | 0.32 to 0.78 | No
I^2^ = 0%
Q = 13.45
p of Q = 1.000
| | 5% limits 55.5% to 61.0% | Not robust | 5% limits 81.8% to 90.4% | Not robust | 5% limits 4.1 to 4.5 | 5% limits 0.48 to 0.53 | Not robust

Evidence Table 41. Meta-analysis of Studies of Scintimammography for Lesions Larger than 10 mm

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Tofani et al. 1999 ^85^ | 257 | 8.3 | 95.2% (91.2% to 97.4%) | 79.4% (68.3% to 87.3%) | 92.8% (88.2% to 95.6%) | 85.7% (74.9% to 92.2%) | 4.63 (4.48 to 4.78) | 0.06 (0.03 to 0.11)
Imbriaco et al. 2001 ^98^ | 26 | 7.6 | 87.5% (63.7% to 96.3%) | 80.0% (48.9% to 94.0%) | 87.5% (63.7% to 96.3%) | 80.0% (48.9% to 94.0%) | 4.38 (3.64 to 5.27) | 0.16 (0.04 to 0.59)
Gutfilen et al. 2001 ^101^ | 23 | 6.9 | 100.0% (83.5% to 99.8%) | 33.3% (6.7% to 79.0%) | 90.9% (72.0% to 97.3%) | 100.0% (20.8% to 99.2%) | 1.56 (1.46 to 1.67) | 0.06 (0.00 to 1.30)
3 studies | 306 lesions | Median 7.6 Moderate | 95.1% (92.2% to 97.9%) | 77.8% (68.7% to 86.8%) | 92.2% (88.7% to 95.7%) | 85.1% (77.4% to 92.9%) | Heterogeneous, no summary estimate calculated | 0.07 (0.05 to 0.10)
Heterogeneity tests | | Cumulative meta-analysis, last three studies
[underlined: D] | | New study | Sensitivity 95% CI | Within 5% limits? | Specificity 95% CI | Within 5% limits? | nLHR 95% CI | Within 5% limits?
I^2^ = 0% | | Tofani et al. 1999 ^85^ | 92.2 to 98.3 | Yes | 69.8 to 89.0 | No | 0.04 to 0.09 | No
Q = 1.62
p of Q = 0.445
[underlined: -LHR] | | Imbriaco et al. 2001 ^98^ | 91.5 to 97.7 | Yes | 70.5 to 88.4 | No | 0.05 to 0.10 | No
I^2^ = 0%
Q = 1.61
p of Q = 0.447
[underlined: +LHR] | | Gutfilen et al. 2001 ^101^ | 92.3 to 97.9 | Yes | 68.7 to 86.8 | No | 0.05 to 0.10 | No
I^2^ = 88.2%
Q = 829
p of Q = 0.0000000001
| | | 5% limits 90.3 to 99.4 | Robust | 5% limits 73.9 to 81.7 | Not robust | 5% limits 0.067 to 0.074 | Not robust

Evidence Table 42. Analysis of Studies of Scintimammography: SPECT vs. Planar Imaging

Study | N lesions | Quality score | False negatives on SPECT | False negatives on planar | Odds ratio (95% CI) | p value of difference | Conclusion
Obwegeser et al. 1999 ^90^ | 103 | 7.4 | 17 | 30 | 0.48 (0.25 to 0.94) | 0.0327 | SPECT better
Schillaci et al. 1997 ^92^ | 66 | 8.8 | 3 | 6 | 0.48 (0.11 to 2.0) | 0.309 | No statistically significant difference
Palmedo et al. 1996 ^106,^ ^107^ | 54 | 7.9 | 4 | 3 | 1.36 (0.29 to 6.36) | 0.697 | No statistically significant difference
Palmedo et al. 1997 ^58^ | 20 | 8.3 | 1 | 1 | 1.00 (0.058 to 17.12) | 1.00 | No statistically significant difference
4 studies | 243 lesions | Median 8.1 | | | | | Not qualitatively robust
| | Moderate | | | | | No conclusion

## Studies of MRI

Evidence Table 43. Included Studies of MRI

Study | N patients | Quality score | MRI parameters | Contrast agent | Patients | Mean age (range) | % 65 or older | % Female | Demographics
Bluemke et al. 2004 ^130^ | 1,004 | 7.8 | 1.5T | 0.1 mmol/kg gadolinium chelate | Age 18 to 80 years, referred for breast biopsy due to abnormal mammogram (BIRADS 4 or 5), or a suspicious clinical or sonographic finding. Patients were excluded if pregnant or had a history of breast cancer. | 53.2 (NR) | NR | NR | 76% White
| | | T2 3D fat suppressed | | | | | | 16.6% Black
| | | 3/20/4.5/45^a^ | | | | | | 38.4% Family history
| | | | | | | | | 36.2% Premenopausal
Huang et al. 2004 ^139^ | 50 | 7.1 | 1.5T | 0.1 mmol/kg gadodiamide | Referred for breast biopsy due to a finding of BIRADS 4 or 5 on screening mammography. | NR | NR | NR | NR
| | | T1 3D spoiled gradient-recalled echo
| | | 5/9/3.8/30^a^
Bone et al. 2003 ^461^ | 97 | 8.2 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Patients scheduled for surgery after physical exam, mammography, and fine needle aspiration. | 54 (33 to 81) | NR | NR | NR
| | | T1 3D fast low angle shot
| | | 2.2/12/5/25^a^
| | | Patient prone
Hienisch et al. 2003 ^56^ | 36 | 7.2 | T2 Dynamic 3D FFE sequence, fat suppressed | 0.2 mmol/kg gadopenetate dimeglumine | Women with suspicious breast lesions detected by physical exam, mammography, and/or ultrasound, scheduled for biopsy, referred when there was time on the scanners. Pregnant women were excluded. | 48.4 (25 to 77) | NR | 100% | NR
| | | 2.2/12/6/30^a^
| | | Patient prone
Knopp et al. 2003 ^138^ | 47 | 8.3 | 1.5, 1.0, or 0.5T | 0.1 mmol/kg gadopenetate dimeglumine | At least 18 years old, and had a mammographic examination within the previous 30 days that revealed an abnormality highly suspected of cancer so that the patient was highly likely to undergo either core or excisional biopsy. Pregnant or lactating patients were excluded. | 54.9 (42 to 67) | NR | NR | NR
| | | T1 3D spoiled gradient-recalled echo, no fat suppression
| | | 3/13/NR/10 to 35^a^
| | | Patient prone
Walter et al. 2003 ^57^ | 44 | 7.9 | 1.5 or 1.0T | 0.1 mmol/kg gadolinium-DTPA | Patients referred to the clinic for biopsy of suspicious lesions on the basis of mammography, ultrasound, or physical examination. Referred patients were chosen randomly from 550 possible patients to fill restricted scanner time. | 52 (21 to 77) | NR | NR | NR
| | | T1 3D gradient echo
| | | 4/11/6.9/35^a^
| | | Patient prone
Del Maschio et al. 2002 ^135^ | 215 | 6.5 | 1.5 or 1.0T | 0.1 mmol/kg gadoteridol | Patients with microcalcification foci identified by mammography as BIRADS 3–5, and scheduled for biopsy or surgery. Patients who were pregnant, lactating, or in severe kidney failure were excluded. | NR | NR | NR | NR
| | | 3D gradient echo
| | | NR/NR/NR/NR^a^
Wiberg et al. 2002 ^470^ | 97 | 7.6 | 1.5T | 0.2 mmol/kg gadopentetate dimeglumine | Referred for breast biopsy after evaluation by physical exam, mammography, and fine needle aspiration/cytology. | 54 (33 to 81) | NR | NR | NR
| | | T1 3D fast low angle shot
| | | 2.2/12/5/25^a^
| | | Patient prone
Brix et al. 2001 ^52^ | 14 | 8.3 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Women with suspicious breast lesions detected by physical exam, mammography, and/or ultrasound, scheduled for biopsy, referred when there was time on the scanners. Patients with lesions smaller than 10 mm, elevated blood glucose, younger than 18 years of age, or pregnant were excluded. | 49 (35 to 66) | NR | 100% | NR
| | | 3D fast low angle shot
| | | 4/12/5/35^a^
| | | Patient prone
Cecil et al. 2001 ^134^ | 38 | 7.2 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Patients with either a palpable mass or abnormal mammographic findings. | 49.8 (18 to 85) | NR | NR | NR
| | | T2 3D fast spoiled gradient recalled echo, fat saturated, fat suppressed
| | | 2-3/9.3/2.2/4^a^
Imbriaco et al. 2001 ^98^ | 49 | 7.6 | 0.5T | 0.1 mmol/kg gadopenetate dimeglumine | Patients with a suspicious breast lesion detected either by physical examination or by mammography and ultrasound. Patients younger than 18 years of age, pregnant, lactating, or with a previous history of breast cancer were excluded. | 49 (20 to 72) | 8.1% | NR | NR
| | | 3D gradient echo
| | | Patient prone
Malich et al. 2001 ^137^ | 94 | 7.9 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Patients being evaluated for mammographic abnormalities. | NR | NR | NR | NR
| | | T1 2D fast field echo
| | | 4/97/5/80^a^
| | | Patient prone
Nakahara et al. 2001 ^136^ | 40 | 7.9 | 0.5T | 0.1 mmol/kg gadopenetate dimeglumine | All patients who had significant microcalcifications detected by mammography between October 1994 and July 1998 who were sent for biopsy. | 49.5 (27 to 76) | NR | NR | NR
| | | 3D spoiled gradient-recalled echo, fat saturated
| | | 1.5/60/9/45^a^
| | | Patient prone
Tiling et al. 1997 ^469^ | 82 | 8.3 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Women with indeterminate mammograms and/or physical exams. | 50 (22 to 80) | NR | NR | NR
| | | 3D fast low angle shot
| | | NR/40/14/50^a^
| | | Patient prone
Tiling et al. 1997 ^95^ | 56 | 7.4 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Women with abnormal findings on mammography and/or physical examination who were scheduled for surgery. | 53 (22 to 80) | NR | 100% | 46.4% White
| | | T1 3D fast low angle shot
| | | NR/40/14/50^a^
| | | Patient prone
Heiberg et al. 1996 ^131^ | 56 | 6.4 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Patients scheduled for biopsy for a mammographic or palpable breast mass. First few patients enrolled had a minimal lesion size requirement, but this criterion was dropped later in the study. | NR (25 to 83) | NR | NR | NR
| | | T1 and T2, 3D fast spoiled gradient recalled echo
| | | 3-4/10.6/2.2/20^a^
| | | Patient prone
Obdeijn et al. 1996 ^132^ | 54 | 7.9 | 1.5T | 0.1 mmol/kg gadopenetate dimeglumine | Patients with clinically and/or mammographically suspicious breast lesions, who had been scheduled for surgery. | NR | NR | NR | NR
| | | T1 Gradient echo scan with 2-D FLASH, not fat saturated, fat suppressed
| | | 4/290/5/NR^a^
| | | Patient prone
Palmedo et al. 1996 ^96^ | 56 | 7.9 | 1.5T | 0.2 mmol/kg gadopenetate dimeglumine | Women with a suspicious lesion detected by physical examination or by mammography. Patients with a prior or concurrent history of breast cancer were excluded. | 58 (22 to 81) | NR | 100% | NR
| | | T1 3D gradient echo
| | | 5/NR/NR/NR^a^
| | | Patient prone
Hachiya et al. 1991 ^133^ | 52 | 7.5 | 0.5T | 0.1 mmol/kg gadolinium-DTPA | Patients with clinically palpable lesions. | NR (35 to 79) | NR | 98.10% | NR
| | | T1 Gradient echo
| | | NR/50/14/50^a^
| | | Patient prone

a. slice thickness mm/time to repetition ms/time to echo ms/flip angle degrees

NR = not reported

Evidence Table 44. Quality Assessment of Studies of MRI

Question | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16 | 17 | 18 | score
Study | consecutive | consistent | prospective | case control | funding | valid reference | gold standard | interreader | blinding | blinding | blinding | blinding | full testing | threshold | intervening | attrition | conclusions | discrepancy | standardized
Bluemke et al. 2004 ^130^ | r | y | y | y | y | y | y | n | y | r | r | r | y | y | y | y | y | y | 7.8
Huang et al. 2004 ^139^ | r | y | y | y | r | y | y | r | y | r | r | r | y | r | y | y | y | y | 7.1
Bone et al. 2003 ^461^ | y | y | y | y | r | y | y | n | y | r | y | r | y | y | y | y | y | y | 8.2
Hienisch et al. 2003 ^56^ | r | y | y | y | r | y | y | n | y | r | n | r | y | y | y | y | y | y | 7.2
Knopp et al. 2003 ^138^ | y | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 8.3
Walter et al. 2003 ^57^ | y | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.9
Del Maschio et al. 2002 ^135^ | r | y | y | y | r | y | y | r | y | r | r | r | y | r | y | n | y | y | 6.5
Wiberg et al. 2002 ^470^ | y | y | y | y | r | y | y | n | y | r | n | r | y | y | y | y | y | y | 7.6
Brix et al. 2001 ^52^ | y | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 8.3
Cecil et al. 2001 ^134^ | r | n | y | y | y | y | y | r | y | r | n | r | y | y | y | y | y | y | 7.2
Imbriaco et al. 2001 ^98^ | y | y | y | y | r | y | y | n | y | r | n | r | y | y | y | y | y | y | 7.6
Malich et al. 2001 ^137^ | y | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.9
Nakahara et al. 2001 ^136^ | y | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.9
Tiling et al. 1997 ^95^ | r | y | y | y | r | y | y | y | y | r | y | r | y | y | y | y | y | y | 8.3
Tiling et al. 1997 ^469^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | n | y | y | 7.4
Heiberg et al. 1996 ^131^ | r | n | y | y | n | y | y | r | y | r | r | r | y | r | y | y | y | y | 6.4
Obdeijn et al. 1996 ^132^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Palmedo et al. 1996 ^96^ | r | y | y | y | r | y | y | r | y | r | y | r | y | y | y | y | y | y | 7.9
Hachiya et al. 1991 ^133^ | r | y | y | y | r | y | y | y | y | r | r | r | y | r | y | y | y | y | 7.5

y = yes

n = no

r = not reported

Evidence Table 45. Diagnostic Test Characteristics of MRI

Study | N lesions | Patient subgroup | Prevalence | True positive | False negative | False positive | True negative | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Bluemke et al. 2004 ^130^ | 821 | All | 49.3 | 356.27 | 48.12 | 135.81 | 280.79 | 88.1% (84.6% to 91.1%) | 67.4% (62.7% to 71.9%) | 72.4% (68.2% to 76.3%) | 85.4% (81.1% to 89.0%) | 2.70 (2.61 to 2.80) | 0.18 (0.13 to 0.23)
| 346 | Premenopausal | 41.7 | 123.07 | 21.04 | 68.04 | 133.85 | 85.4% (78.6% to 90.7%) | 66.3% (59.4% to 71.2%) | 64.4% (57.2% to 71.2%) | 86.5% (80.0% to 91.4%) | 2.53 (2.37 to 2.71) | 0.22 (0.15 to 0.33)
| 474 | Post menopausal | 54.9 | 233.01 | 27.05 | 68.04 | 145.91 | 89.6% (85.3% to 93.0%) | 68.2% (61.5% to 74.4%) | 77.4% (72.3% to 82.0%) | 84.4% (78.1% to 89.5%) | 2.82 (2.70 to 2.94) | 0.15 (0.11 to 0.22)
| 345 | Palpable lesions | 61.7 | 194.03 | 18.96 | 50.96 | 81.06 | 91.1% (86.4% to 94.5%) | 61.4% (52.5% to 69.7%) | 79.2% (73.6% to 84.1%) | 81.0% (71.9% to 88.2%) | 2.36 (2.26 to 2.46) | 0.14 (0.09 to 0.23)
| 474 | Non-palpable lesions | 40.3 | 161.93 | 29.02 | 84.91 | 198.13 | 84.8% (78.9% to 89.6%) | 70.0% (64.3% to 75.2%) | 65.6% (59.3% to 71.5%) | 87.2% (82.2% to 91.3%) | 2.83 (2.66 to 3.00) | 0.22 (0.15 to 0.31)
| 300 | Micro-calcifications | 42.3 | 106.01 | 20.95 | 42.05 | 130.99 | 83.5% (75.8% to 89.5%) | 75.7% (68.6% to 81.9%) | 71.6% (63.6% to 78.7%) | 86.2% (79.7% to 91.2%) | 3.44 (3.18 to 3.71) | 0.22 (0.15 to 0.33)
| 470 | No micro-calcifications | 54.6 | 231.85 | 24.9 | 84.02 | 129.23 | 90.3% (86.0% to 93.6%) | 60.6% (53.7% to 67.2%) | 73.4% (68.2% to 78.2%) | 83.8% (77.0% to 89.2%) | 2.29 (2.20 to 2.39) | 0.16 (0.11 to 0.24)
| 170 | First degree relatives with history of breast cancer | 55.3 | 81.09 | 12.98 | 23.01 | 52.92 | 86.2% (77.5% to 92.4%) | 69.7% (58.1% to 79.8%) | 77.9% (68.7% to 85.4%) | 80.3% (68.7% to 89.1%) | 2.84 (2.62 to 3.08) | 0.20 (0.12 to 0.34)
| 145 | Other relatives with history of breast cancer | 45.7 | 59.7 | 6.63 | 31.86 | 46.81 | 90.9% (81.3% to 96.6%) | 59.5% (47.9% to 70.4%) | 65.2% (54.6% to 74.9%) | 88.7% (77.0% to 95.7%) | 2.22 (2.05 to 2.41) | 0.17 (0.08 to 0.35)
| 496 | No relatives with history of breast cancer | 48.9 | 214.77 | 27.91 | 79.03 | 174.28 | 88.5% (83.8% to 92.2%) | 68.8% (62.7% to 74.4%) | 73.1% (67.7% to 78.1%) | 86.1% (80.6% to 90.6%) | 2.84 (2.71 to 2.97) | 0.17 (0.12 to 0.24)
| 79 | Dense breast tissue | 46.8 | 32.01 | 5 | 17.01 | 24.99 | 86.5% (71.2% to 95.5%) | 59.5% (43.3% to 74.4%) | 65.3% (50.4% to 78.3%) | 83.3% (65.3% to 94.4%) | 2.14 (1.88 to 2.43) | 0.23 (0.10 to 0.53)
| 106 | Mostly fatty breast tissue | 50.9 | 48.98 | 5.02 | 25.01 | 26.99 | 90.7% (79.7% to 96.9%) | 51.9% (37.6% to 66.0%) | 66.2% (54.3% to 76.6%) | 84.4% (67.2% to 94.7%) | 1.89 (1.73 to 2.05) | 0.18 (0.07 to 0.43)
Huang et al. 2004 ^139^ | 50 | BIRADS 4 or 5 | 36.0 | 18 | 0 | 12 | 20 | 100.0% (82.0% to 99.8%) | 62.5% (45.2% to 77.0%) | 60.0% (42.3% to 75.3%) | 100.0% (83.5% to 99.8%) | 2.57 (2.39 to 2.77) | 0.04 (0.00 to 0.66)
Bone et al. 2003 ^461^ | 111 | Positive on FNA | 71.2 | 74 | 5 | 17 | 15 | 93.7% (85.9% to 97.2%) | 46.9% (30.9% to 63.5%) | 81.3% (72.1% to 87.9%) | 75.0% (53.0% to 88.6%) | 1.76 (1.66 to 1.87) | 0.14 (0.05 to 0.34)
| 40 | Lesions ≤10 mm, positive on FNA | 50.0 | 15 | 5 | 11 | 9 | 75.0% (53.0% to 88.6%) | 45.0% (25.9% to 65.8%) | 57.7% (39.0% to 74.4%) | 64.3% (38.8% to 83.5%) | 1.36 (1.06 to 1.76) | 0.56 (0.23 to 1.37)
| 71 | Lesions >10 mm, positive by FNA | 83.1 | 59 | 0 | 6 | 6 | 100.0% (93.7% to 99.9%) | 50.0% (25.5% to 74.5%) | 90.8% (81.2% to 95.6%) | 100.0% (60.4% to 99.6%) | 1.98 (1.94 to 2.03) | 0.02 (0.00 to 0.28)
Hienisch et al. 2003 ^56^ | 40 | All | 62.5 | 23 | 2 | 4 | 11 | 92.0% (74.8% to 97.6%) | 73.3% (48.0% to 88.9%) | 85.2% (67.4% to 93.9%) | 84.6% (57.6% to 95.4%) | 3.45 (3.07 to 3.87) | 0.11 (0.03 to 0.43)
Knopp et al. 2003 ^138^ | 61 | BIRADS 4–5 | 78.7 | 34 | 14 | 3 | 10 | 70.8% (56.8% to 81.7%) | 76.9% (49.6% to 91.6%) | 91.9% (78.5% to 97.1%) | 41.7% (24.6% to 61.2%) | 3.07 (2.56 to 3.68) | 0.38 (0.22 to 0.65)
Walter et al. 2003 ^57^ | 42 | All | 45.2 | 17 | 2 | 6 | 17 | 89.5% (68.4% to 96.8%) | 73.9% (53.4% to 87.3%) | 73.9% (53.4% to 87.3%) | 89.5% (68.4% to 96.8%) | 3.43 (2.94 to 4.00) | 0.14 (0.04 to 0.54)
Del Maschio et al. 2002 ^135^ | 134 | Micro- calcifications | 66.0 | 77 | 10 | 16 | 32 | 88.5% (80.1% to 93.6%) | 66.7% (52.5% to 78.3%) | 82.8% (73.8% to 89.1%) | 76.2% (61.4% to 86.4%) | 2.66 (2.46 to 2.86) | 0.17 (0.09 to 0.32)
Wiberg et al. 2002 ^470^ | 114 | Positive by FNA | 71.9 | 77 | 5 | 17 | 15 | 93.9% (86.4% to 97.3%) | 46.9% (30.9% to 63.5%) | 81.9% (72.9% to 88.3%) | 75.0% (53.0% to 88.6%) | 1.77 (1.67 to 1.87) | 0.13 (0.05 to 0.33)
| 32 | Postiive by FNA, dense breast tissue | 56.3 | 17 | 1 | 9 | 5 | 94.4% (73.9% to 98.8%) | 35.7% (16.5% to 61.2%) | 65.4% (46.2% to 80.5%) | 83.3% (43.5% to 96.5%) | 1.47 (1.31 to 1.64) | 0.16 (0.02 to 1.18)
Brix et al. 2001 ^52^ | 13 | Lesions >10 mm | 69.2 | 8 | 1 | 2 | 2 | 88.9% (56.2% to 97.6%) | 50.0% (15.4% to 84.6%) | 80.0% (48.9% to 94.0%) | 66.7% (21.0% to 93.3%) | 1.78 (1.41 to 2.24) | 0.22 (0.03 to 1.80)
Cecil et al. 2001 ^134^ | 38 | All | 60.5 | 21 | 2 | 3 | 12 | 91.3% (73.0% to 97.4%) | 80.0% (54.7% to 92.7%) | 87.5% (68.8% to 95.5%) | 85.7% (59.8% to 95.7%) | 4.57 (4.02 to 5.18) | 0.11 (0.03 to 0.42)
| 32 | Younger than age 65 | 59.4 | 19 | 0 | 3 | 10 | 100.0% (82.8% to 99.8%) | 76.9% (49.6% to 91.6%) | 86.4% (66.5% to 95.1%) | 100.0% (71.7% to 99.7%) | 3.90 (3.64 to 4.18) | 0.03 (0.00 to 0.52)
Imbriaco et al. 2001 ^98^ | 49 | All | 51.0 | 24 | 1 | 6 | 18 | 96.0% (80.2% to 99.1%) | 75.0% (55.0% to 87.8%) | 80.0% (62.6% to 90.4%) | 94.7% (75.1% to 98.8%) | 3.84 (3.54 to 4.16) | 0.05 (0.01 to 0.37)
| 45 | Younger than age 65 | 53.3 | 23 | 1 | 6 | 15 | 95.8% (79.5% to 99.1%) | 71.4% (50.0% to 86.0%) | 79.3% (61.5% to 90.0%) | 93.8% (71.4% to 98.6%) | 3.35 (3.09 to 3.65) | 0.06 (0.01 to 0.40)
| 23 | Lesions ≤10 mm | 39.1 | 9 | 0 | 3 | 11 | 100.0% (69.5% to 99.7%) | 78.6% (52.3% to 92.2%) | 75.0% (46.7% to 90.8%) | 100.0% (73.6% to 99.7%) | 4.07 (3.53 to 4.69) | 0.07 (0.00 to 0.99)
| 26 | Lesions >10 mm | 61.5 | 15 | 1 | 3 | 7 | 93.8% (71.4% to 98.6%) | 70.0% (39.6% to 88.9%) | 83.3% (60.6% to 93.9%) | 87.5% (52.6% to 97.4%) | 3.13 (2.75 to 3.55) | 0.09 (0.01 to 0.62)
Malich et al. 2001 ^137^ | 90 | BIRADS 4–5 | 50.0 | 53 | 1 | 7 | 29 | 98.1% (90.1% to 99.6%) | 80.6% (64.9% to 90.1%) | 88.3% (77.7% to 94.1%) | 96.7% (83.1% to 99.3%) | 5.05 (4.87 to 5.24) | 0.02 (0.00 to 0.16)
Nakahara et al. 2001 ^136^ | 40 | Micro- calcifications | 60.0 | 18 | 2 | 1 | 19 | 90.0% (69.7% to 97.0%) | 95.0% (76.1% to 98.9%) | 94.7% (75.1% to 98.8%) | 90.5% (70.9% to 97.1%) | 18.00 (15.55 to 20.83) | 0.11 (0.03 to 0.39)
Tiling et al. 1997 ^469^ | 68 | Indeterminate mammogram or physical exam | 36.8 | 14 | 11 | 9 | 34 | 56.0% (37.1% to 73.3%) | 79.1% (64.7% to 88.5%) | 60.9% (40.8% to 77.7%) | 75.6% (61.3% to 85.7%) | 2.68 (1.89 to 3.79) | 0.56 (0.35 to 0.89)
Tiling et al. 1997 ^95^ | 56 | All | 58.9 | 30 | 3 | 11 | 12 | 90.9% (76.3% to 96.7%) | 52.2% (33.0% to 70.7%) | 73.2% (58.0% to 84.2%) | 80.0% (54.7% to 92.7%) | 1.90 (1.71 to 2.12) | 0.17 (0.06 to 0.55)
Heiberg et al. 1996 ^131^ | 81 | All | 25.9 | 21 | 0 | 16 | 44 | 100.0% (84.2% to 99.8%) | 73.3% (60.9% to 82.8%) | 56.8% (40.9% to 71.3%) | 100.0% (91.8% to 99.9%) | 3.61 (3.39 to 3.85) | 0.03 (0.00 to 0.48)
Obdeijn et al. 1996 ^132^ | 54 | All | 61.1 | 30 | 3 | 7 | 14 | 90.9% (76.3% to 96.7%) | 66.7% (45.3% to 82.7%) | 81.1% (65.7% to 90.4%) | 82.4% (58.8% to 93.6%) | 2.73 (2.45 to 3.04) | 0.14 (0.04 to 0.42)
Palmedo et al. 1996 ^96^ | 56 | All | 48.2 | 25 | 2 | 23 | 6 | 92.6% (76.4% to 97.8%) | 20.7% (10.0% to 38.5%) | 52.1% (38.3% to 65.5%) | 75.0% (40.8% to 92.5%) | 1.17 (1.05 to 1.30) | 0.36 (0.08 to 1.62)
| 43 | Palpable lesions | 51.2 | 20 | 2 | 18 | 3 | 90.9% (72.0% to 97.3%) | 14.3% (5.2% to 34.8%) | 52.6% (37.3% to 67.5%) | 60.0% (23.3% to 87.9%) | 1.06 (0.93 to 1.21) | 0.64 (0.12 to 3.44)
| 13 | Non-palpable lesions | 38.5 | 5 | 0 | 4 | 4 | 100.0% (56.0% to 99.6%) | 50.0% (21.7% to 78.3%) | 55.6% (26.8% to 80.9%) | 100.0% (50.5% to 99.5%) | 1.83 (1.44 to 2.33) | 0.17 (0.01 to 2.56)
Hachiya et al. 1991 ^133^ | 52 | All | 73.1 | 36 | 2 | 0 | 14 | 94.7% (82.5% to 98.4%) | 100.0% (78.0% to 99.8%) | 100.0% (90.1% to 99.9%) | 87.5% (63.7% to 96.3%) | 28.08 (25.86 to 30.48) | 0.07 (0.02 to 0.22)

FNA = fine needle aspiration

Evidence Table 46. Meta-analysis of Studies of MRI for Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Bluemke et al. 2004 ^130^ | 821 | 7.8 | 88.1% (84.6% to 91.1%) | 67.4% (62.7% to 71.9%) | 72.4% (68.2% to 76.3%) | 85.4% (81.1% to 89.0%) | 2.70 (2.61 to 2.80) | 0.18 (0.13 to 0.23)
Heiberg et al. 1996 ^131^ | 81 | 6.4 | 100.0% (84.2% to 99.8%) | 73.3% (60.9% to 82.8%) | 56.8% (40.9% to 71.3%) | 100.0% (91.8% to 99.9%) | 3.61 (3.39 to 3.85) | 0.03 (0.00 to 0.48)
Tiling et al. 1997 ^95^ | 56 | 7.4 | 90.9% (76.3% to 96.7%) | 52.2% (33.0% to 70.7%) | 73.2% (58.0% to 84.2%) | 80.0% (54.7% to 92.7%) | 1.90 (1.71 to 2.12) | 0.17 (0.06 to 0.55)
Palmedo et al. 1996 ^96^ | 56 | 7.9 | 92.6% (76.4% to 97.8%) | 20.7% (10.0% to 38.5%) | 52.1% (38.3% to 65.5%) | 75.0% (40.8% to 92.5%) | 1.17 (1.05 to 1.30) | 0.36 (0.08 to 1.62)
Obdejin et al. 1996 ^132^ | 54 | 7.9 | 90.9% (76.3% to 96.7%) | 66.7% (45.3% to 82.7%) | 81.1% (65.7% to 90.4%) | 82.4% (58.8% to 93.6%) | 2.73 (2.45 to 3.04) | 0.14 (0.04 to 0.42)
Hachiya et al. 1991 ^133^ | 52 | 7.5 | 94.7% (82.5% to 98.4%) | 100.0% (78.0% to 99.8%) | 100.0% (90.1% to 99.9%) | 87.5% (63.7% to 96.3%) | 28.08 (25.86 to 30.48) | 0.07 (0.02 to 0.22)
Imbracio et al. 2001 ^98^ | 49 | 7.6 | 96.0% (80.2% to 99.1%) | 75.0% (55.0% to 87.8%) | 80.0% (62.6% to 90.4%) | 94.7% (75.1% to 98.8%) | 3.84 (3.54 to 4.16) | 0.05 (0.01 to 0.37)
Walter et al. 2003 ^57^ | 42 | 7.9 | 89.5% (68.4% to 96.8%) | 73.9% (53.4% to 87.3%) | 73.9% (53.4% to 87.3%) | 89.5% (68.4% to 96.8%) | 3.43 (2.94 to 4.00) | 0.14 (0.04 to 0.54)
Hienisch et al. 2003 ^56^ | 40 | 7.2 | 92.0% (74.8% to 97.6%) | 73.3% (48.0% to 88.9%) | 85.2% (67.4% to 93.9%) | 84.6% (57.6% to 95.4%) | 3.45 (3.07 to 3.87) | 0.11 (0.03 to 0.43)
Cecil et al. 2001 ^134^ | 38 | 7.2 | 91.3% (73.0% to 97.4%) | 80.0% (54.7% to 92.7%) | 87.5% (68.8% to 95.5%) | 85.7% (59.8% to 95.7%) | 4.57 (4.02 to 5.18) | 0.11 (0.03 to 0.42)
10 studies | 1,289 lesions | Median 7.6 Moderate | At mean threshold 92.5% | At mean threshold 72.4% At 95% sensitivity 62.8% | At mean threshold 77.2% At 95% sensitivity 72.1% | At mean threshold 90.5% At 95% sensitivity 92.5% | Heterogeneous, no summary estimate calculated | 0.16 (0.13 to 0.19)
Heterogeneity tests | | Cumulative meta-analysis (last three studies)
[underlined: D] | | New study | D 95% CI | Within 5% limits? | -LHR 95% CI | Within 5% limits?
I^2^ = 34%
Q = 13.56
p of Q = 0.13877 | | Walter et al. 2003 ^57^ | 2.84 to 2.88 | Yes | 0.14 to 0.20 | No
[underlined: +lnLHR] | | Hienisch et al. 2003 ^56^ | 2.86 to 2.90 | Yes | 0.14 to 0.19 | No
I^2^ = 97.0%
p of Q = 0.00000001
[underlined: -lnLHR] | | Cecil et al. 2001 ^134^ | 2.88 to 2.92 | Yes | 0.13 to 0.19 | No
I^2^ = 0%
Q = 7.0
p of Q = 0.63717
| | | 5% limits 2.76 to 3.04 | Stable | 5% limits 15 to 0.17 | Not stable

D = ln of diagnostic odds ratio

Evidence Table 47. Meta-analysis of Studies of MRI for Lesions with Microcalcifications

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Bluemke et al. 2004 ^130^ | 300 | 7.8 | 83.5% (75.8% to 89.5%) | 75.7% (68.6% to 81.9%) | 71.6% (63.6% to 78.7%) | 86.2% (79.7% to 91.2%) | 3.44 (3.18 to 3.71) | 0.22 (0.15 to 0.33)
Del Maschio et al. 2002 ^135^ | 134 | 6.5 | 88.5% (80.1% to 93.6%) | 66.7% (52.5% to 78.3%) | 82.8% (73.8% to 89.1%) | 76.2% (61.4% to 86.4%) | 2.66 (2.46 to 2.86) | 0.17 (0.09 to 0.32)
Nakahara et al. 2001 ^136^ | 40 | 7.9 | 90.0% (69.7% to 97.0%) | 95.0% (76.1% to 98.9%) | 94.7% (75.1% to 98.8%) | 90.5% (70.9% to 97.1%) | 18.00 (15.55 to 20.83) | 0.11 (0.03 to 0.39)
3 studies | 474 lesions | median 7.8 Moderate | Summary estimate 85.9% (81.5% to 90.4%) | Summary estimate 75.5% (70.1% to 80.9%) | Summary estimate 77.3% (71.9% to 82.7%) | Summary estimate 84.7% (80.1% to 89.2%) | Heterogeneous, no summary estimate calculated | Summary estimate 0.20 (0.15 to 0.25)
Heterogeneity tests | | Cumulative meta-analysis
[underlined: D] | | New study | Sensitivity 95% CI | Within 5% limits? | Specificity 95% CI | Within 5% limits? | -LHR 95%CI | Within 5% limits?
I^2^ = 28% | | Bluemke et al. 2004 ^130^ | 77.0 to 90.0 | No | 69.3 to 82.1 | No | 0.16 to 0.33 | No
Q = 2.79
p of Q = 0.24747
[underlined: +lnLHR] | | Del Maschio et al. 2002 ^135^ | 80.8 to 90.2 | No | 67.9 to 79.5 | No | 0.16 to 0.27 | No
I^2^ = 81.43%
Q = 527.6
p of Q = 0.00000001
[underlined: -lnLHR] | | Nakahara et al. 2001 ^136^ | 81.5 to 90.4 | No | 70.1 to 80.9 | No | 0.15 to 0.25 | No
I^2^ = 0.0%
Q = 1.29
p of Q = 0.524526
| | | 5% limits 81.6 to 90.2 | Not stable | 5% limits 71.7 to 79.3 | Not stable | 5% limits 0.19 to 0.21 | Not stable

D = ln diagnostic odds ratio

+lnLHR = ln of positive likelihood ratio

-lnLHR = ln of negative likelihood ratio

Evidence Table 48. Meta-analysis of Studies of MRI for Lesions of BIRADS 4 or 5

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Malich et al. 2001 ^137^ | 90 | 7.9 | 98.1% (90.1% to 99.6%) | 80.6% (64.9% to 90.1%) | 88.3% (77.7% to 94.1%) | 96.7% (83.1% to 99.3%) | 5.05 (4.87 to 5.24) | 0.02 (0.00 to 0.16)
Knopp et al. 2003 ^138^ | 61 | 8.3 | 70.8% (56.8% to 81.7%) | 76.9% (49.6% to 91.6%) | 91.9% (78.5% to 97.1%) | 41.7% (24.6% to 61.2%) | 3.07 (2.56 to 3.68) | 0.38 (0.22 to 0.65)
Huange et al. 2004 ^139^ | 50 | 7.1 | 100.0% (82.0% to 99.8%) | 62.5% (45.2% to 77.0%) | 60.0% (42.3% to 75.3%) | 100.0% (83.5% to 99.8%) | 2.57 (2.39 to 2.77) | 0.04 (0.00 to 0.66)
3 studies | 201 lesions | Median 7.9 Moderate | Heterogeneous, no summary estimates calculated.
Heterogeneity tests | | | [underlined: D] | | | | [underlined: +lnLHR] | [underlined: -lnLHR]
| | | I^2^ = 70% | | | | I^2^ = 63.97% | I^2^ = 78.6%
| | | Q = 7.12 | | | | Q = 271.98 | Q = 9.36
| | | p of Q = 0.02843 | | | | p of Q = 0.00000001 | p of Q = 0.00927

D = ln diagnostic odds ratio

-lnLHR = ln of negative likelihood ratio

+lnLHR = ln of positive likelihood ratio

## Studies of Ultrasound

Evidence Table 49. Included Studies of Ultrasound

Study | N patients | Quality score | US parameters | Patients | Age | % 65 or older | % Female
Chen et al. 2004 ^191^ | 1,203 | 6.9 | Aloka SSD-2000 or SSD-5500, 7.5 or 10 MHz linear array | Women with palpable breast lesions | Range 14 to 83 | Not reported | 100%
Meyberg-Solomayer et al. 2004 ^189^ | 65 | 7.4 | HDI 3000 or Voluson 730, 5 to 12 MHz or 5 to 10 MHz linear array | Women with breast lesions | Mean 54 Range 16 to 96 | Not reported | 100%
Malich et al. 2001 ^137^ | 94 | 7.9 | HDI 5000, 7.5 to 10 MHz | Patients being evaluated for mammographic abnormalities | Not reported | Not reported | Not reported
Chao et al. 1999 ^190^ | 3,050 | 7.5 | Aloka SSD-2000 or SSD-5500, 7.5 MHz linear array | Patients with solid breast lesions | Mean 38.7 Range 14 to 86 | Not reported | Not reported
Perre et al. 1994 ^192^ | 380 | 7.4 | Toshiba SSA-270-A or Technicare Autosector IV, 7.5 MHz linear array | Women with palpable breast lesions | Median 49.3 Range 13.7 to 98.8 | Not reported | 100%
McNicholas et al. 1993 ^194^ | 203 | 7.8 | Acuson 128, 7 MHz | Women with palpable breast lesions | Mean 42 Range 17 to 82 | Not reported | 100%
Hachiya et al. 1991 ^133^ | 52 | 7.1 | Hitachi EUB, 7.5 MHz | Patients with palpable lesions | Range 35 to 79 | Not reported | 98.10%
van Oord et al. 1991 ^193^ | 305 | 7.2 | Diasonic DR F 400, 10 MHz | Women with palpable breast lesions | Mean 48 Range 18 to 88 | Not reported | 100%

Evidence Table 50. Quality Assessment of Studies of Ultrasound

Question | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16 | 17 | 18 | score
Study | consecutive | consistent | prospective | Case control | funding | valid reference | gold standard | interreader | blinding | blinding | blinding | blinding | full testing | threshold | intervening | attrition | conclusions | discrepancy | standardized
Chen et al. 2004 ^191^ | r | y | y | y | r | y | y | n | y | r | r | r | y | r | y | y | y | y | 6.9
Meyberg-Solomayer et al. 2004 ^189^ | r | y | y | y | r | y | y | n | y | r | r | r | y | y | y | y | y | y | 7.4
Malich et al. 2001 ^137^ | y | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.9
Chao et al. 1999 ^190^ | r | y | y | y | r | y | y | r | y | r | r | r | y | y | y | y | y | y | 7.5
Perre et al. 1994 ^192^ | r | y | y | y | r | y | y | n | y | r | r | r | y | y | y | y | y | y | 7.4
McNicholas et al. 1993 ^194^ | y | y | y | y | r | y | y | n | y | r | r | r | y | y | y | y | y | y | 7.8
Hachiya et al. 1991 ^133^ | r | y | y | y | r | y | y | y | r | r | r | r | y | r | y | y | y | y | 7.1
van Oord et al. 1991 ^193^ | r | y | y | y | r | y | y | n | y | r | y | r | y | y | y | n | y | y | 7.2

y = yes

n = no

r = not reported

Evidence Table 51. Diagnostic Test Characteristics of Ultrasound

Study | N lesions | Patient subgroup | Prevalence | True positive | False negative | False positive | True negative | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Chen et al. 2004 ^191^ | 1,203 | Palpable lesions | 32.5% | 310 | 81 | 87 | 725 | 79.3% (75.0% to 83.0%) | 89.3% (87.0% to 91.2%) | 78.1% (73.8% to 81.9%) | 90% (87.7% to 91.8%) | 7.4 (7.1 to 7.8) | 0.23 (0.19 to 0.28)
| 135 | Palpable lesion 1 cm or smaller | 28.9% | 17 | 22 | 11 | 85 | 43.6% (29.4% to 59.0%) | 88.5% (80.5% to 93.4%) | 60.7% (42.4% to 76.3%) | 79.4% (70.7% to 85.9%) | 3.8 (2.7 to 5.4) | 0.64 (0.48 to 0.85)
| 567 | Palpable lesion 1.1 to 2 cm | 27.5% | 114 | 42 | 35 | 376 | 73.1% (65.6% to 79.4%) | 91.5% (88.4% to 93.8%) | 76.5% (69.0% to 82.6%) | 90% (86.7% to 92.5%) | 8.6 (7.8 to 9.5) | 0.29 (0.23 to 0.38)
| 501 | Palpable lesion larger than 2 cm | 39.1% | 179 | 17 | 41 | 264 | 91.3% (86.5% to 94.5%) | 86.6% (82.3% to 90.0%) | 81.4% (75.7% to 86.0%) | 94% (90.5% to 96.2%) | 6.8 (6.5 to 7.1) | 0.10 (0.06 to 0.16)
Meyberg-Solomayer et al. 2004 ^189^ | 65 | All | 64.6% | 42 | 0 | 10 | 13 | 100.0% (91.4% to 99.9%) | 56.5% (36.8% to 74.3%) | 80.8% (68.0% to 89.1%) | 100.0% (76.7% to 99.8%) | 2.3 (2.2 to 2.3) | 0.02 (0.00 to 0.33)
Malich et al. 2001 ^137^ | 100 | All | 62.0% | 48 | 14 | 4 | 34 | 77.4% (65.5% to 86.0%) | 89.5% (75.7% to 95.7%) | 92.3% (81.7% to 96.9%) | 70.8% (56.8% to 81.7%) | 7.4 (6.4 to 8.4) | 0.25 (0.16 to 0.41)
Chao et al. 1999 ^190^ | 3,093 | All | 23.7% | 631 | 102 | 800 | 1560 | 86.1% (83.4% to 88.4%) | 66.1% (64.2% to 68.0%) | 44.1% (41.5% to 46.7%) | 93.9% (92.6% to 94.9%) | 2.5 (2.5 to 2.6) | 0.21 (0.18 to 0.25)
Perre et al. 1994 ^192^ | 400 | Palpable lesions | 43.5% | 170 | 4 | 15 | 211 | 97.7% (94.2% to 99.1%) | 93.4% (89.3% to 95.9%) | 91.9% (87.0% to 95.0%) | 98.1% (95.3% to 99.2%) | 14.7 (14.4 to 15.1) | 0.02 (0.01 to 0.06)
McNicholas et al. 1993 ^194^ | 203 | Palpable lesions | 26.6% | 48 | 6 | 19 | 130 | 88.9% (77.7% to 94.7%) | 87.2% (80.9% to 91.6%) | 71.6% (59.9% to 81.0%) | 95.6% (90.7% to 97.9%) | 7.0 (6.3 to 7.7) | 0.13 (0.06 to 0.27)
Hachiya et al. 1991 ^133^ | 52 | Palpable lesions | 73.1% | 37 | 1 | 0 | 14 | 97.4% (86.3% to 99.4%) | 100.0% (78.0% to 99.8%) | 100.0% (90.3% to 99.9%) | 93.3% (69.9% to 98.6%) | 28.9 (27.1 to 30.7) | 0.04 (0.01 to 0.19)
van Oord et al. 1991 ^193^ | 232 | Palpable lesions | 32.8% | 75 | 1 | 51 | 105 | 98.7% (92.8% to 99.7%) | 67.3% (59.6% to 74.2%) | 59.5% (50.8% to 67.7%) | 99.1% (94.8% to 99.8%) | 3.0 (2.9 to 3.1) | 0.02 (0.00 to 0.14)

Evidence Table 52. Meta-analysis of Studies of Ultrasound for Suspicious Breast Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Meyberg-Solomayer et al. 2004 ^189^ | 65 | 7.4 | 100.0% (91.4% to 99.9%) | 56.5% (36.8% to 74.3%) | 80.8% (68.0% to 89.1%) | 100.0% (76.7% to 99.8%) | 2.3 (2.2 to 2.3) | 0.02 (0.00 to 0.33)
Malich et al. 2001 ^137^ | 100 | 7.9 | 77.4% (65.5% to 86.0%) | 89.5% (75.7% to 95.7%) | 92.3% (81.7% to 96.9%) | 70.8% (56.8% to 81.7%) | 7.4 (6.4 to 8.4) | 0.25 (0.16 to 0.41)
Chao et al. 1999 ^190^ | 3,093 | 7.5 | 86.1% (83.4% to 88.4%) | 66.1% (64.2% to 68.0%) | 44.1% (41.5% to 46.7%) | 93.9% (92.6% to 94.9%) | 2.5 (2.5 to 2.6) | 0.21 (0.18 to 0.25)
3 studies | 3,258 lesions | Median 7.6 Moderate | Summary estimate 86.1% (83.8% to 88.5%) | Summary estimate 66.4% (64.5% to 68.2%) | Summary estimate 47.0% (43.6% to 50.4%) | Summary estimate 93.3% (92.3% to 94.2%) | Heterogeneous, no summary estimate calculated | Summary estimate 0.21 (0.24 to 0.19)
Heterogeneity tests | | Cumulative meta-analysis
[underlined: D] | | New study | Sensitivity 95% CI | Within 5% limits? | Specificity 95% CI | Within 5% limits? | -LHR 95% CI | Within 5% limits?
I^2^ = 47% | | Chao et al. 1999 ^190^ | 83.6 to 88.6 | Yes | 64.2 to 68.0 | Yes | 0.18 to 0.24 | No
Q = 3.78
p of Q = 0.15109
[underlined: +lnLHR] | | Malich et al. 2001 ^137^ | 83.0 to 87.9 | Yes | 64.6 to 68.4 | Yes | 0.19 to 0.25 | No
I^2^ = 65.7%
Q = 285.56
p of Q = 0.00000001
[underlined: -lnLHR] | | Meyberg-Solomayer et al. 2004 ^189^ | 83.8 to 88.5 | Yes | 64.5 to 68.3 | Yes | 0.19 to 0.24 | No
I^2^ = 37.8%
Q = 3.22
p of Q = 0.200
| | | 5% limits 81.8 to 90.4 | Stable | 5% limits 63.1 to 69.7 | Stable | 5% limits 0.20 to 0.23 | Not stable

D = ln diagnostic odds ratio

+lnLHR = ln of positive likelihood ratio

-lnLHR = ln of negative likelihood ratio

Evidence Table 53. Meta-analysis of Studies of Ultrasound for Palpable Lesions

Study | N lesions | Quality score | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
Chen et al. 2004 ^191^ | 1,203 | 6.9 | 79.3% (75.0% to 83.0%) | 89.3% (87.0% to 91.2%) | 78.1% (73.8% to 81.9%) | 90% (87.7% to 91.8%) | 7.4 (7.1 to 7.8) | 0.23 (0.19 to 0.28)
Perre et al. 1994 ^192^ | 400 | 7.4 | 97.7% (94.2% to 99.1%) | 93.4% (89.3% to 95.9%) | 91.9% (87.0% to 95.0%) | 98.1% (95.3% to 99.2%) | 14.7 (14.4 to 15.1) | 0.02 (0.01 to 0.06)
van Oord et al. 1991 ^193^ | 232 | 7.2 | 98.7% (92.8% to 99.7%) | 67.3% (59.6% to 74.2%) | 59.5% (50.8% to 67.7%) | 99.1% (94.8% to 99.8%) | 3.0 (2.9 to 3.1) | 0.02 (0.00 to 0.14)
McNicholas et al. 1993 ^194^ | 203 | 7.8 | 88.9% (77.7% to 94.7%) | 87.2% (80.9% to 91.6%) | 71.6% (59.9% to 81.0%) | 95.6% (90.7% to 97.9%) | 7.0 (6.3 to 7.7) | 0.13 (0.06 to 0.27)
Hachiya et al. 1991 ^133^ | 52 | 7.1 | 97.4% (86.3% to 99.4%) | 100.0% (78.0% to 99.8%) | 100.0% (90.3% to 99.9%) | 93.3% (69.9% to 98.6%) | 28.9 (27.1 to 30.7) | 0.04 (0.01 to 0.19)
5 studies | 2,090 lesions | Median 7.2 Moderate | Heterogeneous, no summary estimate calculated
Heterogeneity tests D | I^2^ = 90%
| Q = 28.22
| p of Q = 0.000011

Evidence Table 54. Meta-regression of Studies of Ultrasound for Palpable Lesions

Study | D | Standard error of D | Year of publication | Quality score | Size of study | Number of operators | Open or core biopsy | Patients lost % | Accounted for interreader reliablility | Prevalence of disease % | S
Chen et al. 2004 ^191^ | 3.5 | 0.168 | 2004 | 6.9 | 1203 | 1 | 1 (Either) | 0 | 0 (No) | 32.5 | -0.77764
Perre et al. 1994 ^192^ | 6.3 | 0.531 | 1994 | 7.4 | 380 | 1 | 2 (Open only) | 0 | 0 (No) | 43.5 | 1.021273
van Oord et al. 1991 ^193^ | 4.6 | 0.965 | 1991 | 7.2 | 305 | 1 | 0 (Not reported) | 23.9 | 0 (No) | 32.8 | 3.201538
McNicholas et al. 1993 ^194^ | 3.9 | 0.483 | 1993 | 7.8 | 203 | 1 | 1 (Either) | 0 | 0 (No) | 26.6 | 0.108803
Hachiya et al. 1991 ^133^ | 6.6 | 1.662 | 1991 | 7.1 | 52 | 2 | 1 (Either) | 0 | 1 (Yes) | 73.1 | -0.14842
p value | | | 0.412 | 0.934 | 0.428 | 0.602 | 0.503 | 1.0 | 0.601 | 0.173 | 0.685

D = ln of diagnostic odds ratio

SE = standard error

S = ln of measure of thresholdform

## Negative Predictive Value Analysis

Evidence Table 55. Negative Predictive Values Adjusted to 20% Prevalence

Threshold Sensitivity | PET all lesions | | SC nonpalpable lesions | | MRI all lesions | | US all lesions
| Specificity | NPV | Specificity | NPV | Specificity | NPV | Specificity | NPV
95% from SROC | 46.7 | 97.4 | 39.2 | 96.9 | 62.8 | 98.0 | NA | NA
90% from SROC | 65.0 | 96.3 | 58.0 | 95.9 | NA | NA | NA | NA
85% from SROC | 75.0 | 95.2 | 67.0 | 94.7 | 84.0 | 95.7 | NA | NA
80% from SROC | NA | NA | 75.0 | 93.8 | 88.0 | 94.6 | NA | NA
70% from SROC | 87.0 | 92.1 | NA | NA | 93.0 | 92.5 | NA | NA
60% from SROC | 93.0 | 90.3 | 88.0 | 89.8 | 95.0 | 90.5 | NA | NA
50% from SROC | 94.0 | 88.3 | 93.0 | 88.2 | 96.0 | 88.5 | NA | NA
Mean from SROC | Sensitivity 82.2% | 94.6 | Sensitivity 68.7% | 91.6 | Sensitivity 92.5% | 97.5 | Sensitivity 86.1 | 95.0
| Specificity 78.3% | | Specificity 84.8% | | Specificity 72.4% | | Specificity 66.4
At Mean threshold: from summary negative likelihood ratio (95% confidence interval) | Sensitivity 82.2% | 92.4 (89.7 to 94.3) | Sensitivity 68.7% | 90.7 (89.1 to 92.2) | Sensitivity 92.5% | 96.2 (95.5 to 96.9) | Sensitivity 86.1 | 95.0 (94.3 to 95.5)
| Specificity 78.3% | | Specificity 84.8% | | Specificity 72.4% | | Specificity 66.4

Mean threshold is the average threshold used by the actual studies. It is the threshold that the test will most likely be used at in the clinical setting.

The 95% confidence intervals for results derived from the SROC cannot be calculated due to technical difficulties, but it should not be assumed that the numbers are precide estimates; an range of error around each number does exist.

NA= not calculated. See the mean threshold instead for results close to this threshold.