# Peer Reviewers

- David Atkins, M.D.
- Agency for Healthcare Research and Quality

- Robyn Birdwell, M.D.
- Brigham & Women's Hospital

- Christie R. Eheman, Ph.D.
- Centers for Disease Control and Prevention

- Mark Helfand, M.D.
- Agency for Healthcare Research and Quality

- Maria C. Hinestrosa
- National Breast Cancer Coalition

- Peter I. Juhn
- Johnson & Johnson

- Robert Rosenberg, M.D.
- University of New Mexico Health Sciences Center