# List of Studies Excluded from Questions 1 and 2

Table 22 Studies of PET that Did Not Meet the Inclusion Criteria

Study | Reason
Adler et al. 1993 ^210^ | Report of the same study published in greater detail in Crowe et al. ^53^
Avril et al. 1997 ^211^ | Did not report any of the outcomes of interest.
Avril et al. 1996 ^212^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Avril et al. 2000 ^213^ | Update, with additional patients, of Avril et al. ^213^ , which reports that it studied a mixed population of patients (some patients had a history of breast cancer).
Buck et al. 2002 ^214^ | Did not report any of the outcomes of interest.
Danforth et al. 2002 ^215^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Fujiwara et al. 1999 ^216^ | Did not study the population of interest. Enrolled patients with various types of cancer to look for metastatic lesions. Less than 10 patients.
Inoue et al. 2004 ^217^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Levine et al. 2003 ^61^ | Did not study the technology of interest-- experimental methods.
Murthy et al. 2000 ^218^ | Did not study the technology of interest-- experimental methods.
Nieweg et al. 1993 ^219^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Noh et al. 1998 ^220^ | Fewer than 85% were evaluated by biopsy.
Pietrzyk et al. 1995 ^221^ | Did not report any of the outcomes of interest.
Scheidhauer et al. 1996 ^222^ | Confounded. Results of the PET exam were used to change or direct the surgical procedure for some of the patients, increasing the chances that the biopsy results matched the PET results.
Smyczek-Gargya et al. 2004 ^223^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Yutani et al. 1999 ^67^ | Did not report any of the outcomes of interest.

Table 23 Studies of Scintimammography that Did Not Meet the Inclusion Criteria

Study | Reason
Arslan et al. 1999 ^224^ | Fewer than 85% were evaluated by biopsy.
Aziz et al. 1999 ^225^ | Case-control design
Becherer et al. 1997 ^226^ | Fewer than 85% were evaluated by biopsy.
Buscombe et al. 2001 ^227^ | Retrospective review of patient data.
Buscombe et al. 1997 ^228^ | Reports that not all patients were evaluated by biopsy, but does not report how many were.
Clifford et al. 1996 ^229^ | Fewer than 85% were evaluated by biopsy.
Cwikla et al. 1998 ^230^ | Reports that not all patients were evaluated by biopsy, but does not report how many were.
Danielsson et al. 2003 ^231^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Dunnwald et al. 1997 ^232^ | Fewer than 85% were evaluated by biopsy.
Farias-Jimenez et al. 2002 ^233^ | Retrospective review of patient data.
Fleming 2002 ^234^ | Did not study the technology of interest-- experimental methods.
Fleming 2002 ^235^ | Did not study the technology of interest-- experimental methods.
Horne et al. 1999 ^236^ | Fewer than 85% were evaluated by biopsy.
Horne et al. 2001 ^237^ | Reports that not all patients were evaluated by biopsy, but does not report how many were.
Howarth et al. 1999 ^238^ | Fatally confounded. Results of the SC exam were used to change or direct the surgical procedure for some of the patients, increasing the chances that the biopsy results matched the SC results.
Howarth et al. 1999 ^239^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Iraniha et al. 1999 ^240^ | Reports that not all patients were evaluated by biopsy, but does not report how many were.
Khalkhali et al. 1995 ^241^ | Fewer than 85% were evaluated by biopsy.
Khalkhali et al. 1995 ^242^ | Fewer than 85% were evaluated by biopsy.
Khalkhali et al. 1994 ^243^ | Fewer than 85% were evaluated by biopsy.
Khalkhali et al. 1997 ^244^ | This is a summary of data published in full in Iraniha et al. ^240^
Kim et al. 2004 ^245^ | Fewer than 85% were evaluated by biopsy.
Lumachi et al. 1999 ^246^ | Retrospective review of patient data.
Lumachi et al. 2001 ^247^ | Retrospective review of patient data. Appears to be reporting a subgroup analysis of data already reported in Lumachi et al. ^248^
Lumachi et al. 2002 ^249^ | Retrospective review of patient data. Appears to be reporting a subgroup analysis of data already reported in Lumachi et al. ^250^
Massardo et al. 2002 ^251^ | This is part of a study published in full in Alonso et al. ^103^
Maurer et al. 1995 ^252^ | Did not study the technology of interest-- experimental methods.
Myslivecek et al. 2004 ^253^ | Fewer than 85% were evaluated by biopsy.
Nishiyama et al. 2001 ^254^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Palmedo et al. 1998 ^255^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Papantoniou et al. 2002 ^256^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Polan et al. 2001 ^257^ | Only patients positive by SC were biopsied.
Prats et al. 1999 ^258^ | Retrospective review of patient data.
Ren et al. 2002 ^259^ | Case-control design
Sampalis et al. 2001 ^260^ | This is an interim report of a study that was published in full in Sampalis ^260^
Scopinaro et al. 1999 ^261^ | Fewer than 85% were evaluated by biopsy.
Sillar et al. 1997 ^262^ | Fatally confounded. Results of the SC exam were used to change or direct the surgical procedure for some of the patients, increasing the chances that the biopsy results matched the SC results.
Taillefer et al. 1995 ^263^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Tiling et al. 1998 ^264^ | Fewer than 85% were evaluated by biopsy.
Tiling et al. 2005 ^265^ | Fewer than 85% were evaluated by biopsy.
Tolmos et al. 1998 ^266^ | Retrospective review of patient data.
Tolmos et al. 1998 ^266^ | Retrospective review of patient data.
Vargas et al. 2001 ^267^ | Retrospective review of patient data.
Yildiz et al. 2001 ^118^ | Fewer than 85% were evaluated by biopsy.

SC = scintimammography

Table 24 Studies of MRI that Did Not Meet the Inclusion Criteria

Study | Reason
Barbacioru et al. 2003 ^268^ | Meeting abstract. Not a full-length peer-reviewed publication.
Baum et al. 2002 ^269^ | Fewer than 85% of patients were evaluated with biopsy.
Baum et al. 2002 ^270^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Boetes et al. 2004 ^271^ | Retrospective review of patient data.
Bone et al. 2003 ^272^ | Retrospective review of patient data. Does not report any of the outcomes of interest. Did not study the population of interest. Only patients with confirmed breast cancer were enrolled.
Carriero et al. 2002 ^273^ | Did not study the technology of interest-- experimental methods.
Choi et al. 2002 ^274^ | Fewer than 85% of patients were evaluated with biopsy.
Fenlon et al. 1997 ^275^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Furman et al. 2003 ^276^ | Retrospective review of patient data.
Gibbs et al. 2004 ^277^ | Retrospective review of patient data.
Gibis et al. 1999 ^278^ | Not published in English.
Guo et al. 2002 ^279^ | Did not study the population of interest. Only patients with confirmed breast lesions were enrolled.
Heywang-Kobrunner et al. 2001 ^167^ | Confounded. For some patients, results of the histology were used to direct and change the readings of the MRI images.
Jacobs et al. 2003 ^280^ | Does not report any of the outcomes of interest.
Jacobs et al. 2003 ^281^ | Retrospective review of patient data.
Kaiser 1985 ^282^ | Does not report any of the outcomes of interest. Did not use a contrast agent.
Kelcz et al. 2002 ^165^ | Fatally confounded. Results of the MRI exam were used to change, direct, or repeat the biopsy procedure for some of the patients, increasing the chances that the biopsy results matched the MRI results.
Khatri et al. 2001 ^283^ | Does not report any of the outcomes of interest.
Kim et al. 2001 ^284^ | Retrospective review of patient data. Did not study the population of interest. Only patients with confirmed invasive breast cancer were enrolled.
Kramer et al. 1998 ^285^ | Fatally confounded. Results of the MRI exam were used to change, direct, or repeat the biopsy procedure for some of the patients, increasing the chances that the biopsy results matched the MRI results.
Lee et al. 2003 ^286^ | Did not study the population of interest. Only patients with confirmed breast cancer were enrolled.
Lucht et al. 2001 ^287^ | Did not study the technology of interest-- experimental methods.
Nagashima et al. 2002 ^288^ | Did not study the population of interest. Only patients with confirmed breast cancer were enrolled.
Nakahara et al. 2002 ^289^ | Did not study the population of interest. Only patients with confirmed breast cancer were enrolled.
Obenauer et al. 2002 ^290^ | Did not study the population of interest. Patients were enrolled only after a breast lesion was detected by MRI.
Reinikainen et al. 2002 ^291^ | Does not report any of the results of interest.
Rigauts et al. 1993 ^292^ | Study enrolled only five patients from the population of interest.
Schelfout et al. 2004 ^293^ | Fatally confounded. Results of the MRI exam were used to change, direct, or repeat the biopsy procedure for some of the patients, increasing the chances that the biopsy results matched the MRI results.
Schelfout et al. 2004 ^294^ | Retrospective review of patient data.
Shahar et al. 2002 ^295^ | Did not study the technology of interest-- experimental methods.
Siegmann et al. 2002 ^208^ | Does not report any of the results of interest. A quarter of the enrolled patients had previously had cancer, and their data were not reported separately.
Slanetz et al. 2002 ^296^ | Did not study the population of interest. Only patients with confirmed breast cancer were enrolled.
Szabo et al. 2003 ^297^ | Did not study the population of interest. Only patients with confirmed invasive breast cancer were reported on.
Szabo et al. 2004 ^164^ | Did not study the technology of interest-- experimental methods.
Teifke et al. 2002 ^298^ | Only data from patients referred for surgery or biopsy were reported. Results of the MRI exam may have influenced the decision to refer for surgery/biopsy.
Trecate et al. 2002 ^299^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Tuncbilek 2003 ^300^ | Does not report any of the results of interest.
Van Goethem et al. 2004 ^301^ | Fatally confounded. Results of the MRI exam were used to change, direct, or repeat the biopsy procedure for some of the patients, increasing the chances that the biopsy results matched the MRI results.
Wedegartner et al. 2001 ^302^ | Does not report any of the results of interest.
White et al. 2002 ^303^ | Does not report any of the results of interest.
Wiberg et al. 2003 ^304^ | Does not report any of the results of interest.
Yeh et al. 2003 ^305^ | Retrospective review of patient data.
Zuiani et al. 2002 ^306^ | Retrospective review of patient data.

Table 25 Studies of Ultrasound that Did Not Meet the Inclusion Criteria

Study | Reason
Allen et al. 2001 ^307^ | Did not report any of the outcomes of interest.
Arger et al. 2001 ^308^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Baker and Soo 2002 ^309^ | Retrospective review of patient data. Does not report any of the outcomes of interest.
Baker et al. 1999 ^200^ | Retrospective review of patient data.
Beeckman et al. 1991 ^310^ | Did not report any of the outcomes of interest.
Bhatti et al. 2001 ^311^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Bosch et al. 2003 ^312^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Brittenden et al. 1995 ^313^ | Did not study the technology of interest-- experimental methods.
Britton and Coulden 1990 ^314^ | Fewer than 85% were evaluated by biopsy.
Buadu et al. 1997 ^315^ | Did not study the technology of interest-- experimental methods.
Carson et al. 1997 ^316^ | Did not study the technology of interest-- experimental methods.
Caruso et al. 2002 ^317^ | Did not study the technology of interest-- experimental methods.
Chandawarkar and Shinde 1997 ^318^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Chao et al. 1999 ^319^ | Did not study the technology of interest-- experimental methods.
Chen et al. 2003 ^320^ | Did not study the population of interest-- screening study of women with dense breasts.
Chen et al. 2002 ^321^ | Did not study the technology of interest-- experimental methods.
Chen et al. 2003 ^322^ | Retrospective review of patient data.
Choi et al. 2000 ^323^ | Retrospective review of patient data.
Ciatto et al. 1994 ^324^ | Fewer than 85% were evaluated by biopsy.
Cilotti et al. 1997 ^325^ | Fewer than 85% were evaluated by biopsy, and results of the ultrasound exam influenced the decision to perform biopsy.
Cimitan et al. 1995 ^326^ | Did not study the population of interest. An unspecified number of patients were only enrolled because of prior positive findings by ultrasound.
Cosgrove et al. 1993 ^327^ | Fewer than 85% were evaluated by biopsy.
Cosmacini 1990 ^328^ | Fewer than 85% were evaluated by biopsy.
Debniak et al. 2004 ^329^ | Did not study the technology of interest-- experimental methods.
Delorme et al. 1998 ^330^ | Retrospective review of patient data.
Dixon et al. 1992 ^331^ | Case-control design.
Dock 1993 ^332^ | Did not study the technology of interest-- experimental methods.
Drukker et al. 2003 ^333^ | Did not study the technology of interest-- experimental methods.
Edde 1994 ^334^ | Fewer than 85% were evaluated by biopsy.
Edgar 1995 ^335^ | Retrospective review of patient data.
Eltahir et al. 1999 ^336^ | Retrospective review of patient data.
Finlay et al. 1994 ^337^ | Retrospective review of patient data.
Flobbe et al. 2003 ^188^ | Fewer than 85% were evaluated by biopsy, and results of the ultrasound exam influenced the decision to perform biopsy.
Forsberg et al. 2004 ^338^ | Did not study the technology of interest-- experimental methods.
Foxcroft et al. 2004 ^339^ | Retrospective case-control design.
Fung and Jackson 1990 ^340^ | Did not study the population of interest-- screening study of women with dense breasts.
Garra et al. 1993 ^341^ | Retrospective review of patient data.
Gefan et al. 2003 ^342^ | Did not report any of the outcomes of interest.
Germer et al. 2002 ^343^ | Did not report any of the outcomes of interest.
Giuseppetti et al. 1998 ^344^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Golshan et al. 2003 ^345^ | Retrospective review of patient data.
Golub et al. 1993 ^346^ | Did not study the technology of interest-- experimental methods.
Graf et al. 2004 ^347^ | Retrospective review of patient data.
Hieken et al. 2001 ^348^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Hieken et al. 1998 ^349^ | Fewer than 85% were evaluated by biopsy.
Hollerweger et al. 1997 ^350^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Houssami et al. 2003 ^351^ | Case-control design.
Huang et al. 1999 ^352^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Huber et al. 1998 ^353^ | Did not study the technology of interest-- experimental methods.
Huber et al. 1994 ^354^ | Did not study the technology of interest-- experimental methods.
Jackson et al. 1986 ^355^ | Fewer than 85% were evaluated by biopsy.
Joo et al. 2004 ^356^ | Did not study the technology of interest-- experimental methods.
Kaiser et al. 2002 ^357^ | Retrospective review of patient data.
Kaplan et al. 2001 ^358^ | Did not study the population of interest-- screening study of women with dense breasts.
Kedar et al. 1995 ^359^ | Did not study the technology of interest-- experimental methods.
Kimme-Smith et al. 1988 ^360^ | Fewer than 85% were evaluated by biopsy.
Kolb et al. 2002 ^361^ | Did not study the population of interest-- screening study of women with dense breasts.
Kolb et al. 1998 ^362^ | Did not study the population of interest-- screening study of women with dense breasts.
Kolb et al. 1997 ^363^ | Meeting abstract. Not a full-length peer-reviewed publication.
Kook et al. 2003 ^364^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Kook et al. 1999 ^365^ | Retrospective review of patient data.
Krestan et al. 2002 ^366^ | Case-control design.
Kuupers et al. 1994 ^367^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Lam et al. 2004 ^368^ | Retrospective review of patient data.
Leconte et al. 2003 ^369^ | Retrospective review of patient data.
Lee et al. 1995 ^370^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Lee et al. 1996 ^371^ | Only data from patients referred for surgery or biopsy were reported. Number of patients initially enrolled in the study is not reported. Results of the ultrasound exam may have influenced the decision to refer for surgery/biopsy.
Leung et al. 2002 ^372^ | Retrospective review of patient data.
Lister et al. 1998 ^373^ | Did not study the population of interest. Only enrolled patients with confirmed benign lesions.
Louie et al. 2003 ^374^ | Did not report any of the outcomes of interest.
Madjar et al. 1995 ^375^ | Did not report any of the outcomes of interest.
Madjar et al. 1997 ^376^ | Did not report any of the outcomes of interest.
Madjar et al. 1994 ^377^ | Did not study the technology of interest-- experimental methods.
Madjar et al. 1991 ^378^ | Did not study the technology of interest-- experimental methods.
Madjar et al. 2000 ^379^ | Did not study the technology of interest-- experimental methods.
Marini et al. 2003 ^380^ | Fewer than 85% were evaluated by biopsy.
Martinez et al. 2003 ^381^ | Did not study the technology of interest-- experimental methods.
Medl et al. 1994 ^382^ | Did not study the technology of interest-- experimental methods.
Mesaki et al. 2003 ^383^ | Fewer than 85% were evaluated by biopsy.
Milz et al. 2001 ^384^ | Did not study the technology of interest-- experimental methods.
Moss et al. 1999 ^385^ | Retrospective review of patient data.
Murad and Bari 2004 ^203^ | Retrospective review of patient data.
Obwegeser et al. 1999 ^386^ | Not a full-length peer-reviewed publication.
Ohlinger et al. 2004 ^387^ | Did not report any of the outcomes of interest.
Ozdemir et al. 2004 ^388^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Ozdemir et al. 2004 ^389^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Ozdemir et al. 2001 ^390^ | Did not study the technology of interest-- experimental methods.
Ozdemir et al. 1997 ^391^ | Only data from patients referred for surgery or biopsy were reported. Number of patients initially enrolled in the study is not reported. Results of the ultrasound exam may have influenced the decision to refer for surgery/biopsy.
Pamilo et al. 1991 ^392^ | Does not describe what reference standard was used.
Park et al. 2003 ^393^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Peters-Engl et al. 1998 ^394^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Peters-Engl et al. 1994 ^395^ | Did not study the technology of interest-- experimental methods.
Pillsbury et al. 2005 ^396^ | Retrospective review of patient data.
Pinero et al. 2003 ^397^ | Did not study the technology of interest-- experimental methods.
Pritt et al. 2004 ^398^ | Retrospective review of patient data.
Puglisi et al. 2003 ^399^ | Pooled the results of US and mammography into a single diagnosis.
Rahbar et al. 1999 ^202^ | Retrospective review of patient data.
Ramlau and Sledzikowski 1993 ^400^ | Did not study the technology of interest-- experimental methods.
Ranieri et al. 1997 ^401^ | Fewer than 85% were evaluated by biopsy.
Raza and Baum 1997 ^402^ | Only data from patients referred for surgery or biopsy were reported. Number of patients initially enrolled in the study is not reported. Results of the ultrasound exam may have influenced the decision to refer for surgery/biopsy.
Reinikainen et al. 2001 ^403^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Richter 1995 ^404^ | Did not study the technology of interest-- experimental methods.
Richter 1996 ^405^ | Did not study the technology of interest-- experimental methods.
Richter and Heywang-Kobrunner 1995 ^406^ | Did not study the technology of interest-- experimental methods.
Richter and Kobrunner 1995 ^407^ | Did not study the technology of interest-- experimental methods.
Richter et al. 1997 ^408^ | Did not study the technology of interest-- experimental methods.
Rosen and Soo 2001 ^409^ | Fewer than 85% were evaluated by biopsy.
Rubin et al. 2001 ^410^ | Retrospective review of patient data.
Saarenmaa et al. 2001 ^411^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Sahin-Akyar and Sumer 1996 ^412^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Saitoh et al. 1994 ^413^ | Only data from patients referred for surgery or biopsy were reported. Number of patients initially enrolled in the study is not reported. Results of the ultrasound exam may have influenced the decision to refer for surgery/biopsy.
Schelling et al. 1997 ^414^ | Did not report any of the outcomes of interest.
Schroeder et al. 1999 ^415^ | Fewer than 85% were evaluated by biopsy.
Schutze et al. 1998 ^416^ | Fewer than 85% were evaluated by biopsy, and results of the ultrasound exam influenced the decision to perform biopsy.
Sehgal et al. 2004 ^417^ | Retrospective review of patient data.
Selinko et al. 2004 ^418^ | Retrospective review of patient data.
Seo et al. 2002 ^419^ | Fewer than 85% were evaluated by biopsy.
Shetty et al. 2003 ^420^ | Fewer than 85% were evaluated by biopsy.
Shimamoto et al. 1998 ^206^ | Retrospective review of patient data.
Skaane 1999 ^421^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Skaane 1999 ^186^ | Retrospective review of patient data.
Skaane and Sauer 1999 ^422^ | Retrospective review of patient data.
Skaane et al. 1997 ^204^ | Retrospective review of patient data.
Skanne and Skjorten 1999 ^423^ | Retrospective review of patient data.
Skanne et al. 1999 ^424^ | Retrospective review of patient data.
Snelling et al. 2004 ^425^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Spreafico et al. 1994 ^426^ | Did not study the population of interest. Only enrolled patients with a palpable mass that was not visible on ultrasound.
Stavros et al. 1995 ^427^ | Did not study the population of interest. Some patients were only enrolled because of prior positive findings by ultrasound. Only reported data for patients with solid, visible lesions on ultrasound. Unknown how many patients were originally examined.
Steinberg et al. 2001 ^428^ | Did not study the technology of interest-- experimental methods.
Szopinski et al. 2003 ^429^ | Did not study the technology of interest-- experimental methods.
Tavassoli et al. 1997 ^430^ | Does not describe what reference standard was used.
Taylor et al. 2002 ^431^ | Pooled the results of US and mammography into a single diagnosis.
Tohnosu et al. 1993 ^432^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Vetto et al. 1996 ^433^ | Fewer than 85% were evaluated by biopsy.
Wang et al. 2002 ^434^ | Did not study the population of interest-- screening study of women with dense breasts.
Whitehouse et al. 2001 ^435^ | Fewer than 85% were evaluated by biopsy.
Whitehouse et al. 2001 ^436^ | Meeting abstract. Not a full-length peer-reviewed publication.
Wilkens et al. 1998 ^437^ | Did not study the population of interest. An unspecified number of patients were only enrolled because of prior positive findings by ultrasound.
Wright et al. 1998 ^438^ | Does not describe what reference standard was used.
Yang and Metreweli 1996 ^439^ | Did not report any of the outcomes of interest.
Yang and Tse 2004 ^440^ | Retrospective review of patient data.
Yang et al. 1997 ^441^ | Did not report any of the outcomes of interest.
Yang et al. 2001 ^442^ | Did not study the technology of interest-- experimental methods.
Yang et al. 1996 ^443^ | Fewer than 85% were evaluated by biopsy.
Youssefzadeh et al. 1996 ^444^ | Did not study the technology of interest-- experimental methods.
Zonderland et al. 1999 ^445^ | Fewer than 85% were evaluated by biopsy, and results of the ultrasound exam influenced the decision to perform biopsy.

Table 26 Studies of Multiple Imaging Technologies that Did Not Meet the Inclusion Criteria

Study | Reason
Bagni et al. 2003 ^446^ | Fewer than 85% evaluated by biopsy.
Berg et al. 2004 ^447^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Boetes et al. 1995 ^448^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Hardy et al. 1990 ^449^ | Fewer than 85% evaluated by biopsy.
Hata et al. 2004 ^450^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Hlawatsch et al. 2002 ^451^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Klaus et al. 2000 ^127^ | Did not study the population of interest. Only enrolled patients with prior positive findings by ultrasound.
Leinsinger et al. 2001 ^452^ | Patients enrolled were of a mixed population, and data from the population of interest were not reported separately.
Liang et al. 2003 ^453^ | Did not report any of the outcomes of interest.
Malur et al. 2001 ^454^ | Retrospective review of patient data.
Muller-Schimpfle et al. 1997 ^455^ | Retrospective review of patient data.
Rieber et al. 2002 ^456^ | Fatally confounded. Results of the imaging exams were used to change or direct the surgical procedure for some of the patients, increasing the chances that the biopsy results matched the PET results.
Sommer et al. 1997 ^457^ | Duplicate publication of data reported in Tiling et al. ^95^
Tiling et al. 1998 ^458^ | Retrospective review of patient data.
Wang et al. 2002 ^459^ | Did not study the population of interest-- screening study of women with dense breasts.
Yang et al. 1997 ^460^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.