# Literature Search Strategies

Electronic Database Searches

The following databases have been searched for relevant information:

ClinicalTrials.gov (through April 2005)

Cochrane Database of Systematic Reviews (through 2005, Issue 2)

Cochrane Registry of Clinical Trials (CENTRAL) (through 2005, Issue 2)

Cochrane Review Methodology Database (through 2005, Issue 2)

Controlled Trials.com (searched April 7, 2005)

CRISP (2004-2005)

Database of Reviews of Effectiveness (Cochrane Library) (through 2005, Issue 2)

ECRI Health Devices Alerts (1977 through April 2005)

ECRI Health Devices Sourcebase (through April 2005)

ECRI Healthcare Standards (1975 through April 2005)

ECRI International Health Technology Assessment Database (IHTA) (through April 2005)

ECRI Library Catalog (through April 2005)

ECRI TARGET (through April 2005)

Embase (1985 through March 31, 2005)

PubMed (includes Medline, HealthSTAR and CancerLit) (Q1–Q2 1985 through May 23, 2005; Q3 1999 through May 23, 2005)

U.S. Centers for Medicare & Medicaid Services (CMS) Web site (through April 2005)

Search Strategies

The search strategies employed a number of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts.

Medical Subject Headings (MeSH) and Keywords

[underlined: Conventions:]

[mh] = MeSH heading

[majr] = MeSH heading designated as major topic

[pt] = Publication Type (PubMed)

[sb] = Subset of PubMed database (PreMEDLINE, Systematic, OldMEDLINE)

[sh] = MeSH subheading (qualifiers used in conjunction with MeSH headings)

[tiab] = keyword in title or abstract

[tw] = Text word

/de = controlled vocabulary heading in Dialog syntax (MeSH, Emtree, PsycINFO)

[underlined: Topic-Specific]

Adverse effects[sh]

Breast neoplasms[mh]

Breast cancer!/de

Breast carcinoma!/de

Breast diseases[mh]

Complications[sh]

Contrast media[mh]

Diagnostic imaging/de

Diagnostic use[sh]

Early diagnosis/de

Echogra*

Echomammogr*

Echomammography/de

Electromagnetic fields[mh]

FDG*

Fluorodeoxyglucose F 18[mh]

“Gamma camera”

Gammagraph*

Magnetic resonance imaging[mh]

“Magnet strength”

Miraluma

Methoxy isobutyl isonitrile technetium TC-99/de

Noninvasive

“Non-invasive”

Nuclear magnetic resonance imaging/de

Nuclear medicine

Organotechnetium compounds/du[mh]

PET[ti]

Positron emission tomography

Pulse sequence

Radionuclide

Radionuclide imaging[sh]

Radiopharmaceuticals[mh]

Radiotracer*

Scintimammogr*

Scintimammography/de

Sestamibi*

Sonogr*

Sonomammogr*

SPECT

Spectrometry, gamma[mh]

Spectrometry, x-ray emission[mh]

SPET

Static

Technetium Tc 99m Sestamibi/du[mh]

Tetrofosmin

Tomography, emission-computed[mh]

Ultrason*

Ultrasonography[sh]

Ultrasonography, mammary[mh]

Ultrasound

[underlined: Diagnosis]

Accuracy

Diagnos*

Di[sh]

Diagnostic accuracy/de

Diagnostic value/de

False negative

False positive

Gold standard

Likelihood

Precision

Predictive value of tests[mh]

“Receiver operating characteristic”

ROC

Sensitivity

Sensitivity and specificity[mh]

specificity

true negative

true positive

[underlined: Other]

Acredit*

Ambulatory

Artifact*

Artefact*

Attenuat*

Boundar*

Calibration[mh]

Clinical competence

Data acquisition

Delineat*

Diagnostic errors[mh]

Differentiat*

Discomfort*

Dynamic range

“Effective dose”

Epidemiology

Equipment design[mh:noexp]

Equipment failure[mh:noexp]

Equipment failure analysis[mh]

Equipment reuse[mh]

Equipment safety[mh]

“Exam time”

Experience

facility

“Field of view”

Focal zone

“Foreign bodies”

“Free-standing”

“Free standing”

“Gain setting”

Hazard*

Human error

Human factors

“Iatrogenic air”

Intraobserver[tiab]

“Intra-observer”[tiab]

Interobserver[tiab]

“Inter-observer”[tiab]

Interpret*[tiab]

“Kappa”

Learning curve

Medical errors[mh]

Mobile

“Observer bias”

“Observer variability”

Observer variation[mh]

Occupational exposure[mh]

Operator error

Outcome

Pain

Patient satisfaction[mh]

Radiation dosage[mh]

Radiation monitoring[mh]

Radiometry[mh]

Reader*[tiab]

“Reader concordance”

Reverberat*

“Review time”

Safe*

Scintillation counting[mh]

Shadow*

“Speckle reduction”

Surgicenter*

Tertiary

Timing

User error

Visuali*

Whole-body counting[mh]

[underlined: Publication types]

Guidelines:

“Clinical pathway”

Consensus[pt]

Guideline[pt]

Guideline*[ti]

“Policy statement”

“Position paper”

“Position statement”

Practice guidelines[mh]

“Practice parameter”

Standard*[ti]

Standards[sh]

“White paper”

Meta-analyses/Systematic Reviews:

Meta-analysis

Meta-analysis[mh]

Meta-analysis[pt]

“Systematic Review”

(evidence base* OR methodol* OR systematic* OR quantitative* OR studies OR overview*) AND review[pt]

Randomized Controlled Trials:

Crossover*

Cross-over*

Double-blind method[mh]

“Latin square”

Placebo*

Placebos[mh]

Random*[ti]

Random allocation[mh]

Randomized controlled trial[pt]

Randomized controlled trials[mh]

Single-blind method[mh]

((singl*[tw] OR doubl*[tw] OR trebl*[tw] OR tripl*[tw]) AND (mask* OR blind* OR sham* OR dummy)

## PubMed Search Strategy

1/1/99 - 5/23/05

Parallel strategies were developed to search Embase and the Cochrane libraries

Limited to English language, human population

Set Number | Concept | Search Statement
1 | Breast Cancer | Breast neoplasms[mh] OR breast diseases[mh]
2 | Diagnosis | #1 AND (diagnosis OR diagnose OR diagnostic OR di[sh] OR “gold standard” OR “ROC” OR “receiver operating characteristic” OR sensitivity and specificity[mh] OR likelihood OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “predictive value” OR accuracy OR precision)
3 | Noninvasive Technique | #2 AND (noninvasive OR non-invasive)
4 | Ultrasonography | #2 AND (ultrasonography[sh] OR ultrasonography, mammary[mh] OR echogra* OR echomammogr* OR sonogr* OR sonomammogr*OR ultrasound OR ultrason*)
5 | MRI | #2 AND (magnetic resonance imaging[mh] OR “magnet strength” OR miraluma OR pulse sequence OR MR OR MRI OR magnet strength OR nuclear magnetic resonance OR NMR)
6 | PET | #2 AND (FDG* OR fluorodeoxyglucose F 18[mh] OR PET[ti] OR organotechnetium compounds/du[mh] OR positron emission tomography OR sestamibi OR technetium Tc 99m Sestamibi/du[mh] OR tomography, emission-computed[mh] OR tetrofosmin)
7 | Nuclear Medicine | #2 AND (gamma camera OR gammagraph* OR nuclear medicine OR radionuclide OR radionuclide imaging[sh] OR radiotracer* OR radiopharmaceuticals[mh] OR scintimammogr* OR spectrometry, gamma[mh])
8 | SPECT | #2 AND (spectrometry, x-ray emission[mh] OR SPET OR SPECT)
9 | Combine sets | #3 OR #4 OR #5 OR #6 OR #7 OR #8
10 | Interpretation/quality of test results | #9 AND (artifact* OR artifact* OR attenuate* OR boundar* OR calibration[mh] OR data acquisition OR delineat* OR differentiate* OR dynamic range OR “exam time” OR “field of view” OR “focal zone” OR “foreign bodies” OR “gain setting” OR intraobserver[tiab] OR “intra-observer”[tiab] OR interobserver[tiab] OR “inter-observer”[tiab] OR interpret* OR kappa OR “observer bias” OR “observer variability” OR observer variation[mh] OR reader*[tiab] OR “reader concordance” OR reverberat* OR shadow* OR “speckle reduction” OR visuali*)
11 | Operator experience | #9 AND (Accredit* OR Clinical competence[mh] OR experience OR “learning curve” OR “review time”)
12 | Adverse events | #9 AND (diagnostic errors[mh] OR discomfort* OR “effective dose” OR hazard* OR iatrogenic OR medical errors[mh] OR occupational exposure[mh] OR pain OR patient satisfaction[mh] OR radiation dosage[mh] OR radiation monitoring[mh] OR radiometry[mh] OR safe* OR scintillation counting[mh] OR whole body counting[mh])
13 | Human factors | #9 AND (human error OR human factors OR operator error OR timing OR user error)
14 | Equipment | #9 AND (equipment design[mh:noexp] OR equipment failure[mh:noexp] OR equipment failure analysis[mh] OR equipment reuse[mh] OR equipment safety[mh])
15 | Location | #9 AND (ambulatory OR facility OR “free-standing” OR “free standing” OR mobile OR surgicenter* OR tertiary OR
16 | RCTs | (randomized controlled trials[mh] OR random allocation[mh] OR randomized controlled trial[pt] OR double-blind method[mh] OR single-blind method[mh] OR “single-dummy” OR “double-dummy” OR placebo* OR random*[ti] OR crossover OR “cross-over” OR ((singl*[tw] OR doubl*[tw] OR trebl*[tw] OR tripl*[tw]) AND (mask*[tw] OR blind*[tw])) OR “latin square”)
17 | Systematic Reviews | (systematic[sb] OR meta-analysis OR meta-analysis[pt] OR ((evidence base* OR methodol* OR systematic* OR quantitativ* OR studies OR overview*) AND review[pt]))
18 | Limit publication types | NOT (letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case reports[pt] OR review[pt])
19 | Limit to human | AND (humans[mh] OR preMEDLINE[sb] OR publisher[sb])