# Appendixes

Appendix A Literature Search Strategies

Appendix B Study Quality and Strength of Evidence Evaluation

Appendix C List of Studies Excluded from Questions 1 and 2

Appendix D Peer Reviewers

Appendix E Evidence Tables