# Results

## Summary of Studies

The literature searches yielded 15813 citations (Figure 4), of which 15278 were excluded in abstract screening. A search of the reference lists of relevant systematic reviews yielded another 85 studies, which brought the total number screened in full text to 534. Appendix A presents the literature search strategies (for each database searched). Appendix B lists the articles that were reviewed in full text that were excluded, with their rejection reasons.

Figure 4 Literature flow diagram

Note: Studies that enrolled both BCC and SCC populations are discussed in the BCC sections, because most enrolled lesions were BCCs.

SR = systematic review; SCC = squamous cell carcinoma; BCC = basal cell carcinoma; RCT = randomized controlled trial; NRCS = nonrandomized comparative study.

Figure 4. shows the literature flow for the project. The searches retrieved a combined 15813 unique citations. Of these 15278 were excluded in abstract screening. A search of 38 relevant systematic reviews identified another 1386 studies, of which 85 were deemed relevant (54 of these were duplicative with studies screened in through the database searches). Of the 534 articles assessed in full text, 409 were excluded for a variety of reasons. In the end we included 109 studies in 125 papers, 58 of which were RCTs.

The 109 included studies (described in 125 papers) report 58 randomized controlled trials (RCTs) and 51 nonrandomized comparative studies (NRCSs). Two papers reported the results of two separate trials and were analyzed separately; another seven studies were reported in multiple papers. Among the 58 RCTs in 69 papers,^19, 20, 22, 42–105^ 56 were reported in full papers, and two were reported only as conference abstracts.^42, 43, 45, 64^ Eighteen reported industry funding^54, 56, 66, 68, 69, 74, 75, 79, 83, 85, 92, 94, 96–98, 100, 104^, 5 used materials supplied by industry,^52, 55, 61, 62, 105^ 165 explicitly reported no industry support,^19, 42, 49, 51, 53, 57–59, 70, 72, 73, 76, 81, 91, 99, 102^ and 19 did not provide funding information ^20, 43, 45–48, 50, 63, 64, 67, 71, 80, 82, 89, 90, 93, 101^ (Appendix C).

Eleven of the NRCS contained either matched cohorts or adjustments for known confounders, and they were included in the analysis; the remaining 34 have been tabulated in Appendix G^106–140^ Of the 11 NRCSs in 15 papers.^141–155^ 2 reported industry funding,^143, 153^ 6 explicitly reported no industry support,^142, 144–148, 150–152, 155^ and 3 did not provide funding information^141, 149, 154^ (See Appendix C). Results from NRCSs are presented at the end of each outcome section.

The studies primarily reported on basal cell carcinoma (BCC), with a minority reporting results for squamous cell carcinoma (SCC). Nearly all reported results for recurrence or cure rate outcomes and adverse events, and many reported results for cosmetic outcomes. Few studies reported results using validated instruments for quality of life, mental health, or patient satisfaction with treatment. Details about study design, baselines, and treatments are in Appendix C, D, and E, respectively. Risk of bias assessments are shown in Appendix F.

Because of the wide variety of adverse events reported (see Appendix H for a list of adverse events and how many studies reported each), we have limited the analysis to (1) adverse events that lead to treatment discontinuation, (2) any serious or severe adverse event (as defined by each study), (3) infections of the treatment site, and (4) pain after treatment.

## Basal Cell Carcinoma

The evidence graph in Figure 5 shows that there are 36 comparisons that have been observed between 29 interventions organized in 7 intervention categories.

Figure 5 Evidence graph depicting compared treatments in RCTs of BCC lesions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 5. This is the topology map of the network meta-analysis of the interventions for all BCCs compared in 50 RCTs. Twenty-nine interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, curettage and diathermy, curettage and cryotherapy, laser), radiation (external or brachytherapy), PDT (MAL or ALA), drugs (5-FU, imiquimod, interferon, ingenol, other), curettage, no treatment, and placebo; or combinations of these (excision or Mohs, imiquimod and curettage, external radiation or brachytherapy, imiquimod and Mohs, excision plus PDT with or without curettage, and PDT plus laser therapy). Of the possible pairwise comparisons, 36 are covered by direct study comparisons as indicated by lines between the treatment circles. Most comparisons were covered by only a single RCT, and most treatments were compared with only one or two other treatments. Surgical excision was the most common comparator, being directly compared with imiquimod, MAL PDT, ALA PDT, cryotherapy, curettage and diathermy, curettage and cryotherapy, curettage alone, and Mohs surgery. MAL PDT was the second most compared, with lines to laser plus PDT, cryotherapy, surgical excision, imiquimod, 5-FU, and no treatment. The rest had three or fewer comparisons.

This evidence graph suggests that limited conclusions can be drawn about which individual intervention is best (with respect to each outcome) for two reasons: 1) some interventions have never been compared with other interventions, directly or indirectly, and 2) the observed comparisons between individual interventions are relatively sparse.

Groups of interventions that have never been compared with other groups are readily identified in the Figure, because they are represented as connected subgraphs. For example, one connected subgraph comprises radiation therapy (external or brachytherapy, node D1|D2) versus surgery (surgical excision or Mohs micrographic surgery, node A|B). Another connected subgraph comprises laser ablation (C5) versus diclofenac and/or calcitriol (other medication – F5) and versus no treatment (I). Four such subgraphs exist, and no conclusions can be drawn between interventions that belong to different subgraphs.

For individual interventions, the observed comparisons are relatively sparse: there are only 35 observed comparisons in the figure, out of the 378 that are possible among the 28 treatments. Further, information on each comparison is provided by at most three RCTs, and for most comparisons by only a single RCT. The evidence is even more sparse when one considers the information that is actually available for specific outcomes. Figure 6 shows the evidence graphs for the outcomes for which we have the most data, namely recurrence, lack of histologic clearance, and lack of clinical clearance. For these outcomes, no RCT data exist for 14, 8, and 14 of the 29 interventions, respectively. Evidence on other outcomes (quality of life, cosmetic outcomes, and costs or resource use) is even more sparse, as discussed in the following sections.

Figure 6 Evidence graphs for recurrence, histologic clearance, and clinical clearance from RCTs of BCC lesions

Figure 6. (A) Recurrence: This is the topology map of the network meta-analysis of the interventions for recurrence for all BCCs compared in 13 RCTs. Fifteen interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, curettage and cryotherapy, curettage and diathermy, and laser), radiation (external or brachytherapy), PDT (MAL or ALA), drugs (imiquimod); or combinations of interventions (excision or Mohs, external radiation or brachytherapy, imiquimod and Mohs, MAL PDT and laser). Of the possible pairwise comparisons, 14 are covered by direct study comparisons as indicated by lines between the treatment circles. Most comparisons were covered by only a single RCT, and most treatment were compared with only one or two other treatments. Surgical excision was the most common comparator, being directly compared with MAL PDT, ALA PDT, curettage and diathermy, curettage and cryotherapy, and Mohs surgery. (B) Lack of histological clearance: This is the topology map of the network meta-analysis of the interventions for lack of histological clearance for all BCCs compared in 15 RCTs. Twenty interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy or laser), PDT (MAL or ALA), drugs (imiquimod, 5-FU, ingenol, and other), and placebo or no treatment; or combinations of interventions (imiquimod and Mohs, imiquimod and curettage, MAL PDT and laser, and combinations of excision plus MAL or ALA PDT with or without curettage). Fourteen of these interventions are connected in the primary graph, with only MAL PDT connected to more than three others; most were connected to only one or two. MAL PDT was connected to MAL PDT plus laser, excision, 5-FU, imiquimod, and placebo. There are also three subgraphs: one connects curettage to imiquimod and curettage; the second connects Mohs surgery to imiquimid plus Mohs; and the third connects combinations of excision plus MAL or ALA PDT, with or without curettage. (C) Lack of clinical clearance: This is the topology map of the network meta-analysis of the interventions for lack of clinical clearance for all BCCs compared in 15 RCTs. Thirteen interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, laser), radiation (external or brachytherapy), PDT (MAL or ALA), drugs (imiquimod, interferon, ingenol); or combinations of interventions (excision or Mohs, external radiation or brachytherapy, MAL PDT and laser). Eleven of these interventions are connected in the primary graph, with none connected to more than three others. There is one subgraph comparing Mohs or excision with external radiation or brachytherapy.

The evidence remains sparse at the level of individual interventions even after considering results from the seven eligible NRCSs, which are described separately from the RCTs.

The characteristics of the included RCTs are summarized in Tables 3 through 6, for RCTs on superficial (n=9), nodular (n=18), high-risk (n=2), and mixed types (n=21) of BCC lesions. RCTs that report stratified results for different types of lesions are listed in the mixed table.

Table 3 Characteristics of RCTs of superficial BCCs

Study | Arm | Age, Mean | Female % | Lesion Size, Mean | Lesion location (%) | 1^*^ Adequate Randomization | 2^*^ Allocation Concealment | 3^*^ Arms Similar at Baseline | 4^*^ Patients Blinded | 5^*^ Providers Blinded | 6^*^ Outcome Assessors Blinded | 7^*^ <20% Loss to Followup
Arits 2013 23683751 | MAL-PDT | median 63 | 52 | NR | head/neck excluding H-zone (12), extremities (29), trunk (59), upper extremities (16), lower extremities (13) | Yes | Yes | Yes | No | No | Yes | Yes
Arits 2013 23683751 | Imiquimod | median 62 | 49 | NR | head/neck excluding H-zone (12), extremities (27), trunk (61), upper extremities (13), lower extremities (14) | Yes | Yes | Yes | No | No | Yes | Yes
Arits 2013 23683751 | Fluorouracil | median 64 | 47 | NR | head/neck excluding H-zone (15), extremities (24), trunk (60), upper extremities (13), lower extremities (11) | Yes | Yes | Yes | No | No | Yes | Yes
Basset-Seguin 2008 18693158 | MAL-PDT | 62 | 33 | NR | face/scalp (6), extremities (22), trunk/neck (72) | No | Yes | Yes | No | No | Unsure | Yes
Basset-Seguin 2008 18693158 | Cryotherapy | 64 | 47 | NR | face/scalp (4), extremities (20), trunk/neck (76) | No | Yes | Yes | No | No | Unsure | Yes
Beutner 1999 10570388 | imiquimod 3x/week | NR | NR | NR | upper extremity (25), anterior upper trunk (25), posterior upper trunk (25), neck (25) | No | No | No | Unsure | Yes | Unsure | Yes
Geisse 2002 12196749 | Imiquimod 3x/wk | 62 | NR | median 1.0 cm^2^ | neck/face/forehead (4), upper extremity (not hand) (15), trunk (73), lower extremity/thigh (not foot) (8) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Geisse 2002 12196749 | Imiquimod 5x/wk | 55 | NR | median 0.6 cm^2^ | neck/face/forehead (3), upper extremity (not hand) (31), trunk (55), lower extremity/thigh (not foot) (10) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Geisse 2002 12196749 | Imiquimod 1x/day | 56 | NR | median 0.7 cm^2^ | neck/face/forehead (7), upper extremity (not hand) (21), trunk (64), lower extremity/thigh (not foot) (7) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Geisse 2002 12196749 | Imiquimod 2x/day | 69 | NR | median 1.0 cm^2^ | neck/face/forehead (8), upper extremity (not hand) (54), trunk (31), lower extremity/thigh (not foot) (8) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Geisse 2002 12196749 | vehicle (control) | 58 | NR | median 0.8 cm^2^ | neck/face/forehead (9), upper extremity (not hand) (34), trunk (47), lower extremity/thigh (not foot) (9) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Schleier 2007 25047438 | ALA-thermogel PDT | 69.9 | 46.15 | NR | face (54.17), scalp (20.83), lip (2.78), eyelid (1.39), extremities (9.72), trunk/neck (11.11) | Yes | No | Yes | Yes | Yes | Yes | Yes
Schleier 2007 25047438 | Methyl-ALA-thermogel PDT | 71.8 | 36.36 | NR | face (52.5), scalp (30), extremities (5), trunk/neck (12.5) | Yes | No | Yes | Yes | Yes | Yes | Yes
Schulze 2005 15888150 | imiquimod 5% | 64.3 | 39 | NR | cheek (1), forehead (0), extremities (including hand) (20), trunk/neck (70) | Yes | Yes | Yes | Yes | No | Unsure | No
Schulze 2005 15888150 | vehicle | 64.5 | 39 | NR | cheek (1), forehead (5), scalp (1), extremities (including hand) (30), trunk/neck (61) | Yes | Yes | Yes | Yes | No | Unsure | No
Siller 2010 20546215 | Total (ingenol mebutate vs placebo) | 59 | 27 | 9 mm | NR | Yes | Yes | Yes | Yes | Yes | Yes | Unsure
Sterry 2002 12452875 (superficial) | Imiquimod (2 days/week) with occlusion | 63 | 33 | median 1.5 cm^2^ | extremities (29), trunk/neck (71) | Yes | Yes | No | No | No | Unsure | Yes
Sterry 2002 12452875 (superficial) | Imiquimod (3 days/week) with occlusion | 58 | 35 | median 1.2 cm^2^ | extremities (31), trunk/neck (69) | Yes | Yes | No | No | No | Unsure | Yes
Sterry 2002 12452875 (superficial) | Imiquimod (2 days/week) without occlusion | 69 | 33 | median 1.0 cm^2^ | face (8). extremities (30), trunk/neck (62) | Yes | Yes | No | No | No | Unsure | Yes
Sterry 2002 12452875 (superficial) | Imiquimod (3 days/week) without occlusion | 61 | 44 | median 1.0 cm^2^ | extremities (32), trunk/neck (64), genitals (4) | Yes | Yes | No | No | No | Unsure | Yes
Szeimies 2008 18624836 | MAL-PDT | 64.5 | 36.0 | 12.5 mm | face/scalp (11.1), extremities (28.9), trunk/neck (60) | Yes | Yes | Yes | No | No | No | Yes
Szeimies 2008 18624836 | excision | 63.1 | 31.3 | 12.6 mm | face/scalp (4.5), extremities (25.0), trunk/neck (70.5) | Yes | Yes | Yes | No | No | No | Yes

BCC = basal cell carcinoma; MMS = Mohs micrographic surgery, PDT = photodynamic therapy; ALA = 5-aminolevulinic acid, MAL = methyl aminolevulinate, FU = fluorouracil; INF = interferon; RCT = randomized controlled trial; NR = not reported; x/wk = times per week

* Design items: 1: Adequate generation of a randomized sequence reported; 2: Adequate allocation concealment reported; 3: Group similarity at baseline; 4: Adequate blinding of patients reported; 5: Adequate blinding of providers reported; 6: Adequate blinding of outcome assessors reported; 7: Less than 20% missing for any eligible outcome in any arm.

Table 4 Characteristics of RCTs of nodular BCC

Study | Arm | Age, Mean | Female % | Lesion Size, Mean | Lesion location (%) | 1^*^ Adequate Randomization | 2^*^ Allocation Concealment | 3^*^ Arms Similar at Baseline | 4^*^ Patients Blinded | 5^*^ Providers Blinded | 6^*^ Outcome Assessors Blinded | 7^*^ <20% Loss to Followup
Abbade 2015 | Surgical excision | NR | NR | NR | head and neck (100) | No | No | Yes | No | No | unsure | Yes
Abbade 2015 | MAL-PDT | NR | NR | NR | head and neck (100) | No | No | Yes | No | No | unsure | Yes
Al-Niaimi 2015 26157307 | PDT + MMS | 61.4 | 66.7 | 200 mm^2^ | face (100) | No | Yes | Yes | No | No | Yes | No
Al-Niaimi 2015 26157307 | MMS | 62.7 | 40 | 201 mm2 | face (100) | No | Yes | Yes | No | No | Yes | No
Berroeta 2007 17573890 | Total (PDT vs. excision) | median 72 | NR | NR | NR | Yes | Yes | unsure | No | No | Yes | Yes
Butler 2009 19018814 | Vehicle group +MMS | 75.3 | 43.8 | 30.1 mm2 | face (100) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Butler 2009 19018814 | imiquimod 5% Cream group +MMS | 73.3 | 66.7 | 33.5 mm2 | hands (100) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Choi 2016 26551044 | Er:YAG ablative fractional laser-primed MAL-PDT | NR | 55 | NR | NR | No | Yes | Yes | Yes | Yes | Yes | Yes
Choi 2016 26551044 | MAL-PDT | NR | 36.8 | NR | NR | No | Yes | Yes | Yes | Yes | Yes | Yes
Eigentler 2007 17610993 | imiquimod 5% 8 weeks | median 65 | 27 | 8.2 mm | face (24.4), scalp (2.2), ear (8.9), trunk/neck (4.4), perioral (4.4), periorbital (8.9), nose (42), arm/shoulder (4.4) | No | No | Unsure | No | unsure | unsure | Yes
Eigentler 2007 17610993 | imiquimod 5% 12 weeks | median 63 | 33 | 9.6 mm | face (19.6), scalp (2.2), ear (10.9), trunk/neck (8.7), perioral (2.2), periorbital (6.5), nose (37), arm/shoulder (4.4), leg/hip (4.3) | No | No | Unsure | No | unsure | unsure | Yes
Foley 2009 20064185 | methyl-aminolevulinatePDT | 66 | 28.78 | 8.8 mm | face/scalp (25), extremities (20), Trunk 32 (43%) Neck 9 (12%) | Yes | Yes | unsure | Yes | Yes | Yes | Yes
Foley 2009 20064185 | placebo PDT | 67 | 20 | 9.0 mm | face/scalp (31), extremities (23), Trunk 34 (45%) Neck 1(1%) | Yes | Yes | unsure | Yes | Yes | Yes | Yes
Haak 2015 24903544 | MAL PDT | NR | 37.5 | median 8.5 mm | nose (37), forehead (31), cheek (6), oral area (13), periorbital area (13) | Yes | Yes | Yes | No | No | Yes | Yes
Haak 2015 24903544 | AFXL MAL PDT | NR | 68.8 | median 7 mm | nose (56), forehead (19), cheek (13), oral area (6), periorbital area (6) | Yes | Yes | Yes | No | No | Yes | Yes
Kuijpers 2006 16865869 | ALA-PDT (total) | 68.4 | 34.9 | 8.1 mm | forehead/temple+nose/paranasal (36.4), cheek/chin/lips (9.1), ears (9.1), extremities (9.1), trunk/neck (36.4) | Yes | Yes | unsure | No | No | Unsure | No
Kuijpers 2006 16865869 | MAL-PDT (total) | 68.4 | 34.9 | 8.4 mm | forehead/temple+nose/paranasal (38.1), cheek/chin/lips (4.8), ears (14.3), extremities (4.8), trunk/neck (38.1) | Yes | Yes | unsure | No | No | Unsure | No
Kuijpers 2006 16865869 | ALA-PDT (debulking subgroup) | 68.4 | 34.9 | NR | NR | Yes | Yes | unsure | No | No | Unsure | No
Kuijpers 2006 16865869 | ALA-PDT (no debulking subgroup) | 68.4 | 34.9 | NR | NR | Yes | Yes | unsure | No | No | Unsure | No
Kuijpers 2006 16865869 | MAL-PDT (debulking subgroup) | 68.4 | 34.9 | NR | NR | Yes | Yes | unsure | No | No | Unsure | No
Kuijpers 2006 16865869 | MAL-PDT (no debulking subgroup) | 68.4 | 34.9 | NR | NR | Yes | Yes | unsure | No | No | Unsure | No
Kuijpers 2007 17451581 | Curettage + Cryosurgery | 67 | 43 | 5.4 mm | Forehead/temple, Cheek/chin, Periocular (80), Lips/mouth (4), Ears/periauricular (8), Neck, chest/back (8) | No | No | Yes | Unsure | Unsure | Yes | Yes
Kuijpers 2007 17451581 | Surgical excision | 67 | 43 | 5.3 mm | Forehead/temple, Cheek/chin, Periocular (76), Lips/mouth (6), Ears/periauricular (6), Neck, chest/back (12) | No | No | Yes | Unsure | Unsure | Yes | Yes
Mosterd 2008 18717680 | ALA-PDT | 64 | 48.2 | 8.9 mm | face (53); “rest of the body” (47%) | Yes | Yes | Yes | Yes | No | No | No
Mosterd 2008 18717680 | Surgical excision | 65.1 | 50 | 9.3 mm | face (51); “rest of the body” (49%) | Yes | Yes | Yes | Yes | No | No | No
Orenberg 1992 1430394 | 7.5 mg 5-FU | 60 | 5 | 123.9 mm^2^ | face (30), extremities (30), trunk/neck (40) | unsure | unsure | No | yes | yes | yes | Yes
Orenberg 1992 1430394 | 15 mg 5-FU | 60 | 5 | 76.4 mm^2^ | face (10), scalp (10), lip (10), ear (30), extremities (10), trunk/neck (30) | unsure | unsure | No | yes | yes | yes | Yes
Rhodes 2004 14732655 | MAL PDT | 69 | 38 | NR | face/scalp (40), extremities (11), trunk/neck (49) | Yes | Yes | No | No | No | No | No
Rhodes 2004 14732655 | excision | 67 | 41 | NR | face/scalp (58), extremities (9), trunk/neck (29) | Yes | Yes | No | No | No | No | No
Shumack 2002 12224978 (12 weeks) | vehicle cream | NR | 42 | median 0.8 cm^2^ | face (17), trunk/neck (54.2), upper extremity (not hand) (25), lower extremity (not foot) (4) | No | No | No | Yes | unsure | unsure | Yes
| imiquimod 5% cream - Twice daily for 7 days per week | NR | 75 | median 0.8 cm2 | face (25), trunk/neck (75)
| imiquimod 5% cream - Once daily for 7 days per week | NR | 10 | median 0.7 cm2 | face (29), trunk/neck (33), upper extremity (not hand) (19), lower extremity (not foot) (10)
| imiquimod 5% cream - Once daily for 5 days per week | NR | 35 | median 0.7 cm2 | face (48), trunk/neck (26), Upper extremity (not hand) (17), lower extremity (not foot) (9)
| imiquimod 5% cream - Once daily for 3 days per week | NR | 30 | median 0.7 cm2 | face (40), trunk/neck (35), upper extremity (not hand) (20), lower extremity (not foot) (5)
Shumack 2002 12224978 (6 weeks) | imiquimod 5% cream - Twice daily for 7 days per week | NR | 0 | median 0.6 cm2 | face (100) | Yes | unsure | No | Yes | unsure | unsure | Yes
| imiquimod 5% cream - Once daily for 3 days per week | 63 | 13 | median 0.8 cm2 | face (28), trunk/neck (11.11), Upper extremity (not hand) (25), lower extremity (not foot) (13)
| imiquimod 5% cream - Twice daily for 7 days per week | 69 | 13 | median 0.8 cm2 | face (32), trunk/neck (39), Upper extremity (not hand) (26), lower extremity (not foot) (3)
| imiquimod 5% cream - Once daily for 7 days per week | 66 | 29 | median 0.8 cm2 | face (11), trunk/neck (48), Upper extremity (not hand) (26), lower extremity (not foot) (3)
| imiquimod 5% | NR | 40 | NR | face (60), ear (10), unspecified other (30) | No | No | Unsure | unsure | unsure | No | Yes
| vehicle | NR | 10 | NR | face (50), ear (20), unspecified other (30)
Sterry 2002 12452875 (nodular) | Imiquimod (2 days/wk) with occlusion | 66 | 50 | median: 0.6 cm2 | Face (10), Scalp (1), extremities (2), trunk/neck (9) | Yes | Yes | Yes | No | No | Unsure | Yes
| Imiquimod (3 days/wk) with occlusion | 66 | 30 | median: 0.7 cm2 | Face (18), extremities (2), trunk/neck (3)
| Imiquimod (2 days/wk) without occlusion | 67 | 24 | median: 1.0 cm2 | Face (9), extremities (1), trunk/neck (10)
| Imiquimod (3 days/wk) without occlusion | 66 | 46 | median: 0.6 cm^2^ | Face (11), extremities (5), trunk/neck (8)
van der Geer 2012 22385074 | Imiquimod + MMS | 69 | 37 | NR | H-zone (57), nose (23), ear 4 (11), scalp + frontal (23), other regions (cheek, temporal, chin) (43) | Yes | Yes | Yes | No | No | No | Yes
| no treatment + MMS | 68 | 31 | median 110 mm^2^ | H-zone (66), nose (26), ear (17), scalp + frontal (14), other regions (cheek, temporal, chin) (43)
Wettstein 2013 23566745 | Ringer’s lactate (control group) | 59 | 26.67 | 2.5 cm2 | nose (46.2), cheek (23.1), frontal (7.7), ear (23.1) | Yes | Unsure | Yes | Yes | Yes | Unsure | Yes
| interferon alpha-2b | 59 | 26.67 | 3.1 cm2 | nose (50), cheek (10), frontal (20), ear (20)

BCC = basal cell carcinoma; MMS = Mohs micrographic surgery, PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL= methyl aminolevulinate; FU = fluorouracil; INF = interferon; NR = not reported; RCT = randomized controlled trial; x/wk = times per week; AFXL = ablative fractional laser resurfacing

* Design items: 1: Adequate generation of a randomized sequence reported; 2: Adequate allocation concealment reported; 3: Group similarity at baseline; 4: Adequate blinding of patients reported; 5: Adequate blinding of providers reported; 6: Adequate blinding of outcome assessors reported; 7: Less than 20% missing for any eligible outcome in any arm.

Table 5 Characteristics of RCTs of high-risk BCC lesions

Study | Arm | Age, Mean | Female % | Lesion Size, Mean | Lesion location (%) | 1^*^ Adequate Randomization | 2^*^ Allocation Concealment | 3^*^ Arms Similar at Baseline | 4^*^ Patients Blinded | 5^*^ Providers Blinded | 6^*^ Outcome Assessors Blinded | 7^*^ <20% Loss to Followup
Alpsoy 1996 8708151 | IFN alfa-2a | 58.7 | 53 | median 2.05 cm2 | eyelid (27), nose (13), zygoma (27), forehead (13), cheek (13), trunk (7) | Yes | Yes | Unsure | Yes | Unsure | Unsure | Unsure
Alpsoy 1996 8708151 | IFN alfa-2b | 63.6 | 53 | median 1.82 cm2 | eyelid (20), nose (7), zygoma (20), forehead (20), cheek (27), trunk (7) | Yes | Yes | Unsure | Yes | Unsure | Unsure | Unsure
Alpsoy 1996 8708151 | IFN alfa-2a + IFN alfa-2b | 60.3 | 40 | median 1.9 cm2 | eyelid (20), nose (13), zygoma (27), forehead (13), cheek (20), trunk (7) | Yes | Yes | Unsure | Yes | Unsure | Unsure | Unsure
Migden 2015 25981810 | Sonidegib 200 | median 67 | 39 | NR | head and neck (100) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Migden 2015 25981810 | Sonidegib 800 | median 65 | 36 | NR | head and neck (100) | Yes | Yes | Yes | Yes | Yes | Yes | Yes

NR = not reported; IFN = interferon

* Design items: 1: Adequate generation of a randomized sequence reported; 2: Adequate allocation concealment reported; 3: Group similarity at baseline; 4: Adequate blinding of patients reported; 5: Adequate blinding of providers reported; 6: Adequate blinding of outcome assessors reported; 7: Less than 20% missing for any eligible outcome in any arm.

Table 6 Characteristics of RCTs of mixed types of BCC lesions

Study | Arm | Age, Mean | Female % | Lesion Size, Mean | Lesion Location (%) | 1^*^ Adequate Randomization | 2^*^ Allocation Concealment | 3^*^ Arms Similar at Baseline | 4^*^ Patients Blinded | 5^*^ Providers Blinded | 6^*^ Outcome Assessors Blinded | 7^*^ <20% Loss to Followup
Allen 1979 298425 | cryotherapy | NR | NR | NR | NR | Yes | Yes | Unsure | Yes | Unsure | Unsure | Unsure
Allen 1979 298425 | radiotherapy | NR | NR | NR | NR | Yes | Yes | Unsure | Yes | Unsure | Unsure | Unsure
Alpsoy 1996 8708151 | IFN alfa-2a | 58.7 | 53 | median 2.05 cm2 | eyelid (27), nose (13), zygoma (27), forehead (13), cheek (13), trunk (7) | Unsure | Unsure | Yes | Unsure | Unsure | Unsure | Yes
Alpsoy 1996 8708151 | IFN alfa-2b | 63.6 | 53 | median 1.82 cm2 | eyelid (20), nose (7), zygoma (20), forehead (20), cheek (27), trunk (7) | Unsure | Unsure | Yes | Unsure | Unsure | Unsure | Yes
Alpsoy 1996 8708151 | IFN alfa-2a + IFN alfa-2b | 60.3 | 40 | median 1.9 cm2 | eyelid (20), nose (13), zygoma (27), forehead (13), cheek (20), trunk (7) | Unsure | Unsure | Yes | Unsure | Unsure | Unsure | Yes
Avril 1997 9218740 | surgery | 66.5 | 54 | 11.1 mm | nose (53), cheek, pre- and retroauricular areas (21), eyelids, internal and external eye angles (19), forehead, temple, between eyebrows 36 (21), chin, cutaneous superior lip 10 (6), ear (3) | No | Yes | Yes | No | No | No | No
Avril 1997 9218740 | radiotherapy | 65.4 | 46 | 11.7 mm | nose (28), cheek, pre- and retroauricular areas (24), eyelids, internal and external eye angles (20), forehead, temple, between eyebrows (17), chin, cutaneous superior lip (7), ear (3) | No | Yes | Yes | No | No | No | No
Bath-Hextall 2014 24332516 | Imiquimod | NR | 41 | median 12 mm | face (37), trunk (38), neck (6), arm (6), leg (10), other (3) | Yes | Yes | Yes | No | No | Yes | No
Bath-Hextall 2014 24332516 | excision | NR | 40 | median 10 mm | face (33), trunk (39), neck (9), arm (7), leg (9), other (3) | Yes | Yes | Yes | No | No | Yes | No
Beutner 1999 10570388 | imiquimod 2x/day | NR | NR | NR | upper exremity (57), anterior upper trunk (14), neck (29) | No | No | No | Unsure | Yes | unsure | Yes
Beutner 1999 10570388 | imiquimod 1x/day | NR | NR | NR | upper extremity (50), anterior upper trunk (25), posterior upper trunk (25) | No | No | No | Unsure | Yes | unsure | Yes
Beutner 1999 10570388 | imiquimod 2x/week | NR | NR | NR | lower extremity (20), anterior upper trunk (40), posterior upper trunk (20), neck (20) | No | No | No | Unsure | Yes | unsure | Yes
Beutner 1999 10570388 | imiquimod 1x/week | NR | NR | NR | lower extremity (50), anterior upper trunk (25), posterior upper trunk (25) | No | No | No | Unsure | Yes | unsure | Yes
Beutner 1999 10570388 | vehicle (3 2x/day, 2 1x/day, 2 3x/week, 2 2x/week, 2 1x/week) | NR | NR | NR | face (9), upper extremity (46), anterior upper trunk (9), neck (9), posterior lower trunk (27) | No | No | No | Unsure | Yes | unsure | Yes
Brinkhuizen 2016 27067393 | Diclofenac (results superficial/nodular) | 63.0/78.5 | 25 | 61.7/49.5 mm2 | extremities (47), trunk/neck (53) | Yes | Yes | No | No | No | Yes | Yes
Brinkhuizen 2016 27067393 | Calcitriol (results superficial/nodular) | 65.5/68.5 | 22 | 54.2/59.7 mm2 | trunk/neck (59), genetalia (41) | Yes | Yes | No | No | No | Yes | Yes
Brinkhuizen 2016 27067393 | Diclofenac + Calcitriol (results superficial/nodular) | 67.5/71 | 37.5 | 46.7/44.8 mm2 | trunk/neck (50), genetalia (44) | Yes | Yes | No | No | No | Yes | Yes
Brinkhuizen 2016 27067393 | No treatment (results superficial/nodular) | 61.5/66 | 37.5 | 59.7/53.4 mm2 | extremities (53), trunk/neck (47) | Yes | Yes | No | No | No | Yes | Yes
Carija 2016 27516420 | ALA-PDT | Median 71 | 13.3 | 255.4 mm2 | extremities (3.6), trunk/neck (96.4) | No | No | Yes | unsure | Yes | Yes | Yes
Carija 2016 27516420 | ALA-PDT + PDL | Median 71 | 13.3 | 216 mm2 | extremities (23.5), trunk/neck (76.5) | No | No | Yes | unsure | Yes | Yes | Yes
Cornell 1990 2229497 | interferon | 56 | 19 | 83 mm2 | head and face (25), extermities (12), trunk/neck (63) | Yes | No | Yes | Yes | No | Yes | Yes
Cornell 1990 2229497 | placebo | 57 | 14 | 75 mm2 | head and face (17), extermities (14), trunk/neck (59) | Yes | No | Yes | Yes | No | Yes | Yes
Edwards 1990 2107219 | interferon gamma, 0.01 | NR | NR | NR | NR | No | No | unsure | unsure | unsure | unsure | Yes
Edwards 1990 2107219 | interferon gamma, 0.05 | NR | NR | NR | NR | No | No | unsure | unsure | unsure | unsure | Yes
Edwards 1990 2383027 | Interferon alfa-2b, 30 million IU | NR | NR | NR | NR | No | No | unsure | Yes | Yes | Yes | Yes
Edwards 1990 2383027 | Interferon alfa-2b, 10 million IU | NR | NR | NR | NR | No | No | unsure | Yes | Yes | Yes | Yes
Eimpunth 2014 | Laser vs. no treatment | NR | 33 | NR | NR | No Data | unsure | unsure | No | unsure | unsure | Yes
Garcia-Martin 2011 21242584 | imiquimod 5% | 73.1 | 33.3 | 7.6 mm | eyelid (100) | No | No | Yes | No | Unsure | Unsure | Yes
Garcia-Martin 2011 21242584 | radiotherapy | 74.2 | 41.7 | 7.41 mm | eyelid (100) | No | No | Yes | No | Unsure | Unsure | Yes
Geisse 2004 15097956 | Imiquimod 5x/wk | 58.4 | 37 | NR | neck (4), trunk: anterior lower (1), trunk: anterior upper (17), trunk: posterior lower (7), trunk: posterior upper (24), lower extremity (excluding foot) (15), upper extremity (excluding hand) (31), chin (1), forehead (1) | Yes | Yes | No | Yes | Yes | Yes | Yes
Geisse 2004 15097956 | Vehicle 5x/wk or 7x/wk | 58.7 | 38 | NR | neck (1), trunk: anterior lower (1), trunk: anterior upper (20), trunk: posterior lower (6), trunk: posterior upper (20), lower extremity (excluding foot) (10.5), upper extremity (excluding hand) (39), cheek (1), chin (1), forehead (1) | Yes | Yes | No | Yes | Yes | Yes | Yes
Geisse 2004 15097956 | Imiquimod 7x/wk | 59.4 | 41 | NR | neck (5), trunk: anterior lower 3, trunk: anterior upper (13), trunk: posterior lower (8), trunk: posterior upper (26), lower extremity (excluding foot) (11), upper extremity (excluding hand) (33), cheek (1), chin (1), forehead (1) Face: nose 1 (1%) | Yes | Yes | No | Yes | Yes | Yes | Yes
Hall 1986 3514075 | Radiotherapy | NR | NR | NR | face and neck (82), eyelid (6), trunk (12) | No | No | No | No | No | No | Unsure
Hall 1986 3514075 | Cryotherapy | NR | NR | NR | face and neck (65), eyelid (17), trunk (17) | No | No | No | No | No | No | Unsure
Marks 2001 11312429 | Imiquimod | 61 | 27 | NR | Upper extremities (32), upper trunk (28), head/neck/lower limbs (40) | No | No | unsure | No | unsure | unsure | Yes
Migden 2015 25981810 | sonidegib 200 | median 67 | 39 | NR | head and neck (100) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Migden 2015 25981810 | sonidegib 800 | median 65 | 36 | NR | head and neck (100) | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Miller 1997 8996264 | 5-FU | 61 | 20 | 80 mm2 | head (7), extremities (40), trunk/neck (52) | No | No | unsure | Yes | Yes | Yes | No
Mosterd 2008 19010733 | MMS | 67.4 | 39.7 | 1.28 cm2 | frontal/temporal (26), cheek/chin (9), (peri)nasal (34), lips/perioral (7), periocular (8), ears (4), periauricular (12) | Yes | Yes | Unsure | No | No | No | No
Mosterd 2008 19010733 | Surgical excision | 68.7 | 38.2 | 1.77 cm2 | frontal/temporal (32), cheek/chin (8), (peri)nasal (30), lips/perioral (4), periocular (8), ears (8), periauricular (10) | Yes | Yes | Unsure | No | No | No | No
Salmanpoor 2012 | Surgical excision | 57.3 | 37 | NR | face and scalp (100) | No | No | unsure | Unsure | Unsure | Unsure | Yes
Salmanpoor 2012 | Curettage | 57.3 | 37 | NR | face and scalp (100) | No | No | unsure | Unsure | Unsure | Unsure | Yes
Salmanpoor 2012 | Electodessication and curettage | 57.3 | 37 | NR | face and scalp (100) | No | No | unsure | Unsure | Unsure | Unsure | Yes
Thissen 2000 10940063 | cryotherapy | NR | NR | NR | face (46), eyelid (4), ear (4), trunk/neck (6), forehead/temple (34), chin/perioral (6) | No | No | Yes | No | Unsure | Unsure | Yes
Thissen 2000 10940063 | surgical excision | NR | NR | NR | face (43), eyelid (8), trunk/neck (14), forehead/temple (25), chin/perioral (10) | No | No | Yes | No | Unsure | Unsure | Yes
Torres 2004 15606733 | imiquimod, 2 weeks | NR | 33.3 | median 0.9 cm2 | NR | Yes | No | Yes | Yes | Yes | Unsure | Yes
Torres 2004 15606733 | imiquimod, 4 weeks | NR | 41.7 | median 0.8 cm2 | NR | Yes | No | Yes | Yes | Yes | Unsure | Yes
Torres 2004 15606733 | imiquimod, 6 weeks | NR | 33.3 | median 1.2 cm2 | NR | Yes | No | Yes | Yes | Yes | Unsure | Yes
Torres 2004 15606733 | vehicle controlled-pooled | NR | 19.4 | median 1.2 cm2 | NR | Yes | No | Yes | Yes | Yes | Unsure | Yes
Tran 2012 22511036 | PDL 15 j/cm2 | NR | 57 | 88 mm2 | extremities (12), trunk/neck (88) | No | No | No | Yes | No | No | Yes
Tran 2012 22511036 | PDL 7.5 j/cm2 | NR | 43 | 105 mm2 | extremities (50), trunk/neck (50) | No | No | No | Yes | No | No | Yes
Tran 2012 22511036 | No treatment | NR | 43 | 94 mm2 | extremities (43), trunk/neck (57) | No | No | No | Yes | No | No | Yes
Wang 2001 11298545 | Total (ALA-PDT vs. Cryotherapy) | NR | 50 | NR | legs (11), arms (7), trunk (54), head/neck (28) | Unsure | Unsure | Unsure | No | No | Unsure | Yes

BCC = basal cell carcinoma; MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon; NR = not reported; PDL = pulse dye laser; x/wk = times per week

* Design items: 1: Adequate generation of a randomized sequence reported; 2: Adequate allocation concealment reported; 3: Group similarity at baseline; 4: Adequate blinding of patients reported; 5: Adequate blinding of providers reported; 6: Adequate blinding of outcome assessors reported; 7: Less than 20% missing for any eligible outcome in any arm.

Across all trials, the mean or median age of enrollees ranged between 55 and 75.3 (median: 64, 25^th^–75^th^ percentile: 61 to 67). The proportion of female patients ranged between 0 and 75 percent (median: 37, 25^th^–75^th^ percentile: 30 to 43). When reported, the mean or median lesion area was between 30.1 and 205 mm^2^, and the median maximum diameter was between 5.3 and 12 mm. The majority of RCTs included lesions in various body locations, and only a few reported results stratified by lesion location (discussed separately). Based on this information, the RCTs included patients and lesions are typically encountered in clinical practice, but the lack of information on treatment effect heterogeneity with respect to patient-level factors hinders extrapolation to specific patient subgroups. No RCT focused on patients who were immunocompromised or had substantially limited life expectancy.

In terms of design characteristics, 29 RCTs had two arms, 5 had three arms, and 15 had four or more; the latter were primarily phase II studies, examining the tolerability of various doses or schedules of topically applied medications or alternative photodynamic treatment protocols. Such phase II studies are included in the comparisons between interventions only when they include a no intervention or placebo/sham intervention arm. Their findings with respect to different doses or protocols for the same intervention are summarized separately. Analyzed sample sizes ranged between 18 and 694 (median: 70, 25^th^–75^th^ percentile: 31 to 126.5); sample sizes per RCT arm ranged between 3 and 408.

Based on what was reported in the RCTs, we deemed that the allocation sequence was randomized using formal methods in 26 and successfully concealed in 25 RCTs, and that patients, providers, and outcome assessors were successfully blinded to the received treatments in 19, 13, and 19 RCTs, respectively. Our consensus assessment of the reported baseline characteristics across the compared arms in each RCT was that most RCTs (n=28) had arms that were likely balanced at baseline. In 41 RCTs fewer than 20 percent of patients had missing outcomes for any eligible outcome in any arm.

### Recurrence, All BCC Lesions

The evidence graph for recurrence with respect to individual treatments is sparse (Figure 6 (A) – reproduced in Figure 7 (A) for ease of reference), and comprises two connected subgraphs. Detailed results at the RCT-level are in the appendix.

Figure 7 Evidence graph of RCTs evaluating recurrence in BCCs across (A) individual interventions and (B) types of interventions

Note: The evidence graph for the individual treatments comprises 2 connected subgraphs defined by the following sets of nodes: A|B, D1|D2; and all remaining nodes.

Figure 7. (A) This is the topology map of the network meta-analysis of the interventions for recurrence for all BCCs compared in 13 RCTs. Fifteen interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, curettage and cryotherapy, curettage and diathermy, and laser), radiation (external or brachytherapy), PDT (MAL or ALA), drugs (imiquimod); or combinations of interventions (excision or Mohs, external radiation or brachytherapy, imiquimod and Mohs, MAL PDT and laser). Of the possible pairwise comparisons, 14 are covered by direct study comparisons as indicated by lines between the treatment circles. Most comparisons were covered by only a single RCT, and most treatment were compared with only one or two other treatments. Surgical excision was the most common comparator, being directly compared with MAL PDT, ALA PDT, curettage and diathermy, curettage and cryotherapy, and Mohs surgery. (B) This is the coarse topology map of the network meta-analysis of the different types of interventions for recurrence for all BCCs compared in 13 RCTs. The six intervention types include surgical, thermodynamic, radiation, PDT, medical/drugs, and curettage). Of the 15 possible pairwise comparisons, 8 are covered by direct study comparisons as indicated by lines between the treatment circles.

#### Comparisons Across Intervention Categories

In total, 13 RCTs (1664 lesions) were included in this analysis.^19, 20, 42, 45, 50–52, 67, 70, 71, 85, 90, 104^ Ten RCTs were deemed to be at low or moderate risk of bias. Cumulative sample sizes per comparison ranged from 27 to 347; for more details see Table 7.

Table 7 Sample information, recurrence (all BCC lesions, intervention categories)

Studies (total sample) | 13 (1664)
Total sample by intervention | (A,B): 580; (E): 329; (D): 234; (F): 221; (C): 280; (H): 20
Total sample by intervention, (min, max) | 20, 580
Data by comparison | (A,B--E): 3 (305); (A,B--D): 1 (347); (A,B--C): 2 (134); (A,B--H): 1 (44); (A—F): 1 (203); (E--C): 3 (355); (D--F): 1 (27); (D--C): 1 (93); (C--H): 1 (45)
Studies by comparison (min, max) | 1, 3
Total sample by comparison (min, max) | 27, 355
Followup median (min, max) | 28 (3, 96) months

A = surgical excision; B = Mohs micrographic surgery; BCC=basal cell carcinoma; C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F2 = Imiquimod; H = curettage

Table 8 shows the relative odds ratios for recurrence across intervention categories. Overall, surgical treatments (A,B), radiation (D), and drugs (F), appear to be better than interventions that destroy lesions with heat or cold (C), photodynamic therapies (E), or curettage (H); and in many instances in the Table, statistically significantly so. There are no statistically significant differences among the intervention categories in the former set (namely, [A,B], D, F) or among those in the latter set (namely, C, E, H), but almost universally, the confidence intervals are broad and cannot exclude large differences in the odds of recurrence in either direction.

Table 8 Relative odds ratios for recurrence between intervention categories (all BCC lesions, Figure 7B)

Surgery/MMS (A,B) | 0.13 (0.05, 0.35) | 0.77 (0.21, 2.74) | 0.13 (0.05, 0.36) | 1.09 (0.05, 24.26) | 0.14 (0.03, 0.77)
7.66 (2.85, 20.6) | Heat/cold (C) | 5.87 (2.02, 17.08) | 1 (0.48, 2.08) | 8.33 (0.4, 171.71) | 1.07 (0.23, 5.1)
1.3 (0.36, 4.66) | 0.17 (0.06, 0.5) | Radiation (D) | 0.17 (0.06, 0.51) | 1.42 (0.06, 32.45) | 0.18 (0.03, 1.05)
7.63 (2.79, 20.9) | 1 (0.48, 2.07) | 5.85 (1.98, 17.31) | PDT (E) | 8.3 (0.4, 172.17) | 1.07 (0.22, 5.14)
0.92 (0.04, 20.5) | 0.12 (0.01, 2.48) | 0.71 (0.03, 16.14) | 0.12 (0.01, 2.5) | Drugs (F) | 0.13 (<0.005, 3.6)
7.12 (1.29, 39.21) | 0.93 (0.2, 4.42) | 5.46 (0.95, 31.5) | 0.93 (0.19, 4.48) | 7.75 (0.28, 216.43) | Curettage (H)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

In Table 8, shaded cells correspond comparisons that have been inferred from the analysis model but have not been examined in the included RCTs. For example, comparisons of drugs (F) versus other intervention categories are mostly indirect, and drugs have been compared head-to-head only with radiation (D). Indirect comparisons are more uncertain than those for which head-to-head data exist. The added uncertainty in indirect comparisons is partly reflected in the width of the respective 95 percent confidence intervals, which is (often much) broader for comparisons without direct data. For all comparisons that are empirically observed (all nonshaded cells in the Table), results using only head-to-head data agree well with the results from the network meta-analysis in Table 8 (see Appendix I).

Table 9 offers complementary information from the same analysis; for each intervention category, it shows the mean recurrence rate across the included RCTs. Surgical treatments, radiation, and drugs RCT arms had on average lower recurrence rates (3.1% to 4.4%) compared to photodynamic therapy, curettage, and interventions that destroy lesions with heat or cold, which had average recurrence in the 20 to 23 percent range.

Table 9 Mean and forecasted recurrence rates by intervention category (all BCC lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
Surgery/MMS (A,B) | 3.4 (1.5, 7.6) | 3.4 (0.9, 11.5)
Heat/cold (C) | 21.2 (14.0, 30.7) | 21.2 (8.2, 44.8)
Radiation (D) | 4.4 (1.7, 10.5) | 4.4 (1.2, 15.2)
PDT (E) | 21.1 (13.6, 31.3) | 21.1 (8.0, 45.2)
Drugs (F) | 3.1 (0.2, 39.0) | 3.1 (0.1, 42.8)
Curettage (H) | 20.0 (5.4, 52.2) | 20.0 (4.1, 59.6)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma; CI = confidence interval

#### Comparisons Across Individual Interventions

The results of the analyses of intervention categories are congruent with the corresponding results of the analyses of individual interventions. As evident from Figure 7, there are two connected subgraphs: a smaller one comprising the comparison between surgical treatments (surgical excision or MMS, [A,B]]) and external radiation of brachytherapy (D1|D2), and a larger one with all other interventions. In total, 14 RCTs (1772 lesions) were included in this analysis.^19, 20, 45, 50–52, 67, 70, 71, 81, 85, 90, 104, 105^ They are described in Table 10.

Table 10 Sample information, recurrence (all BCC lesions, individual interventions)

| First subgraph^19, 20, 42, 45, 51, 52, 67, 70, 71, 81, 85, 90, 104, 105^ | Second Subgraph^50^
Studies (total sample) | 13 (1425) | 1 (347)
Total sample by intervention | (A): 475; (E2): 149; (D1): 61; (F2): 15; (C1): 176; (C4): 38; (C3): 25; (H): 20; (B): 77; (E1): 206 (F2); 180; (B+F3): 9; (C5+E1): 16; (C5 + E2): 25 | (A\|B): 174; (D1\|D2): 173
Total sample by intervention, (min, max) | 9, 298 | 173, 174
Data by comparison | (A--E2): 1 (171); (A--C4): 1 (85); (A--C3): 1 (49); (A--H): 1 (44); (A--B): 1 (140); (A--E1): 2 (134); (A—F2): 1 (383); (E2--C1): 1 (83); (D1--F2): 1 (27); (D1--C1): 1 (93); (C1--E1): 1 (193); (C3--H): 1 (45); (B--B+F3): 1 (15); (E1--C5+E1): 1 (32); (E2—C5 + E2): 47 | (A\|B--D1\|D2): 1 (347)
Studies by comparison (min, max) | 1, 2 | 1, 1
Total sample by comparison (min, max) | 15, 193 | 347, 347
Followup median (min, max) | 28 (3, >120) months | 41 (41, 41) months

A = surgical excision; B = Mohs micrographic surgery; BCC = basal cell carcinoma; C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F2 = Imiquimod; H = curettage

Tables 11 and 12 show the relative effects for the larger and smaller subgraphs, respectively. Because the comparisons across individual interventions are sparse, however, the confidence intervals of the odds ratios for most indirect comparisons are very broad and cannot exclude very large differences between the compared interventions.

Table 11 Relative odds ratios for recurrence between individual interventions (all BCC lesions, Figure 7A, first subgraph)

Surgery (A) | 1.04 (0.21, 5.23) | 0.92 (0.04, 23.35) | 0.16 (0.05, 0.5) | 0.71 (0.11, 4.38) | 0.23 (0.07, 0.73) | 0.39 (0.06, 2.33) | 0.09 (0.01, 0.51) | 1.85 (0.34, 10.11) | 0.17 (0.05, 0.52) | 0.11 (0.03, 0.35) | 1.49 (0.06, 37.27) | 0.25 (0.05, 1.17)
0.96 (0.19, 4.82) | MMS (B) | 0.89 (0.03, 25.27) | 0.16 (0.03, 0.85) | 0.68 (0.07, 6.92) | 0.22 (0.03, 1.45) | 0.37 (0.04, 3.34) | 0.08 (0.01, 0.74) | 1.78 (0.21, 14.78) | 0.16 (0.03, 0.88) | 0.1 (0.02, 0.59) | 1.43 (0.05, 45.3) | 0.24 (0.03, 1.97)
1.08 (0.04, 27.38) | 1.13 (0.04, 32.17) | MMS + INF (B+F3) | 0.18 (0.01, 4.31) | 0.77 (0.02, 28) | 0.25 (0.01, 7.05) | 0.42 (0.01, 13.67) | 0.09 (<0.005, 3.04) | 2 (0.06, 62.36) | 0.18 (0.01, 4.41) | 0.12 (<0.005, 2.93) | 1.61 (0.02, 129.86) | 0.27 (0.01, 8.59)
6.14 (2, 18.85) | 6.4 (1.17, 34.91) | 5.67 (0.23, 138.61) | Cryotherapy (C1) | 4.35 (0.63, 30.11) | 1.4 (0.34, 5.84) | 2.36 (0.48, 11.59) | 0.54 (0.1, 2.77) | 11.35 (2.83, 45.48) | 1.01 (0.54, 1.9) | 0.66 (0.28, 1.58) | 9.14 (0.39, 213.14) | 1.51 (0.28, 8.2)
1.41 (0.23, 8.71) | 1.47 (0.14, 14.94) | 1.3 (0.04, 47.52) | 0.23 (0.03, 1.59) | Curettage and Diathermy (C3) | 0.32 (0.04, 2.59) | 0.54 (0.05, 5.92) | 0.12 (0.01, 1.31) | 2.61 (0.26, 26.39) | 0.23 (0.03, 1.63) | 0.15 (0.02, 1.09) | 2.1 (0.06, 75.31) | 0.35 (0.06, 2.13)
4.38 (1.37, 13.94) | 4.56 (0.69, 30.25) | 4.04 (0.14, 115.26) | 0.71 (0.17, 2.97) | 3.1 (0.39, 24.95) | Curettage and Cryotherapy (C4) | 1.69 (0.23, 12.48) | 0.38 (0.05, 2.74) | 8.1 (1.2, 54.76) | 0.72 (0.17, 3.06) | 0.47 (0.11, 2.06) | 6.52 (0.23, 182.96) | 1.08 (0.17, 6.93)
2.6 (0.43, 15.7) | 2.71 (0.3, 24.47) | 2.4 (0.07, 78.64) | 0.42 (0.09, 2.07) | 1.84 (0.17, 20.09) | 0.59 (0.08, 4.39) | Laser + PDT (MAL) (C5+E1) | 0.23 (0.03, 2) | 4.8 (0.61, 37.94) | 0.43 (0.09, 1.94) | 0.28 (0.05, 1.56) | 3.87 (0.12, 122.7) | 0.64 (0.07, 5.76)
11.44 (1.96, 66.7) | 11.92 (1.36, 104.37) | 10.56 (0.33, 339.17) | 1.86 (0.36, 9.61) | 8.11 (0.76, 85.93) | 2.61 (0.36, 18.7) | 4.4 (0.5, 38.73) | Laser + PDT (ALA) (C5+E2) | 21.15 (2.64, 169.72) | 1.89 (0.36, 10.04) | 1.24 (0.25, 6.12) | 17.02 (0.54, 532.11) | 2.82 (0.32, 24.57)
0.54 (0.1, 2.96) | 0.56 (0.07, 4.69) | 0.5 (0.02, 15.54) | 0.09 (0.02, 0.35) | 0.38 (0.04, 3.88) | 0.12 (0.02, 0.84) | 0.21 (0.03, 1.64) | 0.05 (0.01, 0.38) | Radiotherapy (D1) | 0.09 (0.02, 0.39) | 0.06 (0.01, 0.28) | 0.8 (0.03, 21.66) | 0.13 (0.02, 1.1)
6.06 (1.94, 18.94) | 6.31 (1.14, 34.96) | 5.59 (0.23, 137.95) | 0.99 (0.53, 1.85) | 4.29 (0.61, 30.09) | 1.38 (0.33, 5.86) | 2.33 (0.51, 10.58) | 0.53 (0.1, 2.82) | 11.2 (2.53, 49.56) | PDT (MAL) (E1) | 0.65 (0.25, 1.73) | 9.02 (0.38, 213.68) | 1.49 (0.27, 8.21)
9.25 (2.88, 29.69) | 9.64 (1.7, 54.78) | 8.54 (0.34, 214.06) | 1.51 (0.63, 3.59) | 6.56 (0.92, 46.94) | 2.11 (0.49, 9.18) | 3.56 (0.64, 19.83) | 0.81 (0.16, 4.01) | 17.11 (3.53, 82.88) | 1.53 (0.58, 4.04) | PDT (ALA) (E2) | 13.77 (0.57, 333.54) | 2.28 (0.41, 12.84)
0.67 (0.03, 16.82) | 0.7 (0.02, 22.19) | 0.62 (0.01, 49.98) | 0.11 (<0.005, 2.55) | 0.48 (0.01, 17.08) | 0.15 (0.01, 4.31) | 0.26 (0.01, 8.21) | 0.06 (<0.005, 1.84) | 1.24 (0.05, 33.44) | 0.11 (<0.005, 2.63) | 0.07 (<0.005, 1.76) | Imiquimod (F2) | 0.17 (0.01, 5.24)
4.06 (0.85, 19.26) | 4.23 (0.51, 35.17) | 3.75 (0.12, 120.49) | 0.66 (0.12, 3.58) | 2.88 (0.47, 17.63) | 0.93 (0.14, 5.95) | 1.56 (0.17, 14.04) | 0.35 (0.04, 3.09) | 7.5 (0.91, 62.09) | 0.67 (0.12, 3.68) | 0.44 (0.08, 2.47) | 6.04 (0.19, 190.85) | Curettage (H)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

ALA = 5-aminolevulinic acid; BCC = basal cell carcinoma; FU = fluorouracil; INF = interferon; MAL = methyl aminolevulinate; MMS = Mohs micrographic surgery; PDT = photodynamic therapy

Table 12 Relative odds ratios for recurrence between individual interventions (all BCC lesions, Figure 7A, second subgraph)

Surgical excision/MMS (A\|B) | 0.12 (0.01, 0.96)
8.39 (1.04, 67.8) | External radiation/brachytherapy (D1\|D2)

Note: Bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

BCC = basal cell carcinoma; MMS = Mohs micrographic surgery

Table 13 shows, for each intervention, the mean recurrence rates across all RCTs; estimates for interventions in both subgraphs are listed in the table. One cannot compare statistically the estimated recurrence rates between an intervention in the first subgraph (e.g., cryotherapy [C1]) and the second subgraph (e.g., external radiation or brachytherapy [D1|D2]), because they come from disjoint analyses. The mean recurrence rates for individual interventions follow the same pattern as the corresponding recurrence rates for intervention categories. For example, the point estimates for the mean recurrence rate for surgical excision (A), MMS (B), and a combination of MMS and interferon (B+F3) ranged between 4.0 and 4.5 percent; and it was estimated at 3.4 percent for surgical interventions (A,B) in Table 8.

Table 13 Mean recurrence rates by intervention (all BCC lesions)

Intervention Type | MeanPercent (95% CI) | Forecast Percent (95% CI)
First subgraph (Figure 7)
Surgical excision (A) | 4.2 (1.7, 9.7) | 4.2 (0.8, 18.5)
MMS (B) | 4.0 (0.9, 16.4) | 4.0 (0.5, 24.9)
MMS+INF (B+F3) | 4.5 (0.2, 51.4) | 4.5 (0.2, 58.7)
Cryotherapy (C1) | 21.0 (11.6, 35.1) | 21.0 (5.3, 55.7)
Diathermy+curettage (C3) | 5.8 (1.0, 27.2) | 5.8 (0.6, 37.3)
Cryotherapy+curettage (C4) | 15.9 (5.1, 40.0) | 15.9 (2.8, 55.1)
Laser+PDT (MAL) (C5+E1) | 10.1 (2.3, 35.1) | 10.1 (1.4, 47.6)
Laser+PDT (ALA) | 33.1 (9.7, 69.4) | 33.1 (6.0, 79.5)
External radiation (D1) | 2.3 (0.5, 9.1) | 2.3 (0.3, 14.8)
PDT (MAL) (E1) | 20.8 (11.0, 35.7) | 20.8 (5.2, 55.8)
PDT (ALA) (E2) | 28.6 (15.0, 47.6) | 28.6 (7.5, 66.6)
Imiquimod (F2) | 2.8 (0.1, 39.0) | 2.8 (0.1, 46.2)
Curettage (H) | 14.9 (3.6, 45.2) | 14.9 (2.2, 58.2)
Second subgraph (Figure 7)
Surgical excision or Mohs (A\|B) | 0.6 (0.1, 4.0) | NA
External radiation or brachytherapy (D1\|D2) | 4.6 (2.3, 9.0) | NA

ALA = 5-aminolevulinic acid; BCC = basal cell carcinoma; CI = confidence interval; FU = fluorouracil; INF = interferon; MAL = methyl aminolevulinate; MMS = Mohs micrographic surgery; PDT = photodynamic therapy

#### Recurrence, Subgroup Analyses by Lesion Type

We conducted subgroup analyses by the type of BCC lesion. We report analyses comparing intervention categories, but not analyses comparing individual treatments. The latter are very sparse, and their results are very similar to the pertinent comparisons in Tables 9 and 10.

Many subgroup analyses per lesion type are possible; we describe here analyses in RCTs of lower-risk lesions (strata of predominantly [>80%] superficial BCCs, predominantly nodular BCCs, and superficial or nodular BCCs) overall, and broken down by lesion type; and of higher-risk lesions (morpheaform, micronodular, trabecular, infiltrative, or squamous differentiation).

Eleven RCTs (n=1234 lesions) included low risk BCCs (nodular and superficial subtypes). All results about comparisons among intervention categories are the same as in the previous section (Tables 7 and 8).

With respect to RCT strata of predominantly superficial lesions, a single RCT deemed to be at low risk of bias compared cryotherapy (C1, n=93) with PDT with MAL (E1, n=100).^51^ A second RCT, also deemed to be at low risk of bias, compared surgery to drug therapy, in this case Imiquimod.^52^ Results are shown in Tables 14 and 15. Both studies had a followup of 60 months. Briefly, there was no statistically significant difference between the two interventions in ether study, but based on the width of the 95% confidence intervals, one cannot exclude differences in the odds of the outcome as large as 80% in either direction.

Table 14 Relative odds ratios for recurrence between interventions (predominantly superficial BCC lesions)

Heat/cold (C) [Cryotherapy (C1)] | 0.91 (0.46, 1.82)
1.10 (0.55, 2.19) | PDT (E) [PDT (MAL) (E1)]
| | Surgery\|MMS (A\|B) | 0.28 (0.06, 1.35)
| | 3.57 (0.74, 17.26) | Drug (F)

Note: Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT (MAL) = methyl aminolevulinate photodynamic therapy

Table 15 Mean recurrence rates by intervention category (predominantly superficial BCC lesions)

Intervention Type | Mean Recurrence Rate (95% CI)
Subgraph 1 (Figure 7)
Heat/cold (C) [Cryotherapy (C1)] | 20.4 (13.4, 29.8)
PDT (E) [PDT (MAL) (E1)] | 22.0 (14.9, 31.2)
Subgraph 2 (Figure 7)
Surgery\|MMS (A\|B) | 2.1 (0.5, 8.1)
Drug (F) | 7.2 (3.6, 18.8)

Note: Forecasted expected recurrence rates in groups of patients similar to the patients included in the analyzed RCTs are not given, because these results are from a fixed effects analysis

CI = confidence interval; MMS = Mohs micrographic surgery; PDT (MAL) = methyl aminolevulinate photodynamic therapy

Information about the samples for predominantly nodular lesions is in Table 16. The corresponding results are listed in Tables 17 and 18. These results are congruent with the corresponding results from the analyses in Tables 14 and 15.

Table 16 Sample information (predominantly nodular lesions)

| Studies ^20, 45, 52, 67, 70, 85^
Studies (total sample) | 6 (747)
Total sample by intervention | (A,B): 335; (E): 163; (C): 16; (D): 12; (F): 221
Total sample by intervention, (min, max) | 12, 335
Data by comparison | (A,B--E): 3 (305); (E--C): 1 (32); (A—F): 383; (D--F): 1 (27)
Studies by comparison (min, max) | 1, 3
Total sample by comparison (min, max) | 27, 383
Followup median (min, max) | 48 (12, 96)

A = surgical excision; B = Mohs micrographic surgery; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs

Table 17 Relative odds ratios for recurrence between interventions (predominantly nodular BCC lesions)

Surgery\|MMS (A\|B) | 0.04 (<0.005, 0.57) | 0.23 (0.01, 9.06) | 0.04 (0.01, 0.28) | 0.28 (0.03, 3.06)
25.53 (1.74, 374.42) | Heat or Cold (C) | 5.77 (0.11, 295.02) | 1 (0.09, 10.84) | 7.1 (0.45, 111.9)
4.43 (0.11, 177.45) | 0.17 (<0.005, 8.86) | Radiotherapy (D) | 0.17 (0.01, 5.61) | 1.23 (0.03, 52.02)
25.59 (3.61, 181.57) | 1 (0.09, 10.9) | 5.78 (0.18, 187.64) | PDT (E) | 7.12 (0.91, 55.67)
3.6 (0.33, 39.57) | 0.14 (0.01, 2.22) | 0.81 (0.02, 34.36) | 0.14 (0.02, 1.1) | Drug (F)

Note: Results from comparisons in the first and second subgraphs are shown in the upper left and lower right blocks in this Table. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

Table 18 Mean and forecasted recurrence rates by intervention category (predominantly nodular BCC lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
First subgraph (Figure 7)
Surgery/MMS (A,B) | 0.9 (0.2, 4.4) | 0.9 (0.1, 8.8)
Heat/cold (C) | 18.7 (2.7, 66.0) | 18.7 (1.5, 78.1)
Radiation (D) | 3.8 (0.1, 52.2) | 3.8 (0.1, 62.5)
PDT (E) | 18.8 (7.3, 40.4) | 18.8 (3.0, 63.8)
Drugs (F) | 3.1 (0.6, 15.8) | 3.1 (0.3, 27.5)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; Drugs, in this case represents Imiquimod; CI = confidence interval

Finally, with respect to high risk lesions, a single RCT compared surgical excision (A) with MMS (B) in histologically aggressive facial lesions (morpheaform, micronodular, trabecular, infiltrative, or squamous differentiation).^81^ Although the average recurrence rate was smaller in the MMS arm (3.4% [95% CI 1.0% to 11.0%]) versus the surgical excision arm (4.8% [95% CI, 2.5% to 8.8%]), it was not significantly so (odds ratio for surgical excision versus MMS 1.43 [95% CI 0.35 to 5.95]).

#### Recurrence, Other Subgroup Analyses (Lesion Location, Lesion Size)

Table 19 summarizes results from two RCTs by lesion location and size. One RCT comparing surgical excision (A) versus MAL PDT (E) in predominantly nodular lesions^22, 85^ examined subgroups defined by lesion diameter (<=10 mm versus 10 to 20 mm) and found no evidence of effect modification by lesion size at one through 5 years of follow up. Another RCT comparing cryotherapy (C) to radiation therapy (D) in low-risk lesions (mixed superficial and nodular BCCs) found no evidence of effect modification by lesion size (smaller than 10 mm, between 10 and 20 mm, and larger than 20 mm) or location (eyelids, face or neck, and trunk).^71^

Table 19 Subgroup results by lesion size and location for recurrence (BCC lesions)

Study | Comparison | Timepoint | Subgroup | n/N Arm 1 vs. n/N Arm 2 | OR (95% CI); P-Value Within | P-Value Between
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 12 months | lesion diameter: 10–20 mm | 0/14 vs. 1/19 | 0.43 (0.02, 11.23); p=1.00 | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 12 months | lesion diameter: <= 10 mm | 0/34 vs 1/29 | 0.28 (0.01, 7.02); p=0.46 | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 24 months | lesion diameter: 10–20 mm | 0/14 vs. 0/19 | NA | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 24 months | lesion diameter: <= 10 mm | 0/29 vs. 3/29 | 0.13 (0.01, 2.60); p=0.24 | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 36 months | lesion diameter: 10–20 mm | 1/14 vs. 1/19 | 1.38 (0.08, 24.23); p=1.00 | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 36 months | lesion diameter: <= 10 mm | 0/29 vs. 1/29 | 0.32 (0.01, 8.24); p=1.00 | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 48 months | lesion diameter: 10–20 mm | 1/14 vs. 0/19 | 4.33 (0.16, 114.58); p=0.42 | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 48 months | lesion diameter: <= 10 mm | 0/29 vs. 0/29 | NA | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 60 months | lesion diameter: 10–20 mm | 0/14 vs 0/19 | NA | NA
Rhodes 2004 14732655 | Excision (A) vs MAL-PDT (E) | 60 months | lesion diameter: <= 10 mm | 0/29 vs 0/29 | NA | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion location: eyelids | 3/6 vs. 0/3 | 7.00 (0.25, 192.26); p=0.464 | p= 0.97
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion location: face/neck | 12/30 vs. 2/40 | 12.67 (2.56, 62.65); p<0.001 | p= 0.97
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion location: trunk | 2/8 vs. 0/6 | 5.00 (0.20, 125.78); p=0.473 | p= 0.97
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion diameter <10 mm | 6/19 vs. 0/19 | 18.78 (0.97, 362.00); p=0.020 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion diameter 10–20 mm | 9/23 vs. 2/25 | 7.39 (1.39, 39.27); p=0.016 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion diameter >20 mm | 2/2 vs. 0/5 | 55.00 (0.83, 3650.69); p=0.048 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 24 months | Lesion location: eyelids | 3/6 vs. 0/3 | 7.00 (0.25, 192.26); p=0.464 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 24 months | Lesion location: face/neck | 12/30 vs. 2/40 | 12.67 (2.56, 62.65); p<0.001 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 24 months | Lesion location: trunk | 2/8 vs. 0/6 | 5.00 (0.20, 125.78); p=0.473 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion diameter <10 mm | 6/19 vs. 0/19 | 18.78 (0.97, 362.00) p=0.020 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion diameter 10–20 mm | 9/23 vs. 2/25 | 7.39 (1.39, 39.27); p=0.016 | NA
Hall 1986 3514075 | Cryotherapy (E) vs Radiation (D) therapy | 12 months | Lesion diameter >20 mm | 2/2 vs. 0/5 | 55.00 (0.83, 3650.69); p=0.048 | NA

NA = not significant; PDT = photodynamic therapy; MAL = methyl aminolevulinate; OR = odds ratio; CI = confidence interval

#### Recurrence, Results From Nonrandomized Studies (BCC Lesions)

Two NRCSs reported on recurrence in populations with only BCC lesions. The first included 74 patients and reported on a matched population of 94 superficial (64%) and nodular (36%) BCCs 25 months after treatment. The study was rated as having a moderate risk of confounding bias because of lack of blinding, and unclear reporting. The mean age at baseline was 66 (range: 49 to 90), 47 percent of the population was female. Recurrence was similar across groups (4.2% in the ALA-PDT group vs. 4.3% in the surgical excision group; OR: 0.96 [95% CI 0.13 to 7.09]).^148^ The second reported recurrence in 621 people (47% female) with BCC lesions (38.5% superficial, 17% nodular, and 44.5% infiltrative, micronodular, morpheaform, or sclerosing). This study was judged to have a high risk of confounding and selection bias because of lack of blinding, unclear distribution of dropouts, unclear results reporting, and uneven groups at baseline that were not accounted for in the analysis. Surgical excision had a higher rate of recurrence up to 5 years compared to Imiquimod (HR 2.13; 95% CI 1.28 to 3.53).^149^

Two NRCS reported on recurrence in populations with both BCCs and SCC lesions. One reported on 1174 patients with 1488 lesions selected from a private, university-affiliated clinic and a nearby Veterans Affairs clinic. This study was deemed to have a low risk of bias, with balanced groups, consecutive recruitment, blinding of outcome assessors, and adequate accounting for people lost to followup. Most (75%) of the lesions were BCCs; the other 25 percent were SCCs; 26 percent were female, 40 percent had a Fitzpatrick skin score of I or II, and 3 percent were immunocompromised due to prior solid-organ transplant. The lesions were treated by Mohs surgery (246; 65% in the H-zone of the face), surgical excision (251; 26% in H-zone of the face), and electrodessication and curettage (ED&C) (136; 11% in H-zone of the face). ED&C had the highest rate of recurrence after 5 years (4.9%), then excision (3.5%), and finally Mohs (2.1%). In a subsample of 240 pairs of tumors matched on propensity score, the difference in hazard of recurrence between Mohs and excision was not statistically significant (0.61; 95% CI 0.3, 1.24).^142, 144–147^ A secondary analysis limited to 1483 lesions judged appropriate for Mohs surgery reported a similar nonsignificant 5-year adjusted hazard ratio for recurrence (0.6; 95% CI 0.3, 1.0),^156^ The second NRCS reported on two doses and schedules of orthovoltage radiotherapy. The population consisted of 436 lesions in 385 elderly people, with BCCs (71%) and SCCs (29%). The mean age was 78, and 42 percent were female. A lower dose of radiation (3675 cGy) had a nonsignificantly higher recurrence rate than the higher dose (4500 cGy) (HR: 0.483; 95% CI 0.065 to 3.58).^151^

### Lack of Histologic Clearance (All BCC Lesions)

The evidence graph for lack of histologic clearance with respect to individual treatments is sparse (Figure 6 (B) – reproduced in Figure 8 (A) for ease of reference) and comprises 5 connected subgraphs. Detailed results at the RCT-level are in Appendix I.

Figure 8 Evidence graph of RCTs evaluating lack of histological clearance in BCCs across (A) individual interventions and (B) types of interventions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 8. (A) This is the topology map of the network meta-analysis of the interventions for lack of histological clearance for all BCCs compared in 15 RCTs. Twenty interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, laser), PDT (MAL or ALA), drugs (imiquimod, 5-FU, ingenol, and other), and placebo or no treatment; or combinations of interventions (imiquimod and Mohs, imiquimod and curettage, MAL PDT and laster, and combinations of excision plus MAL or ALA PDT with or without curettage). Fourteen of these interventions are connected in the primary graph, with only MAL PDT connected to more than three others; most were connected to only one or two. MAL PDT was connected to MAL PDT plus laser, excision, 5-FU, imiquimod, and placebo. There are also three subgraphs: One connects curettage to imiquimod and curettage; the second connects Mohs surgery to imiquimid plus Mohs; and the third connects combinations of excision plus MAL or ALA PDT, with or without curettage. (B) This is the coarse topology map of the network meta-analysis of the different types of interventions for lack of histological clearance for all BCCs compared in 15 RCTs. The five intervention types include surgical, thermodynamic, PDT, medical/drugs, and curettage). Of the 10 possible pairwise comparisons, 7 are covered by direct study comparisons as indicated by lines between the treatment circles.

#### Comparisons Across Intervention Categories

In total, 15 RCTs (1940 lesions) were included in this analysis.^45, 49, 54, 55, 64, 66, 68–70, 92–94, 99, 101, 104^ Twelve RCTs were deemed to be at low or moderate risk of bias. Cumulative sample sizes per comparison ranged from 44 to 1196; for more details see Table 20.

Table 20 Sample information, lack of histological clearance (all BCC lesions, intervention categories)

Studies (total sample) | 15 (1940)
Total sample by intervention | (F): 825; (I,J): 607; (A,B): 83; (C): 131; (E): 294
Total sample by intervention, (min, max) | 83, 825
Data by comparison | (F--I,J): 7 (1196); (F--E): 1 (271); (I,J--C): 2 (44); (I,J--E): 1 (150); (A,B--C): 1 (96); (A,B--E): 1 (68); (C--E): 2 (115)
Studies by comparison (min, max) | 1, 7
Total sample by comparison (min, max) | 44, 1196
Followup median (min, max) | 3 (1.5, 36) months

A = surgical excision; B = Mohs micrographic surgery; BCC = basal cell carcinoma; C = heat/cold; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 21 shows the relative odds ratios for lack of histologic clearance across intervention categories. Overall, surgical treatments (A,B) were statistically significantly better than any other intervention category in terms of histological clearance. No or sham treatment (I,J) was statistically significantly worse that all other treatments. Among the other intervention categories, the odds ratios favor PDT (E) over interventions that destroy lesions with heat or cold (C), and the latter (C) over drugs (F), but these differences are not statistically significant. Further, the confidence intervals for the comparisons between the latter three treatments are broad and cannot exclude large effects in either direction.

Table 21 Relative odds ratios for lack of histologic clearance between intervention categories (all BCC lesions, Figure 8B)

Surgery/MMS (A,B) | 0.04 (<0.005, 0.77) | 0.05 (<0.005, 1.03) | 0.02 (<0.005, 0.41) | <0.005 (<0.005, 0.04)
27.5 (1.3, 579.51) | Heat/cold (C) | 1.36 (0.22, 8.45) | 0.6 (0.11, 3.16) | 0.07 (0.01, 0.34)
20.11 (0.97, 418.64) | 0.73 (0.12, 4.54) | PDT (E) | 0.44 (0.09, 2.25) | 0.05 (0.01, 0.24)
45.91 (2.42, 870.68) | 1.67 (0.32, 8.83) | 2.28 (0.44, 11.74) | Drugs (F) | 0.11 (0.03, 0.45)
418.6 (22.48, 7793.78) | 15.25 (2.98, 77.94) | 20.81 (4.18, 103.57) | 9.12 (2.2, 37.76) | No/sham treatment (I,J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

In the table, shaded cells correspond to comparisons that have been inferred from the analysis model, but that have not been examined in the included RCTs. For example, comparisons of surgical treatments (A,B) or interventions that destroy lesions with heat or cold (C) versus drugs (F) or placebo (I,J) are indirect, through PDT (E) as the common comparator. Indirect comparisons are more uncertain that those for which head-to-head data exist. The added uncertainty in the indirect comparisons is partly reflected in the width of the respective 95 percent confidence intervals, which is (often much) broader for comparisons without versus with direct data. For all comparisons that have been empirically observed (all nonshaded cells in the table), results using only head-to-head data agree well with the results from the network meta-analysis in Table 17 (see Appendix I).

Table 22 offers complementary information from the same analysis. For each intervention category, it shows the mean fraction of lesions without histologic clearance across the included RCTs. It also forecasts the expected fractions with lack of histologic clearance in each intervention category in groups of patients similar to the patients included in the analyzed RCTs. The average number of lesions with no histological clearance was 1.2 percent in the surgery arms, between 19.5 and 35.6 percent in other active intervention categories, and 83.5 percent for no or sham (placebo) treatment.

Table 22 Mean and forecasted lack of histologic clearance fractions by intervention category (all BCC lesions)

Intervention Type | Mean Lack of Histological Clearance Fraction Percent (95% CI) | Forecasted Lack of Histological Clearance Fraction Percent (95% CI)
Surgery/MMS (A,B) | 1.2 (0.1, 15.9) | 1.2 (<0.5, 36.7)
Heat/cold (C) | 24.9 (8.2, 55.0) | 24.9 (1.6, 87.1)
PDT (E) | 19.5 (6.4, 46.4) | 19.5 (1.2, 83.0)
Drugs (F) | 35.6 (16.5, 60.8) | 35.6 (2.9, 91.0)
No/sham treatment (I,J) | 83.5 (65.5, 93.1) | 83.5 (21.8, 98.9)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; CI = confidence interval

#### Comparisons Across Individual Interventions

The results of the analyses of individual interventions are congruent with the analyses intervention categories are congruent with the corresponding results. As is evident from Figure 8, there are five connected subgraphs. Separate analyses are conducted for each connected subgraph. In total, 19 RCTs (2170 lesions) were included in these analyses, as summarized in the Table 23

Table 23 Sample information, lack of histological clearance (all BCC lesions, individual interventions)

| First subgraph^45, 49, 54, 66, 68–70, 92–94, 99, 104^ | Second subgraph^73^ | Third subgraph^55, 64, 101^ | Fourth subgraph^96^ | Fifth subgraph^56, 100^
Studies (total sample) | 12 (2010) | 1 (43) | 3 (76) | 1 (20) | 2 (97)
Total sample by intervention | (F2): 761; (J): 575; (A): 83; (C1): 87; (E2): 44; (E1): 250; (F1): 146; (F4): 48; (C5+E1): 16 | (A+E1): 11; (A+E1+H): 10; (A+E2): 11; (A+E2+H): 11 | (C5): 28; (I): 32; (F5): 16 | (F2+H): 10; (H): 10 | (B): 50; (B+F2): 47
Total sample by intervention, (min, max) | 16, 761 | 10, 11 | 16, 32 | 10, 10 | 47, 50
Data by comparison | (F2--J): 5 (1110); (F2--E1): 1 (271); (F2--F1): 1 (291); (J--E1): 1 (150); (J--F4): 1 (54); (A--C1): 1 (96); (A--E1): 1 (68); (C1--E2): 1 (83); (E1--F1): 1 (272); (E1--C5+E1): 1 (32) | (A+E1--A+E1+H): 1 (21); (A+E1--A+E2): 1 (22); (A+E1--A+E2+H): 1 (22); (A+E1+H--A+E2): 1 (21); (A+E1+H--A+E2+H): 1 (21); (A+E2--A+E2+H): 1 (22) | (C5--I): 2 (44); (I--F5): 1 (32) | (F2+H--H): 1 (20) | (B--B+F2): 2 (97)
Studies by comparison (min, max) | 1, 5 | 1, 1 | 1, 2 | 1, 1 | 2, 2
Total sample by comparison (min, max) | 32, 1110 | 21, 22 | 32, 44 | 20, 20 | 97, 97
Followup median (min, max) | 3 (3, 36) months | 2.5 (2.5, 2.5) months | 2 (1.5, 2) months | 2 (2, 2) months | 1.5 (0.5, 2.5) months

A = surgical excision; B = Mohs micrographic surgery; BCC = basal cell carcinoma; C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; C5 = laser; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F1 = 5-FU; F2 = Imiquimod; F4 = Ingenol; H = curettage; J = placebo

Table 24 has results on the relative effects for the largest subgraph. Table 25 has the corresponding results for the other subgraphs: the one for the comparison of surgical excision with PDT with MAL or ALA, with or without curettage (A+E1 versus A+E2 versus, A+E1+H versus A+E2+H); and the one for the comparison between laser ablation (C5) versus diclofenac and/or calcitriol (other medication – F5) and versus no treatment (I). Table 26 shows the relative effects for the last two subgraphs, namely the one for the comparison between curettage alone (H) versus curettage and imiquimod (H+F2); and the one for the comparison between MMS (B) and MMS with imiquimod (B+F2). In all three tables, comparisons across individual observations are sparse. The confidence intervals of the odds ratios for most indirect comparisons are very broad and cannot exclude very large differences between the compared interventions. The exception is for comparisons between surgical treatments and no intervention, which are statistically significant despite the wide confidence interval, because the relative effect is very large.

Table 24 Relative odds ratios for lack of histological clearance between individual interventions (all BCC lesions, Figure 8A, largest subgraph)

(A) Surgery | 0.11 (<0.005, 3.3) | 0.02 (<0.005, 1.08) | 0.05 (<0.005, 1.19) | 0.04 (<0.005, 1.81) | 0.21 (<0.005, 10.47) | 0.04 (<0.005, 0.83) | <0.005 (<0.005, 0.18) | <0.005 (<0.005, 0.05)
9.31 (0.3, 285.72) | (C1) Cryotherapy | 0.19 (0.01, 6.43) | 0.5 (0.04, 6.05) | 0.34 (0.01, 10.68) | 1.93 (0.06, 61.81) | 0.39 (0.04, 4.11) | 0.03 (<0.005, 1.06) | 0.02 (<0.005, 0.23)
49.8 (0.93, 2678.92) | 5.35 (0.16, 184.09) | (C5+E1) Laser + PDT (MAL) | 2.69 (0.11, 67.1) | 1.8 (0.03, 99.7) | 10.35 (0.19, 576.29) | 2.1 (0.09, 47.08) | 0.18 (<0.005, 9.86) | 0.12 (0.01, 2.66)
18.52 (0.84, 407.72) | 1.99 (0.17, 23.98) | 0.37 (0.01, 9.28) | (E1) PDT (MAL) | 0.67 (0.03, 15.3) | 3.85 (0.17, 88.57) | 0.78 (0.13, 4.86) | 0.07 (<0.005, 1.51) | 0.04 (0.01, 0.27)
27.67 (0.55, 1386.65) | 2.97 (0.09, 94.42) | 0.56 (0.01, 30.77) | 1.49 (0.07, 34.14) | (E2) PDT (ALA) | 5.75 (0.11, 298.48) | 1.17 (0.06, 23.88) | 0.1 (<0.005, 5.11) | 0.07 (<0.005, 1.35)
4.81 (0.1, 242.47) | 0.52 (0.02, 16.52) | 0.1 (<0.005, 5.38) | 0.26 (0.01, 5.98) | 0.17 (<0.005, 9.03) | (F1) 5-FU | 0.2 (0.01, 4.18) | 0.02 (<0.005, 0.89) | 0.01 (<0.005, 0.24)
23.66 (1.2, 464.54) | 2.54 (0.24, 26.54) | 0.48 (0.02, 10.63) | 1.28 (0.21, 7.93) | 0.86 (0.04, 17.46) | 4.92 (0.24, 101.09) | (F2) Imiquimod | 0.08 (<0.005, 1.73) | 0.06 (0.01, 0.28)
279.18 (5.58, 13970.12) | 30 (0.95, 951.08) | 5.61 (0.1, 310.02) | 15.07 (0.66, 343.77) | 10.09 (0.2, 520.18) | 58.02 (1.12, 3007.15) | 11.8 (0.58, 240.42) | (F4) Ingenol | 0.67 (0.03, 13.6)
414.45 (21.31, 8061.19) | 44.53 (4.32, 459.3) | 8.32 0.38, 184.46) | 22.38 (3.66, 136.75) | 14.98 (0.74, 302.98) | 86.14 (4.23, 1754.46) | 17.52 (3.51, 87.41) | 1.48 (0.07, 29.96) | (J) Placebo/sham

PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, BCC=basal cell carcinoma. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

Table 25 Relative odds ratios for lack of histological clearance between individual interventions (all BCC lesions, Figure 8, other subgraphs)

(A_plus_E1) Surgery + PDT (MAL) | 2.29 (0.32, 16.51) | 1 (0.18, 5.68) | 2.57 (0.36, 18.33)
0.44 (0.06, 3.16) | (A_plus_E1_plus_H) Surgery + PDT (MAL) + curettage | 0.44 (0.06, 3.16) | 1.13 (0.13, 9.94)
1 (0.18, 5.68) | 2.29 (0.32, 16.51) | (A_plus_E2) Surgery + PDT (MAL) | 2.57 (0.36, 18.33)
0.39 (0.05, 2.77) | 0.89 (0.1, 7.86) | 0.39 (0.05, 2.77) | (A_plus_E2_plus_H) Surgery + PDT (MAL) + curettage
| | | | (C5) laser | 0.02 (<0.005, 0.56) | 0.17 (0.03, 0.9)
| | | | 43.95 (1.77, 1090.16) | (F5) Other medical | 7.49 (0.29, 196.65)
| | | | 5.87 (1.11, 31.13) | 0.13 (0.01, 3.51) | (I) No treatment

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; BCC = basal cell carcinoma

Table 26 Relative odds ratios for lack of histological clearance between individual interventions (all BCC lesions, Figure 8A, 2 more subgraphs)

(F2_plus_H) Imiquimod + curettage | 0.17 (0.01, 1.88)
6.00 (0.53, 67.65) | Curettage (H)
| | MMS (B) | 11.11 (2.66, 46.36)
| | 0.09 (0.02, 0.38) | (B_plus_F2) MMS + imiquimod

Note: Results are given as odds ratios (95% confidence intervals). Bold-italic indicates statistical significance.

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; BCC = basal cell carcinoma

Table 27 shows, for each intervention, the mean fractions for lack of histologic clearance across all RCTs. Estimates for interventions in all five subgraphs are listed in the table. One should not compare statistically these fractions across the subgraphs, because they come from disjoint analyses. In general, the mean fractions for lack of histologic clearance for individual interventions are in congruence with the corresponding fractions estimated for intervention categories. For example, in the first subgraph, the average recurrence rates for PDT with MAL (E1) and ALA (E2) were 18.2 percent (95% CI 5.1 to 48.0) and 25.0 percent (95% CI 2.0 to 84.0), respectively, and the corresponding result from the analysis between intervention categories was 19.5 percent (95% CI 6.4 to 46.4). The mean number of lesions with no histological clearance for the three medical interventions, namely 5-FU (F1), imiquimod (F2), and ingenol (F4), ranged between 5.5 and 77.1 percent, but the respective confidence intervals were very wide, and the corresponding odds ratios in Table 24 were not statistically significant.

Table 27 Mean and forecasted lack of histological clearance fractions by intervention category (all BCC lesions)

Intervention Type | Mean Lack of Histological Clearance Fraction (95% CI) | Forecasted Lack of Histological Clearance Fraction (95% CI)
First subgraph
Surgical excision (A) | 1.2 (0.1, 15.8) | 1.2 (<0.5, 36.3)
Cryotherapy (C1) | 10.1 (1.4, 46.4) | 10.1 (0.4, 76.9)
Laser (C5+E1) + PDT (MAL) | 37.5 (3.2, 91.5) | 37.5 (1.1, 96.9)
PDT (MAL) (E1) | 18.2 (5.1, 48.0) | 18.2 (1.0, 82.5)
PDT (ALA) (E2) | 25.0 (2.0, 84.4) | 25.0 (0.7, 94.2)
5-FU (F1) | 5.5 (0.4, 48.7) | 5.5 (0.1, 73.9)
Imiquimod (F2) | 22.2 (8.3, 47.3) | 22.2 (1.5, 84.3)
Ingenol (F4) | 77.1 (17.2, 98.2) | 77.1 (6.5, 99.4)
Placebo (J) | 83.3 (61.9, 93.9) | 83.3 (21.1, 98.9)
Second subgraph
Surgery + PDT (MAL) (A+E1) | 36.4 (14.3, 66.1) | NA
Surgery + PDT (MAL) + curettage (A+E1+H) | 20.0 (5.0, 54.1) | NA
Surgery + PDT (ALA) (A+E2) | 36.4 (14.3, 66.1) | NA
Surgery + PDT (ALA) + curettage (A+E2+H) | 18.2 (4.6, 50.7) | NA
Third subgraph
Laser (C5) | 43.5 (26.1, 62.8) | NA
Other medical (diclofenac and/or calcitriol) (F5) | 97.1 (66.4 99.8) | NA
No treatment (J) | 80.5 (58.8, 92.2) | NA
Fourth subgraph
Imiquimod + curettage (F2+H) | 10.0 (1.4, 46.7) | NA
Curettage (H) | 40.0 (15.8, 70.3) | NA
Fifth subgraph
MMS (B) | 92.0 (75.8, 97.7) | NA
MMS + imiquimod (B+F2) | 51.0 (37.0, 64.9) | NA

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; BCC = basal cell carcinoma; CI = confidence interval; NA=forecasts are not available for the 4 smaller subgraphs, because they were analyzed with a fixed effects model

#### Incomplete Excision, All BCC Lesions

Two RCTs reported incomplete excision outcomes in mixed BCC populations. In the first study, the average age was 68 (SD 12), and 39.7 percent were female. The average lesion size was 1.28 cm^2^ (SD 1.36) in the group randomized to receive Mohs surgery (n=198) and 1.77 cm^2^ (SD 1.28) in the surgical excision without intraoperative evaluation group (n=199). In this study, about half of the BCCs were classified as aggressive. After the first excision, 35 of 199 lesions (17.6%) were found to have been incompletely excised in the surgical excision without intraoperative margin assessment group; whereas none were found in the Mohs surgery group (0/198). Thirty-one of the lesions in the excision group were reexcised and of these four were found to have been incompletely excised (12.9%). In the aggressive lesions, the incomplete excision rate was 21 of 88 (23.9%) in the surgical excision group; none in the Mohs group (n=105).^81^

The second RCT reported incomplete excision and number of repeat procedures in people who had either surgical excision without intraoperative assessment of the margins or curettage and cryosurgery for BCCs on their face (90%) or trunk/neck (10%). The mean age was 67 (range 34 to 92), and 43 percent were women. In the curettage and cryosurgery group there were 51 lesions, all nodular, with an average diameter of 5.4 mm (SD 2.9). In the surgical excision arm, there were 49 lesions, 92 percent nodular and 8 percent superficial, with an average diameter of 5.3 mm (SD 2.6). There were no incomplete excisions in the curettage and cryosurgery group; and there were three in the surgical excision group (6%). There were no repeat procedures in the curettage and cryosurgery group and four in the surgical excision group.^19^

#### Lack of Histological Clearance, Subgroup Analyses by Lesion Type

We conducted subgroup analyses by the type of BCC lesion. We report analyses comparing groups of interventions, but not analyses comparing individual treatments. The latter are very sparse, and their results are very similar to the pertinent comparisons in Tables 24, 25, and 26.

Many subgroup analyses per lesion type are possible. In this section, we describe analyses in RCTs of lower-risk lesions (strata of predominantly [>80%] superficial BCCs, predominantly nodular BCCs, and superficial or nodular BCCs) overall, and broken down by lesion type, as well as higher-risk lesions (morpheaform, micronodular, trabecular, infiltrative, or squamous differentiation).

Fifteen RCTs (n=1972 lesions) included low-risk BCCs (nodular and superficial subtypes).^45, 49, 54, 55, 64, 66, 68–70, 92–94, 99, 101, 104^ Their results are very similar to the findings in Tables 22 and 23 in the previous section.

With respect to RCT strata of predominantly superficial lesions, six RCTs (n=1300 lesions) compared PDT (E) versus drugs (F) versus no or sham treatment.^49, 55, 68, 69, 92, 94^ Table 28 provides details about the comparisons between these six RCTs. The results are shown in Tables 29 and 30. Briefly, there was no statistically significant difference between the two active intervention categories, but both were statistically significantly better than no or sham treatment.

Table 28 Sample information, lack of histological clearance (superficial lesions)

Studies (total sample) | 6 (1300)
Total sample by intervention | (E): 126; (F): 693; (I,J): 481
Total sample by intervention, (min, max) | 126, 693
Data by comparison | (E--F): 1 (271); (F--I,J): 5 (1029)
Studies by comparison (min, max) | 1, 5
Total sample by comparison (min, max) | 271, 1029
Followup median (min, max) | 3 (2, 36) months

A = surgical excision; B = Mohs micrographic surgery; C = heat/cold; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 29 Relative odds ratios for lack of histological clearance between intervention categories (predominantly superficial BCC lesions)

PDT (E) | 0.19 (<0.005, 9.84) | 0.01 (<0.005, 0.36)
5.17 (0.1, 263.01) | Drugs (F) | 0.03 (<0.005, 0.36)
150.98 (2.78, 8187.95) | 29.21 (2.81, 303.6) | No/sham treatment (I,J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

PDT = photodynamic therapy; BCC = basal cell carcinoma

Table 30 Mean fraction of lesions without histological clearance by intervention category (predominantly superficial BCC lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
PDT (E) | 7.9 (0.2, 75.9) | 7.9 (0.1, 93.1)
Drugs (F) | 30.8 (8.4, 68.3) | 30.8 (0.9, 95.6)
No/sham treatment (I,J) | 92.9 (69.8, 98.7) | 92.9 (20.2, 99.9)

PDT = photodynamic therapy; BCC = basal cell carcinoma; CI = confidence interval

With respect to the five RCT strata of predominantly nodular lesions (n=374),^45, 55, 66, 70, 93^ details on the comparisons are in Table 31. The corresponding results are listed in Tables 32 and 33. These results are qualitatively similar to the corresponding results from the analyses in Tables 22 and 23.

Table 31 Sample information, lack of histological clearance (nodular lesions)

Studies (total sample) | 5 (374)
Total sample by intervention | (F): 84; (I,J): 115; (A,B): 35; (E): 124; (C): 16
Total sample by intervention, (min, max) | 16, 124
Data by comparison | (F--I,J): 2 (124); (I,J--E): 1 (150); (A,B--E): 1 (68); (E--C): 1 (32)
Studies by comparison (min, max) | 1, 2
Total sample by comparison (min, max) | 32, 150
Followup median (min, max) | 3 (2, 12) months

A = surgical excision; B = Mohs micrographic surgery; C = heat/cold; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 32 Relative odds ratios for lack of histological clearance between intervention categories (nodular BCC lesions)

Surgery/MMS (A,B) | 0.02 (<0.005, 1.48) | 0.04 (<0.005, 1.79) | 0.01 (<0.005, 0.44) | <0.005 (<0.005, 0.14)
42.6 (0.67, 2692.89) | Heat/cold (C) | 1.9 (0.14, 26.18) | 0.39 (0.02, 6.78) | 0.14 (0.01, 1.99)
22.45 (0.56, 903.83) | 0.53 (0.04, 7.27) | PDT (E) | 0.21 (0.02, 1.76) | 0.08 (0.01, 0.48)
108.35 (2.29, 5127.73) | 2.54 (0.15, 43.87) | 4.83 (0.57, 40.95) | Drugs (F) | 0.36 (0.04, 3.13)
298.54 (7.35, 12122.67) | 7.01 (0.5, 97.88) | 13.3 (2.1, 84.38) | 2.76 (0.32, 23.73) | No/sham treatment (I,J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma.

Table 33 Mean and forecasted lack of histological clearance fractions by intervention category (nodular BCC lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
Surgery/MMS (A,B) | 1.4 (<0.5, 31.0) | 1.4 (<0.5, 44.0)
Heat/cold (C) | 37.5 (5.8, 85.5) | 37.5 (2.7, 92.8)
PDT (E) | 24.0 (8.0, 53.6) | 24.0 (2.7, 78.1)
Drugs (F) | 60.4 (21.8, 89.3) | 60.4 (9.6, 95.6)
No/sham treatment (I,J) | 80.8 (52.9, 94.0) | 80.8 (26.9, 98.0)

MMS= Mohs micrographic surgery; PDT=photodynamic therapy; BCC=basal cell carcinoma; CI=confidence interval

##### Incomplete Excision (a Related Outcome) in High-Risk BCCs

We identified one RCT that measured the distinct, yet related, outcome of incomplete excision in 172 lesions, about half of which were on the face, the rest were elsewhere on the body. This study compared surgical excision (A) with MMS (B) in histologically aggressive facial lesions (morpheaform, micronodular, trabecular, infiltrative, or squamous differentiation). The average age was 65 years (standard deviation 13), and 43.3 percent were female. The average lesion diameter was 9.1 mm (standard deviation 4.1). In the 88 lesions that had surgical excision without intraoperative margin assessment, two had an incomplete excision. This outcome was not applicable to the other arm of the study (ALA-PDT).^20^

#### Lack of Histological Clearance, Other Subgroup Analyses (Lesion Location, Lesion Size, Sex, Age)

Table 34 shows results on subgroup analyses for two RCTs that reported treatment effects in subgroups of interest. The first RCT enrolled patients with predominantly superficial BCCs and found significant differences in treatment effects across a number of subgroups that include age, gender, lesion location, and lesion size.^49, 87, 88^ The second RCT reported subgroup results for lack of histological clearance in predominantly nodular BCC. There was no significant difference between or within subgroups based on lesion location or size.^66^

Table 34 Subgroup results for lack of histological clearance in superficial BCCs

Study | Comparison | Timepoint | Subgroup | n/N Arm 1 vs. n/N Arm 2 | OR (95% CI); P-Value Within | P- Value Between
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | age: <= 60 years old | 25/81 vs. 8/77 | 3.85 (1.61, 9.20); p=0.002 | p=0.032
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | age: > 60 years old | 27/115 vs. 23/112 | 1.19 (0.63, 2.23); p=0.633 | p=0.032
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | females | 29/103 vs. 9/92 | 3.61 (1.61, 8.13); p=0.002 | p=0.029
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | males | 23/93 vs. 22/97 | 1.12 (0.57, 2.19); p=0.865 | p=0.029
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | lesion location: head/neck | 9/24 vs. 4/20 | 2.40 (0.61, 9.47); p=0.321 | p=0.047
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | lesion location: trunk | 36/115 vs. 12/116 | 3.95 (1.93, 8.08); p<0.001 | p=0.047
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | lesion location: lower extremities | 2/26 vs. 6/28 | 0.31 (0.06, 1.68); p=0.253 | p=0.047
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | lesion location: upper extremities | 5/31 vs. 3/25 | 1.41 (0.30, 6.58); p=0.720 | p=0.047
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | lesion area: <= 60 mm2 | 23/106 vs. 18/90 | 1.11 (0.55, 2.22); p=0.861 | p=0.043
Arits 2013 23683751 | PDT (MAL) (E1) vs. Imiquimod (F2) | 12 months | lesion area: > 60 mm2 | 27/86 vs. 12/96 | 3.20 (1.50, 6.83); p=0.002 | p=0.043
Foley 2009 20064185 | PDT (MAL) (E1) vs. sham PDT (J) | 3 months | lesion location: extremities | 5/15 vs. 12/17 | 0.21 (0.05, 0.93); p=0.074 | p=0.437
Foley 2009 20064185 | PDT (MAL) (E1) vs. sham PDT (J) | 3 months | lesion location: face/scalp | 3/19 vs. 18/23 | 0.05 (0.01, 0.25); p<0.001 | p=0.437
Foley 2009 20064185 | PDT (MAL) (E1) vs. sham PDT (J) | 3 months | lesion location: neck | 4/9 vs. 1/1 | 0.27 (0.01, 8.46); p=1.000 | p=0.437
Foley 2009 20064185 | PDT (MAL) (E1) vs. sham PDT (J) | 3 months | lesion location: trunk | 8/32 vs. 24/34 | 0.14 (0.05, 0.41); p<0.001 | p=0.437
Foley 2009 20064185 | PDT (MAL) (E1) vs. sham PDT (J) | 3 months | lesion diameter: <10 mm | 15/64 vs. 43/61 | 0.13 (0.06, 0.28); p<0.001 | p=0.939
Foley 2009 20064185 | PDT (MAL) (E1) vs. sham PDT (J) | 3 months | lesion diameter: 10–20 mm | 5/11 vs. 12/14 | 0.14 (0.02, 0.94); p=0.081 | p=0.939

NA = not significant; PDT = photodynamic therapy; BCC = basal cell carcinoma; MAL = methyl aminolevulinate; OR = odds ratio; CI = confidence interval

#### Lack of Histological Clearance, Results From Nonrandomized Studies (BCC Lesions)

We identified six NRCSs reporting lack of histological clearance in BCC or mixed BCC and SCC lesions.^143, 150–154^ These are summarized narratively below.

The first NRCS included 12 patients with one superficial BCC each. After an initial excision surgery, six patients received imiquimod and six received placebo. The study was deemed to be at a high risk of confounding bias, because the arms were not balanced (there were only six patients per arm); both the dermatologist and pathologist were blinded, and the study followed all participants to the end. The mean lesion area was 52 mm^2^, and the lesions were located on the trunk or neck (67%) or forearm (33%). The mean age was 61 (range 52 to 78), and 33 percent were female. All lesions in the vehicle group had residual tumor at excision, as did four of the six treated with imiquimod.^154^

The second NRCS reported lack of clinical and histological clearance in 74 patients with one nodular BCC each, receiving different doses of vismodegib. The risk of bias of this study was judged to be moderate because of lack of blinding and inadequate baselines reporting that lead to ambiguity about how well balanced the arms were. The lesion diameter ranged from 1 to 3 cm, and all were located in the scalp, head, neck, trunk, or limbs. The mean age was 63.6 (SD 12; range 40 to 89), and 22 percent were female; 99 percent were white. Twenty-four lesions were treated with vismodegib for 12 weeks then were excised; twenty-five were treated with vismodegib for 12 weeks then had a 24-week observation period before excision; and 25 were treated with vismodegib for 16 weeks then were excised. The 12-week groups had a much higher and statistically significant rate of lack of clinical clearance than the 16-week group (OR 10.42; 95% CI 1.22 to 89.13). However, the lack of histological clearance was much closer between the two doses, and not significant (OR 1.57; 95% CI 0.49 to 5.01).^153^

The third NRCS reported on lack of histological clearance in 56 people with 56 nodular BCCs, who received ALA-PDT with or without surface preparation with a CO2 laser. This study was judged to have moderate to low risk of bias, primarily because of lack of blinding. The mean age was 62, and 43 percent were females. Most of the lesions (87.5%) were on the head (not H-zone or adjacent to the eyes or ears) or neck. The group with the surface preparation had a lower rate of lack of histological clearance than the group without surface preparation (OR 0.23; 95% CI 0.07 to 0.75).^150^

The fourth NRCS reported on a matched population of 40 patients treated with different doses of brachytherapy (36.6 versus 42 Gy). This study was deemed to be at a moderate risk of confounding bias, primarily for lack of blinding and unclear reporting of baselines. The mean age was 75, 45 percent were female, and all had a Fitzpatrick skin score of I (47.5%) or II (52.5%). Forty-five percent of the BCCs were superficial, while 55 percent were nodular; 75 percent were on the head and neck and 25 percent on the trunk or extremities. The lower dose (36.6 Gy) had a higher rate of lack of histological clearance at up to a year than the higher dose (42 Gy), but this difference was not significant (OR 2.11; 95% CI 0.18 to 25.35).^143^

The fifth NRCS reports on 20 BCC lesions (43% superficial/multicentric, 47.5% nodular, 9.5% infiltrative/micronodular/morpheaform/scelorosing; 90.5% on the trunk/neck and 9.5% on the extremities) treated with pulse dye laser and 20 matched lesions that received no treatment. This study was deemed to be at a moderate risk of confounding bias, primarily for lack of blinding and unclear reporting of baselines. At surgical excision, approximately 2 weeks after the last treatment, 7 of the 20 lesions treated with pulse dye laser showed lack of histological clearance, compared to 18 of the lesions not treated (OR 0.06; 95% CI 0.01 to 0.34).^152^

Finally, the sixth NRCS included both BCCs (71%) and SCCs (29%), and compared two doses of external radiation therapy. In the lower-dose (37 Gy) group 14 of 236 lesions (5.9%) were not histologically clear compared to none of 149 (0%) in the higher-dose (45 Gy) group. There was no adjusted analysis available for this outcome.^151^

### Lack of Clinical Clearance, All BCC Lesions

The evidence graph for lack of clinical clearance with respect to individual treatments is sparse (Figure 6 (C) – reproduced in Figure 9 (A) for ease of reference), and comprises 3 connected subgraphs. Detailed results at the RCT-level are in Appendix I.

Figure 9 Evidence graph of RCTs evaluating lack of clinical clearance in BCCs across (A) individual interventions and (B) types of interventions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 9. (A) This is the topology map of the network meta-analysis of the interventions for lack of clinical clearance for all BCCs compared in 15 RCTs. Thirteen interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, laser), radiation (external or brachytherapy), PDT (MAL or ALA), drugs (imiquimod, interferon, ingenol); or combinations of interventions (excision or Mohs, external radiation or brachytherapy, MAL PDT and laser). Eleven of these interventions are connected in the primary graph, with none connected to more than three others. There is one subgraph comparing Mohs or excision with external radiation or brachytherapy. (B) This is the coarse topology map of the network meta-analysis of the different types of interventions for lack of clinical clearance for all BCCs compared in 15 RCTs. The six intervention types include surgical, thermodynamic, radiation, PDT, medical/drugs, and no treatment/placebo. Of the 15 possible pairwise comparisons, 8 are covered by direct study comparisons as indicated by lines between the treatment circles.

#### Comparisons Across Intervention Categories

In total, 15 RCTs (1846 lesions) were included in this analysis.^42, 47, 50–53, 58, 59, 67, 70, 85, 92, 94, 98, 104^ Twelve RCTs were deemed to be at low or moderate risk of bias. Cumulative sample sizes per comparison ranged from 27 to 380; for more details see Table 35.

Table 35 Sample information, lack of clinical clearance (all BCC lesions, intervention categories)

Studies (total sample) | 15 (1846)
Total sample by intervention | (D): 201; (F): 379; (A,B): 460; (C): 223; (I,J): 129; (E): 404
Total sample by intervention, (min, max) | 129, 460
Data by comparison | (D--F): 1 (27); (D--A,B): 1 (347); (D--C): 1 (31); (F--A,B): 1 (212); (F--I,J): 3 (379); (A,B--E): 3 (380); (C--E): 4 (420)
Studies by comparison (min, max) | 1, 4
Total sample by comparison (min, max) | 27, 420
Followup median (min, max) | 6 (3, 41) months

A = surgical excision, B = Mohs micrographic surgery; BCC=basal cell carcinoma; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 36 shows the relative odds ratios for lack of clinical clearance across intervention categories. Overall, no or sham treatment (I,J) was statistically significantly worse than all active treatments. Surgical treatments (A,B) were statistically significantly better than PDT (E) and drugs (F) All other comparisons were statistically not significant; however, the confidence intervals were wide and could not exclude even large differences between the comparators.

Table 36 Relative odds ratios for lack of clinical clearance between intervention categories (all BCC lesions, Figure 9B)

Surgery\|MMS (A\|B) | 0.23 (0.05, 1.11) | 0.64 (0.08, 5.11) | 0.18 (0.05, 0.7) | 0.16 (0.03, 0.87) | 0.01 (<0.005, 0.04)
4.29 (0.9, 20.48) | Heat/cold (C) | 2.74 (0.36, 20.9) | 0.78 (0.28, 2.2) | 0.68 (0.13, 3.56) | 0.03 (<0.005, 0.17)
1.57 (0.2, 12.55) | 0.37 (0.05, 2.79) | Radiation (D) | 0.29 (0.04, 2.08) | 0.25 (0.03, 2.09) | 0.01 (<0.005, 0.1)
5.48 (1.44, 20.89) | 1.28 (0.46, 3.58) | 3.5 (0.48, 25.44) | PDT (E) | 0.86 (0.18, 4.1) | 0.03 (0.01, 0.2)
6.35 (1.15, 35.1) | 1.48 (0.28, 7.8) | 4.05 (0.48, 34.21) | 1.16 (0.24, 5.51) | Drugs (F) | 0.04 (0.01, 0.14)
171.32 (23.53, 1247.4) | 39.94 (5.86, 272.09) | 109.33 (10.37, 1152.42) | 31.28 (5, 195.56) | 26.99 (7.26, 100.4) | No/sham treatment (I\|J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy.

In the Table, shaded cells correspond comparisons that have been inferred from the analysis model, but that have not been examined in the included RCTs. For example, comparisons of surgical treatments (A,B) versus drugs (F) are indirect. Indirect comparisons are more uncertain that those for which head-to-head data exist. The added uncertainty about indirect comparisons is partly reflected in the width of the respective 95% confidence intervals, which is (often much) broader for comparisons without versus with direct data. For all comparisons that are empirically observed (all nonshaded cells in the Table), results using only head-to-head data agree well with the results from the network meta-analysis in Table 36 (see Appendix I).

Table 37 offers complementary information from the same analysis. For each intervention category, it shows the mean fraction of lesions without clinical clearance across the included RCTs. It also forecasts expected fractions with each intervention category in groups of patients similar to the patients included in the analyzed RCTs. The average percentage of lesions with no clinical clearance was 2.9 percent in surgical treatment arms, between 4.5 and 16.5 percent in other active intervention categories, and 84.2 percent for no or sham treatment.

Table 37 Mean and forecasted lack of clinical clearance fractions by intervention category (all BCC lesions)

Intervention Type | Mean Lack of Clinical Clearance Fraction Percent (95% CI) | Forecasted Lack of Clinical Clearance Fraction Percent (95% CI)
Surgery\|MMS (A\|B) | 3.0 (0.8, 10.7) | 3.0 (0.2, 38.7)
Heat/cold (C) | 11.9 (4.2, 29.1) | 11.9 (0.7, 71.1)
Radiation (D) | 4.7 (0.8, 23.4) | 4.7 (0.2, 55.8)
PDT (E) | 14.7 (6.1, 31.3) | 14.7 (1.0, 74.9)
Drugs (F) | 16.6 (5.3, 41.6) | 16.6 (1.0, 79.6)
No/sham treatment (I\|J) | 84.3 (52.5, 96.3) | 84.3 (19.2, 99.2)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; CI = confidence interval; BCC = basal cell carcinoma

#### Comparisons Across Individual Interventions

The results of the analyses of intervention categories are congruent with the corresponding results of analyses of individual interventions. As evident from Figure 9, there are 2 connected subgraphs for this outcome. Separate analyses are conducted for each connected subgraph. In total, 14 RCTs (1734 lesions) were included in these analyses, as summarized in Table 38.

Table 38 Sample information, lack of clinical clearance (all BCC lesions, individual interventions)

| First subgraph^42, 47, 51–53, 58, 59, 67, 70, 85, 92, 94, 98, 104^ | Second subgraph^50^
Studies (total sample) | 14 (1449) | 1 (347)
Total sample by intervention | (D1): 28; (F2): 213; (C1): 152; (F3): 118; (J): 129; (E2): 93; (A): 286; (E1): 311; (F4): 48; (C5+E1): 37; (C5 + E2): 34 | (A\|B): 174; (D1\|D2): 173
Total sample by intervention, (min, max) | 28, 311 | 173, 174
Data by comparison | (D1--F2): 1 (27); (D1--C1): 1 (31); (F2--J): 1 (166); (F2--A): 1 (212); (C1--E2): 1 (83); (C1--E1): 1 (201); (F3--J): 1 (159); (J--F4): 1 (54); (E2--A): 1 (40); (A--E1): 2 (340); (E1--C5+E1): 2 (74); (E2—C5 + E2): 1 (62) | (A\|B--D1\|D2): 1 (347)
Studies by comparison (min, max) | 1, 2 | 1, 1
Total sample by comparison (min, max) | 27, 340 | 347, 347
Followup median (min, max) | 6 (3, 12) months | 41 (41, 41) months

A = surgical excision; B = Mohs micrographic surgery; BCC=basal cell carcinoma; C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; C5 = laser; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F1 = 5-FU; F2 = Imiquimod; F3 = Interferon; F4 = Ingenol; H = curettage; J = placebo

Table 39 has results on the relative effects for the largest subgraph. Table 40 has the corresponding results for the comparison of surgical excision or MMS (A|B) with external radiation therapy or brachytherapy (D1|D2). In Table 39 comparisons across individual observations are sparse; the majority of the pairwise comparisons are inferred from indirect data. The confidence intervals of the odds ratios for most indirect comparisons are very broad and cannot exclude very large differences between the comparators. The comparison in Table 40 was not statistically significant; the confidence interval was wide and could not exclude large differences between the comparators.

Table 39 Relative odds ratios for lack of clinical clearance between individual interventions (all BCC lesions, Figure 9A, largest subgraph)

Surgery (A) | 0.17 (0.04, 0.65) | 0.6 (0.13, 2.72) | 0.28 (0.07, 1.22) | 0.45 (0.03, 6.02) | 0.2 (0.06, 0.7) | 0.41 (0.14, 1.18) | 0.36 (0.08, 1.74) | 0.27 (0.05, 1.42) | 0.07 (0.01, 0.45) | 0.06 (0.01, 0.29)
5.95 (1.53, 23.14) | Cryotherapy (C1) | 3.56 (0.84, 15.01) | 1.68 (0.34, 8.28) | 2.67 (0.23, 31.74) | 1.21 (0.39, 3.77) | 2.44 (0.7, 8.51) | 2.16 (0.41, 11.44) | 1.61 (0.28, 9.21) | 0.44 (0.07, 2.84) | 0.35 (0.07, 1.88)
1.67 (0.37, 7.6) | 0.28 (0.07, 1.18) | Laser + PDT (MAL) (C5+E1) | 0.47 (0.07, 2.99) | 0.75 (0.05, 10.88) | 0.34 (0.14, 0.84) | 0.69 (0.14, 3.29) | 0.61 (0.1, 3.69) | 0.45 (0.07, 2.95) | 0.12 (0.02, 0.9) | 0.1 (0.02, 0.6)
3.53 (0.82, 15.24) | 0.59 (0.12, 2.92) | 2.11 (0.33, 13.37) | Laser + PDT (ALA) (C5+E2) | 1.59 (0.1, 25.01) | 0.72 (0.14, 3.65) | 1.45 (0.51, 4.16) | 1.28 (0.19, 8.56) | 0.96 (0.13, 6.85) | 0.26 (0.03, 2.09) | 0.21 (0.03, 1.41)
2.22 (0.17, 29.75) | 0.37 (0.03, 4.44) | 1.33 (0.09, 19.26) | 0.63 (0.04, 9.9) | External radiation (D1) | 0.45 (0.04, 5.67) | 0.91 (0.07, 12.11) | 0.81 (0.06, 10.4) | 0.6 (0.04, 8.25) | 0.16 (0.01, 2.47) | 0.13 (0.01, 1.72)
4.93 (1.43, 17.02) | 0.83 (0.26, 2.6) | 2.95 (1.2, 7.28) | 1.4 (0.27, 7.12) | 2.22 (0.18, 27.9) | PDT (MAL) (E1) | 2.02 (0.55, 7.48) | 1.79 (0.36, 8.8) | 1.33 (0.25, 7.1) | 0.36 (0.06, 2.2) | 0.29 (0.06, 1.44)
2.44 (0.85, 7.01) | 0.41 (0.12, 1.43) | 1.46 (0.3, 7) | 0.69 (0.24, 1.98) | 1.1 (0.08, 14.53) | 0.49 (0.13, 1.82) | PDT (ALA) (E2) | 0.88 (0.17, 4.57) | 0.66 (0.12, 3.7) | 0.18 (0.03, 1.15) | 0.14 (0.03, 0.75)
2.75 (0.58, 13.2) | 0.46 (0.09, 2.46) | 1.65 (0.27, 10.02) | 0.78 (0.12, 5.21) | 1.24 (0.1, 15.97) | 0.56 (0.11, 2.75) | 1.13 (0.22, 5.85) | Imiqumod (F2) | 0.74 (0.35, 1.59) | 0.2 (0.06, 0.63) | 0.16 (0.1, 0.28)
3.7 (0.7, 19.48) | 0.62 (0.11, 3.56) | 2.21 (0.34, 14.44) | 1.05 (0.15, 7.51) | 1.66 (0.12, 22.82) | 0.75 (0.14, 3.99) | 1.52 (0.27, 8.54) | 1.34 (0.63, 2.87) | INF (F3) | 0.27 (0.09, 0.87) | 0.22 (0.13, 0.38)
13.59 (2.24, 82.53) | 2.29 (0.35, 14.85) | 8.14 (1.11, 59.66) | 3.85 (0.48, 30.95) | 6.12 (0.41, 92.23) | 2.76 (0.45, 16.72) | 5.58 (0.87, 35.77) | 4.93 (1.58, 15.4) | 3.68 (1.16, 11.69) | Ingenol (F4) | 0.81 (0.29, 2.24)
16.86 (3.47, 82.04) | 2.84 (0.53, 15.08) | 10.09 (1.66, 61.51) | 4.77 (0.71, 32.06) | 7.59 (0.58, 98.98) | 3.42 (0.69, 16.86) | 6.93 (1.33, 36.11) | 6.12 (3.61, 10.4) | 4.56 (2.64, 7.88) | 1.24 (0.45, 3.45) | Placebo (J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates a significant result. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; INF = Interferon; BCC = basal cell carcinoma; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon.

Table 40 Relative odds ratios for lack of clinical clearance between individual interventions (all BCC lesions, Figure 9A, remaining subgraphs)

Surgery or MMS (A\|B) | 0.16 (0.01, 3.27)
6.16 (0.31, 123.87) | External radiation or brachytherapy (D1\|D2)

BCC = basal cell carcinoma

Table 41 shows, for each intervention, the mean fractions for lack of clinical clearance across all RCTs. Estimates for interventions in all three subgraphs are listed in the table. One should not statistically compare these fractions across the subgraphs, because they come from disjoint analyses. In general, the mean fractions of lack of clinical clearance for individual interventions are in congruence with the corresponding fractions estimated for intervention categories.

Table 41 Mean and forecasted lack of clinical clearance fractions by individual intervention (all BCC lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
First subgraph (Figure 9)
Surgical excision (A) | 0.5 (0.2, 1.8) | 0.5 (0.0, 9.8)
Cryotherapy (C1) | 3.1 (1.0, 9.4) | 3.1 (0.2, 38.2)
Laser + PDT (MAL) (C5+E1) | 0.9 (0.2, 3.4) | 0.9 (0.0, 16.2)
Laser + PDT (ALA) | 1.8 (0.4, 7.5) | 1.8 (0.1, 29.1)
External radiation (D1) | 1.2 (0.1, 11.5) | 1.2 (0.0, 31.1)
PDT (MAL) (E1) | 2.6 (0.9, 7.1) | 2.6 (0.1, 32.9)
PDT (ALA) (E2) | 1.3 (0.4, 4.2) | 1.3 (0.1, 20.6)
Imiquimod (F2) | 1.6 (0.4, 5.2) | 1.6 (0.1, 24.0)
IFN(F3) | 1.6 (0.4, 5.9) | 1.6 (0.1, 25.4)
Ingenol (F4) | 5.5 (1.5, 18.4) | 5.5 (0.3, 54.9)
No/sham treatment (J) | 6.6 (2.0, 19.7) | 6.6 (0.4, 58.6)
Second subgraph (Figure 9)
Surgical excision or MMS (A\|B) | 0.3 (0.0, 4.4) | NA
External radiation or brachytherapy (D1\|D2) | 1.7 (0.6, 5.2) | NA

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; INF = interferon; BCC = basal cell carcinoma; CI = confidence interval; NA = not applicable

#### Lack of Clinical Clearance, Subgroup Analyses by Lesion Type

We conducted subgroup analyses by the type of BCC lesion. We report analyses comparing groups of interventions, but not analyses comparing individual treatments. The latter are very sparse, and their results are similar to the pertinent comparisons in Tables 39 and 40.

Many subgroup analyses per lesion type are possible; we describe here analyses in RCTs of lower-risk lesions (strata of predominantly [>80%] superficial BCCs, predominantly nodular BCCs, and superficial or nodular BCCs) overall, and broken down by lesion type, along with analyses of higher-risk lesions (morpheaform, micronodular, trabecular, infiltrative, or squamous differentiation).

All 14 RCTs reporting results on lack of clinical clearance enrolled patients with low-risk BCCs (nodular and superficial subtypes; n=1922).^47, 50–53, 58, 59, 67, 70, 85, 92, 94, 98, 104^ Thus, for the lower-risk BCCs subgroup the results are practically the same as in the previous section (Tables 36 and 37).

Table 42 summarizes characteristics of the five RCTs of patients with predominantly superficial BCC lesions (n=868).^51, 52, 92, 94, 98^ Tables 43 and 44 show the results. Most comparisons in Table 43 are indirect, and the confidence intervals for these differences are too broad to allow drawing conclusions..

Table 42 Sample information, lack of clinical clearance (superficial BCC lesions)

Studies (total sample) | 5 (868)
Total sample by intervention | (F): 246; (I,J): 88; (A,B): 215; (E): 221; (C): 98
Total sample by intervention, (min, max) | 88, 246
Data by comparison | (F--I,J): 2 (220); (F--A,B): 1 (212); (A,B--E): 1 (235); (E--C): 1 (201)
Studies by comparison (min, max) | 1, 2
Total sample by comparison (min, max) | 201, 235
Followup median (min, max) | 3 (3, 36) months

A = surgical excision; B = Mohs micrographic surgery; BCC=basal cell carcinoma; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 43 Relative odds ratios for lack of clinical clearance between intervention categories (superficial BCC lesions)

Surgery/MMS (A,B) | 0.13 (<0.005, 10.81) | 0.12 (<0.005, 5.06) | 0.02 (<0.005, 0.79) | <0.005 (<0.005, 0.02)
7.71 (0.09, 642.49) | Heat/cold (C) | 0.94 (0.01, 59.67) | 0.19 (<0.005, 9.58) | <0.005 (<0.005, 0.28)
8.16 (0.2, 337.33) | 1.06 (0.02, 66.93) | PDT (E) | 0.2 (0.01, 4.49) | <0.005 (<0.005, 0.14)
40.1 (1.27, 1269.18) | 5.2 (0.1, 259.27) | 4.91 (0.22, 108.22) | Drugs (F) | 0.02 (<0.005, 0.53)
2071.45 (41.73, 102817.08) | 268.7 (3.6, 20036.53) | 253.71 (7.01, 9177.18) | 51.65 (1.88, 1415.99) | No/sham treatment (I,J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons. Results are given as odds ratios (95% confidence intervals).

BCC=basal cell carcinoma; MMS = Mohs micrographic surgery; PDT = photodynamic therapy

Table 44 Mean and forecasted lack of clinical clearance fractions by intervention category (superficial BCC lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
Surgery/MMS (A,B) | 0.7 (<0.5, 10.7) | 0.7 (<0.5, 34.6)
Heat/cold (C) | 5.1 (0.2, 61.3) | 5.1 (<0.5, 85.5)
PDT (E) | 5.4 (0.5, 38.5) | 5.4 (0.1, 76.5)
Drugs (F) | 21.9 (3.8, 66.4) | 21.9 (0.6, 92.6)
No/sham treatment (I,J) | 93.5 (50.0, 99.5) | 93.5 (17.6, 99.9)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma; CI = confidence interval

Table 45 provides details on the comparisons of six RCTs of predominantly nodular lesions (n=434). Results are given in Tables 46 and 47.^52, 53, 58, 67, 70, 85^ These results very uncertain, and are based on at most two studies per comparison. The confidence intervals for differences between the intervention categories are generally very broad.

Table 45 Sample information, lack of clinical clearance (superficial BCC lesions)

Studies (total sample) | 6 (434)
Total sample by intervention | (D): 12; (F): 113; (A,B): 161; (E): 111; (C): 37
Total sample by intervention, (min, max) | 12, 161
Data by comparison | (D--F): 1 (27); (F--A,B): 1 (188); (A,B--E): 2 (145); (E--C): 2 (74)
Studies by comparison (min, max) | 1, 2
Total sample by comparison (min, max) | 27, 188
Followup median (min, max) | 8 (3, 36) months

A = surgical excision; B = Mohs micrographic surgery; BCC=basal cell carcinoma; C = heat/cold; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 46 Relative odds ratios between intervention categories for lack of clinical clearance (nodular BCC lesions)

Surgery/MMS (A,B) | 2.06 (0.38, 11.25) | 1.79 (0.03, 97.08) | 0.28 (0.09, 0.87) | 1.98 (0.15, 26.6)
0.49 (0.09, 2.65) | Heat/cold (C) | 0.87 (0.01, 53.43) | 0.13 (0.04, 0.49) | 0.96 (0.06, 16.76)
0.56 (0.01, 30.25) | 1.15 (0.02, 70.67) | Radiotherapy (D) | 0.15 (<0.005, 8.16) | 1.11 (0.03, 44.12)
3.63 (1.16, 11.4) | 7.48 (2.06, 27.14) | 6.5 (0.12, 344.91) | PDT (E) | 7.19 (0.52, 99.37)
0.5 (0.04, 6.77) | 1.04 (0.06, 18.11) | 0.9 (0.02, 36.04) | 0.14 (0.01, 1.92) | Drugs (F)

Note: RCTs of predominantly nodular lesions. Cells shaded gray indicate that the estimate is based only on indirect comparisons. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

Table 47 Mean fractions of lesions with no clinical clearance by intervention category (nodular BCC lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
Surgery/MMS (A,B) | 7.6 (1.5, 31.6) | 7.6 (0.2, 74.7)
Heat/cold (C) | 3.9 (0.6, 20.6) | 3.9 (0.1, 60.6)
Radiotherapy (D) | 4.4 (0.1, 66.7) | 4.4 (0.0, 86.1)
PDT (E) | 23.0 (6.0, 58.5) | 23.0 (0.9, 90.8)
Drugs (F) | 4.0 (0.4, 32.7) | 4.0 (0.1, 69.1)

Note: RCTs of predominantly nodular lesions.

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma; CI = confidence interval

#### Lack of Clinical Clearance, Other Subgroup Analyses (Lesion Location, Lesion Size)

Table 48 shows results on subgroup analyses for three RCTs that reported treatment effects in subgroups of interest, two in patients with predominantly superficial BCCs^51, 98^ and one in patients with predominantly nodular BCCs.^22, 85^ Neither lesion location nor size were associated with differences in the treatment effect beyond what is expected by chance. Only one outcome was statistically significant at a 0.05 level: surgical excision (A) performed better than PDT with MAL (E1) for lesions on the trunk and neck at 3 months; however by 12 months, this finding was no longer significant.^98^

Table 48 Subgroup results for lack of clinical clearance in BCC lesions

Study | Comparison | Timepoint | Subgroup | n/N Arm 1 vs. n/N Arm 2 | OR (95% CI); P-Value Within | P- Value Between
Szeimies 2008 18624842 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion location: face/scalp | 0/4 vs. 0/15 | N/A | NA
Szeimies 2008 18624842 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion location: trunk/neck | 1/83 vs. 7/76 | 0.12 (0.01, 1.00); p=0.028 | NA
Szeimies 2008 18624842 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion location: extremities | 0/31 vs. 3/37 | 0.16 (0.01, 3.15); p=0.245 | NA
Szeimies 2008 18624837 | Surgical excision (A) vs. PDT (MAL) (E1) | 12 months | lesion location: face/scalp | 0/4 vs. 4/15 | 0.28 (0.01, 6.42); p=0.530 | NA
Szeimies 2008 18624837 | Surgical excision (A) vs. PDT (MAL) (E1) | 12 months | lesion location: trunk/neck | 0/82 vs. 3/69 | 0.12 (0.01, 2.27); p=0.093 | NA
Szeimies 2008 18624837 | Surgical excision (A) vs. PDT (MAL) (E1) | 12 months | lesion location: extremities | 0/31 vs. 4/34 | 0.11 (0.01, 2.08); p=0.115 | NA
Rhodes 2004 14732655 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion location: extremities | 0/5 vs. 0/5 | NA | NA
Rhodes 2004 14732655 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion location: face/scalp | 1/32 vs. 1/21 | 0.65 (0.04, 10.91); p=1.000 | NA
Rhodes 2004 14732655 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion location: trunk/neck | 0/15 vs. 4/27 | 0.17 (0.01, 3.35); p=0.279 | NA
Szeimies 2008 18624840 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion diameter: 7–14 mm | 1/70 vs. 7/85 | 0.16 (0.02, 1.35); p=0.073 | NA
Szeimies 2008 18624840 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion diameter: 15–20 mm | 0/43 vs. 3/43 | 0.13 (0.01, 2.66); p=0.241 | NA
Rhodes 2004 14732655 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion diameter: 6–14mm | 1/43 vs 4/40 | 0.21 (0.02, 2.00); p=0.191 | p=0.994
Rhodes 2004 14732655 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion diameter: 15–19mm | 0/6 vs. 1/11 | 0.54 (0.02, 15.30); p=1.000 | p=0.994
Rhodes 2004 14732655 | Surgical excision (A) vs. PDT (MAL) (E1) | 3 months | lesion diameter: 20–30mm | 0/3 vs. 0/2 | NA | p=0.994
Basset-Seguin 2008 18693159 | Cryotherapy (C1) vs. PDT (MAL) (E1) | 3 months | lesion diameter: 5–10mm | 3/41 vs. 1/44 | 3.39 (0.34, 34.02); p=0.349 | NA
Basset-Seguin 2008 18693159 | Cryotherapy (C1) vs. PDT (MAL) (E1) | 3 months | lesion diameter: 11–19 mm | 2/41 vs. 1/43 | 2.15 (0.19, 24.70); p=0.611 | NA
Basset-Seguin 2008 18693159 | Cryotherapy (C1) vs. PDT (MAL) (E1) | 3 months | lesion diameter: >= 20 mm | 0/16 vs. 1/16 | 0.31 (0.01, 8.28); p=1.000 | NA

NA = not significant; PDT = photodynamic therapy; MAL = methyl aminolevulinate; BCC = basal cell carcinoma; CI = confidence interval

#### Lack of Clinical Clearance, Results From Nonrandomized Studies (BCC Lesions)

None of the eligible NRCSs reported data on lack of clinical clearance.

#### Various Outcomes in Patients With High-Risk BCC Lesions Treated With Hedgehog Inhibitors

Hedgehog inhibitors, including vismodegib and sonidegib (F5, other drugs), are a group of systemic medications that are primarily used for advanced or metastatic BCC. Comparisons of outcomes in these high-risk populations with studies that include lower-risk BCCs are not clinically meaningful and so we report these separately.

One RCT (n=230) compared 2 doses (200 vs. 800 mg per os daily) of sonidegib for locally advanced BCC not amenable to surgery (n=194) or radiation or metastatic BCC for which other options had been exhausted (n=36). Median age was 67 and 65, respectively, and over 90 percent were white. In the locally advanced group, 2 of 66 (3%) participants in the 200 mg arm achieved a complete response compared with none of 128 (0%) in the 800 mg arm. The number of participants experiencing any adverse event was high in both arms (75/79 [95%] in the 200 mg arm, 150/150 [100%] in the 800 mg arm.^75^

### Patient-Reported Cosmetic Outcomes, All BCC Lesions

For this outcome we describe only results between intervention categories, because data are sparse for the comparison of individual observations. In total, seven RCTs (752 lesions) were included in this analysis.^50, 51, 67, 70, 85, 98, 99^ Five RCTs were deemed to be at low or moderate risk of bias. The evidence graph in Figure 10 shows the observed comparisons based on RCTs that report patient assessments of “at least good” cosmetic outcome. The evidence graph is sparsely connected. Patients assessed cosmetic outcomes using different scales in each RCT, though often on scales of that included poor, fair, good, and excellent or similar. We provide analyses for an “at least good” cosmetic outcome. Details about the comparisons between these RCTs are in Table 49.

Figure 10 Evidence graph of RCTs comparing patient-assessed cosmetic outcomes (all BCC lesions)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

Figure 10. This is the coarse topology map of the network meta-analysis of the different types of interventions for patient-reported cosmetic outcomes for all BCCs compared in seven RCTs. The five intervention types include surgical (excision or Mohs), thermodynamic, radiation, PDT, and medical/drugs. Of the 10 possible pairwise comparisons, 5 are covered by direct study comparisons as indicated by lines between the treatment circles. Only surgical excision is connected to more than two others (radiation, thermodynamic, and PDT), thermodynamic is also connected to PDT, and radiation to drug therapy.

Table 49 Sample information, patient-reported cosmetic outcomes (all BCC lesions, intervention categories)

Studies (total sample) | 7 (752)
Total sample by intervention | (D): 125; (F): 15; (A,B): 309; (C): 113; (E): 190
Total sample by intervention, (min, max) | 15, 309
Data by comparison | (D--F): 1 (27); (D--A,B): 1 (244); (A,B--C): 1 (96); (A,B--E): 2 (254); (C--E): 2 (131)
Studies by comparison (min, max) | 1, 2
Total sample by comparison (min, max) | 27, 254
Followup median (min, max) | 4 (3, 48) months

A = surgical excision; B = Mohs micrographic surgery; BCC = basal cell carcinoma; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 50 shows the results of the comparisons between intervention categories based on a network meta-analysis. Most comparisons are indirect (denoted by shaded cells) and have wide confidence intervals. For comparisons with head-to-head data (denoted by unshaded cells) the numbers in the table are very similar whether information from indirect comparisons is included or excluded. Five of 10 comparisons are statistically significant.

Table 50 Relative odds ratios between intervention categories for at least good cosmetic outcome as assessed by patients (all BCC lesions, Figure 10)

Surgery/MMS (A,B) | 5.2 (1.37, 19.79) | 2.1 (1.18, 3.72) | 0.17 (0.06, 0.46) | 0.49 (0.02, 14.01)
0.19 (0.05, 0.73) | Heat/cold (C) | 0.4 (0.1, 1.67) | 0.03 (0.01, 0.13) | 0.09 (<0.005, 3.01)
0.48 (0.27, 0.85) | 2.48 (0.6, 10.25) | Radiation (D) | 0.08 (0.02, 0.25) | 0.23 (0.01, 6.69)
6 (2.16, 16.69) | 31.19 (7.54, 128.97) | 12.58 (3.95, 40.03) | PDT (E) | 2.95 (0.09, 93.05)
2.03 (0.07, 58.01) | 10.58 (0.33, 336.76) | 4.27 (0.15, 121.7) | 0.34 (0.01, 10.7) | Drugs (F)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates that the result is statistically significant. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

Table 51 shows the average percentage of patients with at least good cosmetic outcomes in the RCTs, based on the same network meta-analysis as Table 50. Drugs (F) and PDT (E) are associated with highest percentages, followed surgical treatments (A,B), radiation (D), interventions that use heat or cold to destroy the lesion (C).

Table 51 Mean and forecasted fractions of lesions with at least good cosmetic outcome as assessed by patients (all BCC lesions)

Intervention Type | Mean Percent (95% CI) | Mean Percent (95% CI)
Surgery/MMS (A,B) | 88.8 (73.7, 95.7) | 88.8 (44.3, 98.8)
Heat/cold (C) | 60.5 (32.4, 83.0) | 60.5 (12.7, 94.2)
Radiation (D) | 79.1 (55.2, 92.1) | 79.1 (26.8, 97.5)
PDT (E) | 97.9 (93.1, 99.4) | 97.9 (81.1, 99.8)
Drugs (F) | 94.2 (37.5, 99.8) | 94.2 (25.0, 99.9)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma; CI = confidence interval

#### Observer-Reported Cosmetic Outcomes, All BCC Lesions

We describe only the results between intervention categories, because data are sparse for the comparison of individual observations. In total, 10 RCTs (1460 lesions) were included in this analysis.^49–52, 66, 70, 85, 98, 104^ Nine RCTs were deemed to be at low or moderate risk of bias. The evidence graph in Figure 11 shows the observed comparisons based on RCTs that report observers’ (investigators’ or providers’) assessments of “at least good” cosmetic outcome. The cosmetic outcome was assessed using different scales in each RCT, though often on scales of that included poor, fair, good, and excellent or similar. We provide analyses for an “at least good” cosmetic outcome. The evidence graph is sparsely connected. Details about the comparisons between these RCTs are in Table 52.

Figure 11 Evidence graph of RCTs comparing observer-assessed cosmetic outcomes (all BCC lesions)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy

Figure 11. This is the coarse topology map of the network meta-analysis of the different types of interventions for observer-reported cosmetic outcomes for all BCCs compared in nine RCTs. The six intervention types include surgical (excision or Mohs), thermodynamic, radiation, PDT, medical/drugs, and no treatment/placebo. Of the 15 possible pairwise comparisons, 6 are covered by direct study comparisons. Surgical excision is connected to radiation, PDT, and drugs; PDT is also connected to thermodynamic, drugs, and placebo/no treatment.

Table 52 Sample information, observer-reported cosmetic outcomes (all BCC lesions, intervention categories)

Studies (total sample) | 10 (1460)
Total sample by intervention | (A,B): 426; (D): 113; (C): 109; (E): 443; (F): 354; (I,J): 15
Total sample by intervention, (min, max) | 15, 443
Data by comparison | (A,B--D): 1 (244); (A,B--E): 2 (235); (A,B--F): 1 (344); (C--E): 4 (209); (E--F): 1 (370); (E--I,J): 1 (58)
Studies by comparison (min, max) | 1, 4
Total sample by comparison (min, max) | 58, 370
Followup median (min, max) | 12 (12, 60) months

A = surgical excision; B = Mohs micrographic surgery; BCC=basal cell carcinoma; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

Table 53 has the results of the comparisons between intervention categories based on a network meta-analysis. Most comparisons are indirect (denoted by shaded cells) and have wide confidence intervals. For comparisons with head-to-head data (denoted by unshaded cells), the numbers in the table are very similar whether information from indirect comparisons is included or excluded. Overall, the results are compatible with the corresponding results for patient-rated cosmetic outcomes. Specifically, four out of 15 comparisons are statistically significant: For example, based only on indirect data, surgical interventions (A,B) are favored over radiation (D), and based on direct and indirect data, PDT (E) is favored over surgical interventions (A,B).

Table 53 Relative odds ratios between intervention categories for at least good cosmetic outcome as assessed by an observer (all BCC lesions, Figure 11)

Surgery/MMS (A,B) | 0.42 (0.12, 1.47) | 3.57 (0.83, 15.36) | 0.16 (0.06, 0.40) | 0.38 (0.12, 1.18) | 0.14 (0.01, 2.04)
2.37 (0.68, 8.25) | Heat/cold (C) | 8.45 (1.42, 50.4) | 0.37 (0.13, 1.06) | 0.90 (0.22, 3.64) | 0.33 (0.02, 5.11)
0.28 (0.07, 1.21) | 0.12 (0.02, 0.71) | Radiation (D) | 0.04 (0.01, 0.22) | 0.11 (0.02, 0.61) | 0.04 (<0.005, 0.76)
6.39 (2.5, 16.35) | 2.70 (0.94, 7.74) | 22.81 (4.56, 114.26) | PDT (E) | 2.43 (0.81, 7.33) | 0.89 (0.06, 12.23)
2.63 (0.85, 8.14) | 1.11 (0.27, 4.48) | 9.38 (1.63, 54.02) | 0.41 (0.14, 1.24) | Drugs (F) | 0.36 (0.02, 5.78)
7.22 (0.49, 106.52) | 3.05 (0.2, 47.44) | 25.76 (1.31, 505.2) | 1.13 (0.08, 15.59) | 2.75 (0.17, 43.61) | No/sham treatment (I,J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates that the result is statistically significant. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

Table 54 shows the average percentage of patients with at least good cosmetic outcomes in the RCTs, based on the same network meta-analysis as Table 53. The mean percentage of lesions with cosmetic outcome rated as good or excellent ranged between 74.3 and 89.8 percent for interventions that destroy the lesion with heat or cold (C), drugs (F), PDT (E) and no or sham treatment (I,J), and was 55.0 percent for surgical treatments (A,B). Radiation (D) had the smallest percentage of at least good cosmetic outcome. The confidence intervals for these proportions are wide. Refer to Table 53 for a pairwise comparison between these treatments.

Table 54 Mean fractions of lesions with at least good cosmetic outcome as assessed by an observer (all BCC lesions)

Intervention Type | Mean Fraction Percent (95% CI) | Forecasted Fraction Percent
Surgery/MMS (A,B) | 55.0 (34.7, 73.8) | 55.0 (15.1, 89.3)
Heat/cold (C) | 74.3 (51.5, 88.8) | 74.3 (28.0, 95.6)
Radiation (D) | 25.5 (7.1, 60.7) | 25.5 (3.3, 77.3)
PDT (E) | 88.7 (78.9, 94.2) | 88.7 (54.2, 98.1)
Drugs (F) | 76.3 (52.8, 90.2) | 76.3 (29.6, 96.1)
No/sham treatment (I,J) | 89.8 (40.1, 99.1) | 89.8 (28.3, 99.5)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; CI = confidence interval

#### Evidence From NRCSs

Three NRCS reported investigator-evaluated results for cosmetic outcomes.^143, 148, 151^

The first one compared surgical excision (A) and PDT with ALA (E2). It reported investigator-evaluated cosmetic outcomes in a matched population of 94 superficial (64%) and nodular (36%) BCCs in 74 patients at 12 months after treatment. The study was rated as having a moderate risk of bias due to lack of blinding and unclear reporting. The mean age was 66, with an age range of 49 to 90, 47 percent of the population was female. The group that received ALA-PDT reported significantly better cosmetic results on a 4-level scale of poor to excellent (OR 10.2; 95% CI 4.0 to 26.1).^148^

A second NRCS reported whether an investigator saw pigmentation changes or alopecia in a small matched population of 40 patients treated with different doses of brachytherapy (36.6 versus 42 Gy). The risk of bias of this study was determined to be moderate, primarily for lack of blinding and unclear reporting of baselines. The mean age was 75, 45 percent were female, and all had a Fitzpatrick skin score of I (47.5%) or II (52.5%). Forty-five percent of the BCCs were superficial, while 55 percent were nodular; 75 percent were on the head and neck and 25 percent on the trunk or extremities. The lower dose had one fewer patient with pigmentation changes or alopecia (OR 0.81, 95% CI 0.23 to 2.86), but this difference was not significant.^143^

The third NRCS reported investigator-evaluated results for cosmetic outcomes to a median of 31.8 months after treatment, with two different doses and schedules of orthovoltage radiotherapy. The risk of bias was determined to be low with well-balanced arms, outcome assessors blinded, and full followup. The population consisted of 436 lesions in 385 elderly people, with BCCs (71%) and SCCs (29%). The mean age was 78, and 42 percent were female. A lower dose of radiation (37 Gy) had a slightly better cosmetic outcomes on a 4-level scale of poor to excellent than the higher dose (45 Gy), but this difference was not significant (RR: 1.048, 95% CI0.170 to 6.473).^151^

### Quality of Life, All BCC Lesions

One RCT^65^ and one NRCS^142, 144–147, 156^ reported eligible results. The former informs on the comparison between surgical excision (A) and MMS (B), and the latter on the comparison between excision (A), MMS (B), and electrodessication and curettage (C3).

#### Evidence From RCTs

The RCT reported on both quality of life and anxiety in a population of 408 primary BCCs (BCC) in 374 people, randomized to surgical excision (A; n=204) or MMS (B; n=204). The mean age of patients was 67.7. The majority of tumors were located in the H-zone (93%) with the highest distribution in the frontal/temporal area (31%). Approximately half of all lesions had an aggressive histological subtype (47% BCC). Differences in tumor location or subtype were not significantly different between treatment groups. The Quality of life (emotional reactions, energy, pain, sleep, social isolation, and physical mobility) and level of anxiety of patients were measured at baseline and 6 months posttreatment, using the Nottingham Health Profile and the State-trait Anxiety Inventory, respectively. Both questionnaires were administered by a single researcher, and only patients with a single BCC were evaluated for these outcomes. At baseline and 6 months posttreatment, patients in both treatment groups showed good “health-related quality life” and a “minimum level of anxiety,” with no observable statistically significant differences between the two groups for any measure.^65^

#### Evidence From NRCSs

The NRCS reported skin-specific quality of life in three domains: symptoms, emotion, and functioning in 1174 patients with 1488 lesions at two sites, a private, university-affiliated dermatology clinic (where majority of patients were recruited) and a nearby Veterans Affairs clinic. This study was deemed to have a low risk of bias, with balanced groups, consecutive recruitment, blinding of outcome assessors, and adequate accounting for people lost to followup. Most (75%) of the lesions were BCCs; the other 25 percent were SCCs; 26 percent were female, 40 percent had a Fitzpatrick skin score of I or II, and 3 percent were immunocompromised due to prior solid-organ transplant. The lesions were treated by MMS (B; n=246; 65% in H-zone of the face), surgical excision (A; n=251; 26% in H-zone of the face), and electrodessication and curettage (ED&C) (C3; n=136; 11% in H-zone of the face).^142, 144–147^

Table 55 shows the propensity-matched net differences between arms for improvement from baseline for each of the three reported Skindex domains (symptoms, emotions, and function) each measured on a scale from 0 (never bothered) to 100 (always bothered). The authors used a shortened, 16-item version of the Skindex (the current Skindex has 29-items), which they had previously validated in a similar population.^157, 158^

Table 55 Quality of life measured with Skindex

Outcome | Arm | N/arm | Baseline Score Mean (SD) | Comparison | Net Difference at 2 Years (95% CI) | N Propensity-Matched Pairs
QoL: Skindex Symptoms | ED&C | 136 | 19.6 (23.6) | excision vs ED&C | −1.6 (−9.8, 6.7) | 51
QoL: Skindex Symptoms | excision | 251 | 21.7 (23.2) | Mohs vs ED&C | 9.2 (−2.1, 20.5) | 24
QoL: Skindex Symptoms | Mohs | 246 | 21.8 (23.5) | Mohs vs excision | 4.0 (−3.1, 11.1) | 81
QoL: Skindex Emotions | ED&C | 136 | 33.0 (28.0) | excision vs ED&C | 13.2 (3.3, 23.1) | 51
QoL: Skindex Emotions | excision | 251 | 38.9 (30.4) | Mohs vs ED&C | 23.6 (10.1, 37.2) | 24
QoL: Skindex Emotions | Mohs | 246 | 46.3 (27.0) | Mohs vs excision | 3.4 (−3.8, 10.7) | 81
QoL: Skindex Functioning | ED&C | 136 | 12.1 (21.7) | excision vs ED&C | 3.1 (−3.5, 9.8) | 51
QoL: Skindex Functioning | excision | 251 | 15.1 (24.6) | Mohs vs ED&C | 3.7 (−4.6, 12.0) | 24
QoL: Skindex Functioning | Mohs | 246 | 14.0 (21.1) | Mohs vs excision | 4.2 (−2.3, 10.8) | 81

ED&C = electrodessication and curettage; QoL = Quality of Life; CI = confidence interval; SD = standard deviation

The unadjusted results in a large population showed large and significant differences, primarily in favor of Mohs and surgical excision as compared to ED&C, but no difference in improvement was observed comparing excision and Mohs surgery in any of the Skindex domains.^145^ However, these results are subject to residual confounding. The propensity-matched results include a smaller population, and thus, while they show potentially large differences, the differences cannot be distinguished from chance.^142, 144–147^

### Mental Health, All BCC Lesions

A single RCT reported information on anxiety measured with the State-Trait Anxiety Inventory at 6 months, for a population of 408 primary BCCs (BCC) in 374 people randomized to surgical excision (A; n=204) or MMS (B; n=204). No statistically significant differences were found between the comparators. This RCT is summarized in some more detail in the Quality of Life section, under Evidence from RCTs.^65^

### Patient Satisfaction, All BCC Lesions

We did not identify eligible RCTs with results for this outcome.

### Mortality, All BCC Lesions

Three RCTs^22, 49, 81, 85, 87, 88^ and 1 NRCS^151^ reported results on all cause mortality.

#### Evidence From RCTs

The first RCT reported mortality between 1 and 3 years in 501 people with 1 superficial BCC lesion each for the comparison of PDT with MAL (E1), 5-FU (F1), and imiquimod (F2). The risk of bias for this study was low, with randomization and allocation concealment adequately reported, blinding of outcome assessors, high similarity of groups at baseline, and low loss to followup. The median age was 63 (range 26 to 91), 49 percent were women, and most lesions were on the trunk (60%), extremities (27%), and face excluding the H-zone (13%). All-cause mortality was recorded for 5 of 196 (2.6%) patients in the PDT with MAL (E1) arm, 2 of 198 (1.0%) in the 5-FU arm (F1), and 4 of 189 (2.1%) in the imiquimod arm (F2).^49, 87, 88^

The second RCT compared surgical excision (A) (n=49) to PDT with MAL (E1) (n=52). The average age was 68 (range 38 to 95), and 40 percent were female. Most (88%) had Fitzpatrick skin types II (46.5%) and III (41.5%). The risk of bias for this study was judged to be relatively high because the groups were not similar at baseline, there was no blinding, and there was a high loss to followup after a year. Mortality at 1 and 2 years was not statistically significantly different in the excision (2/46, 4.3%) and MAL-PDT groups (2/50, 4.0%).^22, 85^

The third RCT compared surgical excision (A) without intraoperative evaluation of the excised margins (n=199) versus MMS (B) (n=198). It reported results for long-term mortality in people with unspecified BCCs on the face, about half of which were classified as an “aggressive histological subtype” between 18 months and 5 years. The average age was 68 (SD 12), and 39.7 percent were female. The average lesion size was 1.28 cm^2^ (SD 1.36) in the MMS arm and 1.77 cm^2^ (SD 1.28) in the surgical excision arm. The risk of bias was judged to be moderate to high because of lack of baseline details given, lack of blinding, and high loss to followup. Thirty-six (18%) died in the MMS arm as compared to 34 (17%) in the excision arm. None of the deaths were deemed to be related to the tumor or the treatment.^81^

#### Evidence From NRCSs

One NRCS reported results for long-term mortality, from 12 to a median of 31.8 months after treatment with two doses of external radiation (orthovoltage range) therapy. It was deemed that there was low risk of confounding or measurement bias based on the fact that arms were well-balanced, outcome assessors were blinded, and no patients were lost to followup. The population consisted of 436 lesions in 385 elderly people, with BCCs (71%) and SCCs (29%). The mean age was 78, and 42 percent were female. The 45 Gy dose of radiation had a lower mortality (16.1%) than the 37 Gy dose group (30.5%), but the mean age in the lower dose group was significantly higher (81.3 vs. 73.3 years). Once adjusted for age, number of lesions per patient, histology, severity, and lesion site, the difference in mortality was not significant (Adjusted HR: 0.662; 95% CI 0.387 to 1.131).^151^

### Costs and Resource Use, All BCC Lesions

No RCTs informed on U.S. costs or on use of resources.

One NRCS reported cost and resource use outcomes in patients.^155^ It compared surgical excision (A), MMS (B), and electrodessication and curettage (C3). Among the 936 examined lesions, 80 percent (n=748) were BCC and 20 percent (n=188) were SCCs. The risk of confounding bias of this study was determined to be low with differences at baseline controlled for in multivariate analysis, and no loss to followup. Females accounted for 59.4 percent of the population. Overall, 60.1 percent (n=563) of tumors in the study sample presented on the head and neck. Of these, the majority (56.3%) was treated by MMS; the majority (69.3%) of tumors presenting on the trunk and extremities were treated with electrodessication and curettage (ED&C). Similarly, 31.5% (295) of tumors presented in the H-zone, with the majority (80%) of these treated with MMS, compared to a majority (36.8% and 36.2%) of tumors not in the H-zone treated with ED&C and surgical excision, respectively. Differences in histology of the tumors and tumor diameter across treatment types were not observed to be statistically significant.

In both adjusted and unadjusted analyses of total surgical care, there was a statistically significant difference (p<0.001) in costs by treatment type. MMS treatments were observed to have the highest primary procedure and follow-up visit costs compared to excision (by, on average, $857 in adjusted analyses). Excision had the second highest costs for both primary procedure and follow-up visit, and ED&C had the lowest. Also, in both adjusted and unadjusted analyses, total fees for all surgical care were significantly higher for large tumors (>10 mm) and for H-zone locations. Independent predictors of higher total costs were determined using multivariate regression log models and included presentation of tumor at the head or neck, greater than 10mm lesion diameter, and repair with flap or graft. However, the study did not take fees related to recurrence into account.^155^

### Adverse Events, All BCC Lesions

In this section we describe only results between intervention categories, because data are sparse for the comparison of individual observations. Figure 12 shows the evidence graph for the comparison of the frequency of adverse events leading to discontinuation, serious adverse events, pain after treatment completion, and infection of the treated site. Reporting of adverse events was not consistent across RCTs. Appendix I enumerates other types of adverse events that were reported.

Figure 12 Evidence graph of RCTs comparing frequency of adverse events (all BCC lesions)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; BCC = basal cell carcinoma

Figure 12. (A) This is the coarse topology map of the network meta-analysis of the different types of interventions for adverse events leading to treatment discontinuation for all BCCs compared in seven RCTs. The five intervention types include surgical (excision or Mohs), thermodynamic, PDT, medical/drugs, and no treatment/placebo. Of the 10 possible pairwise comparisons, 4 are covered by direct study comparisons. Surgical excision is connected to PDT and drugs; PDT is also connected to thermodynamic; and drugs are connected to placebo/no treatment. (B) This is the coarse topology map of the network meta-analysis of the different types of interventions for serious adverse events for all BCCs compared in seven RCTs. The five intervention types include surgical (excision or Mohs), thermodynamic, PDT, medical/drugs, and no treatment/placebo. Of the 10 possible pairwise comparisons, 4 are covered by direct study comparisons. Surgical excision is connected to PDT and drugs; PDT is also connected to thermodynamic; and drugs are connected to placebo/no treatment. (C) This is the coarse topology map of the network meta-analysis of the different types of interventions for pain for all BCCs compared in 11 RCTs. The five intervention types include surgical (excision or Mohs), radiation, PDT, medical/drugs, and no treatment/placebo. Of the 10 possible pairwise comparisons, 6 are covered by direct study comparisons. Surgical excision is connected to PDT and drugs; PDT is also connected to placebo/no treatment; and drugs are also connected to placebo/no treatment and radiation. (D) This is the coarse topology map of the network meta-analysis of the different types of interventions for infection at the treatment site for all BCCs compared in three RCTs. The three intervention types include surgical (excision or Mohs), PDT, and medical/drugs. Of the 3 possible pairwise comparisons, 3 are covered by direct study comparisons. PDT is connected to both surgical excision and drugs.

The evidence graphs in Figure 12 are sparsely connected. For parsimony, we do not report relative effects for comparisons of the frequency of each type of adverse event. Table 56 has details about the comparisons by type of adverse event.

Table 56 Sample information, adverse events (all BCC lesions, intervention categories)

| Adverse events leading to treatment discontinuation^51, 52, 55, 68, 85, 92, 94^ | Serious adverse events^20, 49, 52, 55, 58, 94, 98^ | Pain after treatment^49, 52, 54, 55, 66, 67, 69, 85, 93, 94, 98^ | Infection of treated site^49, 85, 98^
Studies (total sample) | 7 (1733) | 7 (1395) | 12 (1612) | 3 (682)
Total sample by intervention | (A,B): 287; (E): 120; (F): 782; (I,J): 486; (C): 58 | (A,B): 413; (E): 397; (F): 523; (I,J): 44; (C): 18 | (D): 12; (F): 705; (I,J): 176; (E): 340; (A,B): 351 | (E): 348; (F): 189; (A,B): 145
Total sample by intervention, (min, max) | 58, 782 | 18, 523 | 12, 705 | 145, 348
Data by comparison | (A,B--E): 1 (118); (A,B--F): 1 (483); (E--C): 1 (118); (F--I,J): 4 (1014) | (A,B--E): 2 (369); (A,B--F): 1 (483); (E--F): 1 (385); (E--C): 1 (34); (F--I,J): 2 (124) | (D--F): 1 (27); (F--I,J): 5 (379); (F--E): 1 (339); (F--A,B): 1 (439); (I,J--E): 1 (131); (E--A,B): 2 (297) | (E--F): 1 (385); (E--A,B): 2 (297)
Studies by comparison (min, max) | 1, 4 | 1, 2 | 1, 5 | 1, 2
Total sample by comparison (min, max) | 118, 1014 | 34, 483 | 27, 439 | 297, 385
Followup median (min, max) | [during treatment] | 12 (1, 60) months | 3 (0.5, 12) months | 3 (1, 12) months

A = surgical excision; B = Mohs micrographic surgery; BCC = basal cell carcinoma; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

We report mean fractions of adverse events per intervention category, based on a joint analysis of all RCTs reporting the same outcome. Most likely, adverse events were defined differently across studies, but these definitions were often not clearly described. Results for adverse events, as defined by each study, are in Table 57 and come from different analyses.

Table 57 Mean fractions of adverse events, using each RCT’s definitions (all BCC lesions)

Intervention Type | Leading to Discontinuation (Figure 12A) | | Serious^*^ (Figure 12B) | Pain After Treatment (Figure 12C) | | Infection of the Treated Site^*^ (Figure 12D)
Intervention Type | Mean | Forecast | Mean | Mean | Forecast | Mean
Surgery/MMS (A,B) | Not defined^**^ | Not defined^**^ | 0.6 (0.1, 2.7) | 21.5 (8.1, 46.2) | 21.5 (1.7, 81.5) | 5.5 (2.8, 10.7)
Heat/cold (C) | 0.9 (0.0, 20.1) | 0.9 (0.0, 29.0) | 2.6 (0.1, 36.7) | 12.9 (0.8, 73.1) | 12.9 (0.3, 87.5) | NA
PDT (E) | Not defined^**^ | Not defined^**^ | 0.7 (0.1, 3.0) | 20.7 (8.2, 43.3) | 20.7 (1.6, 80.3) | 0.5 (0.1, 2.4)
Drugs (F) | 4.9 (2.0, 11.6) | 4.9 (0.6, 29.2) | 2.2 (0.8, 6.4) | 9.9 (4.4, 20.9) | 9.9 (0.7, 61.6) | 0.5 (0.1, 3.7)
No/sham treatment (I,J) | 1.0 (0.2, 4.4) | 1.0 (0.1, 9.8) | 2.4 (0.3, 17.8) | 2.9 (0.9, 9.4) | 2.9 (0.2, 33.5) | NA

Note: Results are given as percent and 95% confidence interval.

MMM = Mohs micrographic surgery; PDT = photodynamic therapy; RCT = randomized controlled trial; BCC = basal cell carcinoma

* No forecasts for these outcomes (fixed effects analyses only); NA: not applicable.

** Surgical interventions and PDT are one-time procedures and cannot be “discontinued”; for parsimony of exposition, however, in the descriptive analyses in the Table we assigned 0 discontinuation events to these interventions.

Drugs had the highest frequency of adverse events leading to treatment discontinuation was (4.9%; 95% CI, 2.0 to 20.1); for other interventions, it was less than 1.2 percent. Surgical interventions and PDT are one-time procedures and cannot be “discontinued”; for parsimony of exposition, however, in the descriptive analyses in Table 57 we assigned 0 discontinuation events to these interventions.

The frequency of adverse events characterized as “serious” by the investigators was smaller than 3.6 percent for all intervention categories.

Pain after treatment was most commonly encountered for surgical interventions (21.5%) and for PDT (20.7%), and was least common with sham treatments (2.9%).

Infections at the treatment site were described in 5.5 percent of lesions with surgical treatments (95% CI 28 to 10.7), and were reported in less than 1 percent for PDT (E) and drugs (F). No information on infections was available for treatments that destroy lesions with heat or cold (C) or for no (or sham) treatment.

#### Evidence From NRCSs

Results on the frequency of adverse events are reported in three NRCSs.^151, 153, 154^

The first NRCS reported on adverse events in 12 patients with 1 superficial BCC each. The mean lesion area was 52 mm^2^, and the lesions were located on the trunk or neck (67%) or forearm (33%). This study was deemed to have high risk of confounding bias, because of baseline imbalance. The mean age was 61 (range 52 to 78), and 33% were female. Six lesions were treated with imiquimod (F2) and six with a vehicle (J). More people in the vehicle arm (3 of 6) reported application site adverse events than in the imiquimod arm (2 of 6) during treatment, both erythemas.^154^

The second NRCS reported on adverse events in 74 patients with 1 nodular BCC each, receiving different doses of vismodegib (F5, other drug). It was deemed that this study was at moderate risk of confounding bias; it was not blinded, and it was not possible to assess for baseline (im)balance, because pertinent information was not reported. The lesion diameter ranged from 10 to 30 mm, and all were located in the scalp, head, neck, trunk or limbs. The mean age was 63.6 (SD 12; range 40 to 89), and 22 percent were female; 99 percent were white. Twenty-four lesions were treated with vismodegib for 12 weeks then were excised; twenty-five were treated with vismodegib for 12 weeks then had a 24-week observation period before excision; and 25 were treated with vismodegib for 16 weeks then were excised. Just about everyone (99%) reported at least one adverse event, including muscle spasms (76%), alopecia (58%), and changes in tasting, namely dysgeusia (50%) and ageusia (30%).^153^

The third NRCS reported results for any adverse events, from 12 to a median of 31.8 months after treatment with two doses of (orthovoltage) radiation therapy (D1). The risk of bias was determined to be low; arms were well-balanced at baseline, outcome assessors were blinded, and no patients were lost to followup. The lower-dose group (36 Gy) had fewer adverse events (5.9% as compared to 4.0% in the 45 Gy group), but no adjusted analysis was available for this outcome.^151^

### Dose Response Analyses for Drugs, All BCC Lesions

Table 58 summarizes analyses from phase II or phase II/III trials on different doses or application schedules for drugs (F), stratified by whether the patients had superficial, nodular, or a mix of superficial and nodular BCC lesions in 16 studies.^48, 54, 61–63, 68, 69, 74, 76, 82, 93, 94, 97, 100, 101^ Results cannot be combined across these studies in a straightforwardly interpretable way. Overall, the general pattern was that, with increasing intensity of treatment (higher doses or more applications) there was an apparent increase in the frequency of adverse events; but it is not always clearly reported whether this was statistically significant or not.

Table 58 Summary of phase II or II/III trials comparing different doses or intensities of application schedules for drugs (all BCC lesions)

PMID Author | Arm1 (n) | Arm2 (n) | Arm3 (n) | Arm4 (n) | Arm5 (n) | Arm6 (n) | Arm7 (n) | Authors’ Conclusion
Superficial Lesions
12196749 Geisse | Vehicle (32) | Imiquimod 5% 3x/wk (29) | Imiquimod 5% 5x/wk (26) | Imiquimod 5% 1x/day (31) | Imiquimod 5% 2x/day (10) | | | “There was a positive association between dosing frequency and complete response rate; higher response rates were associated with more frequent dosing…An acceptable safety profile was seen in 3 of the 4 imiquimod dosing regimens. Only the most frequent dosing regimen, twice daily for 12 weeks, presented a safety profile that was judged not acceptable because of severe local skin reactions at the treatment site.”^69^
15097956 Geisse | Vehicle 5x/wk (175) | Vehicle 7x/wk (171) | Imiquimod 5% 5x/wk (178) | Imiquimod 5% 7x/wk (170) | | | | “The results from these Phase III studies confirm that imiquimod has higher complete clearance rates than vehicle cream for each of the active treatment groups. Additionally, there was not a statistically significant or clinically meaningful difference in complete clearance rate noted between the imiquimod 5/week and 7/week (73% composite and 79% histologic) treatment groups.”^69^
11312429 Marks | Imiquimod 5% 1x/day (33) | Imiquimod 5% 2x/day (3) | Imiquimod 5% 1x/day 3x/wk (33) | Imiquimod 5% 2x/day 3x/wk (30) | | | | “There was a dose-response gradient varying from 3 of 3 (100%) in the twice-every-day regimen group to 23/33 (69.7%) in the once-daily 3 times/week regimen group…This study confirms previous work suggesting that imiquimod 5% cream is likely to be of value in the treatment of sBCC.”^74^
20546215 Siller | Vehicle (12) | Ingenol mebutate 0.0025% Days 1 and 2 (8) | Ingenol mebutate 0.01% Days 1 and 2 (8) | Ingenol mebutate 0.05% Days 1 and 2 (8) | Ingenol mebutate 0.0025% Days 1 and 8 (8) | Ingenol mebutate 0.01% Days 1 and 8 (8) | Ingenol mebutate 0.05% Days 1 and 8 (8) | The study was not powered to detect differences in treatment concentration and schedule, but the clinical and histological response was more common in 0.05% 1&2 day application compared to other doses or 0.05% 1&8 day application.^94^
12452875 Sterry | Imiquimod 5% 2x/wk without occlusion (24) | Imiquimod 5% 2x/wk with occlusion (21) | Imiquimod 5% 3x/wk without occlusion | Imiquimod 5% 3x/wk with occlusion | | | | “The complete response rate increased as dosing frequency increased, both with and without occlusion. However, the only statistically significant difference in response rate was seen when comparing the 2 days per week with occlusion and 3 days per week with occlusion groups (P = 0.004).”^97^
Nodular lesions
17610993 Eigentler | Imiquimod 5% 3x/wk for 8 weeks (45) | Imiquimod 5% 3/wk for 12 weeks (45) | | | | | | “There were no significant differences between the treatment arms with respect to efficacy and tolerability.”^63^
1430394 Orenberg | 5-FU 7.5 mg | 5-FU 15 mg | | | | | | “Application of Fisher’s exact test showed no differences in response between the treatment groups.”^82^
12224977 Shumack 12 weeks | Vehicle (24) | Imiquimod 5% 1x/day 3x/wk (20) | Imiquimod 5% 1x/day 5x/wk (23) | Imiquimod 5% 1x/day 7x/wk (21) | Imiquimod 5% 2x/day 7x/wk | | | “An increase in the complete response rate was seen with increasing dosing frequency. This increase was statistically significant (P.001) based on the Cochran-Armitage test for trend (2-sided).”^93^
12224977 Shumack 6 weeks | Imiquimod 5% 1x/day 3x/wk (32) | Imiquimod 5% 2x/day 3x/wk (31) | Imiquimod 5% 1x/day 7x/wk (35) | Imiquimod 5% 2x/day 7x/wk (1) | | | | “The highest complete response rate was seen in the once-daily dosing group. No statistically significant dose-response trend was detected.”^93^
12452875 Sterry | Imiquimod 5% 2x/wk without occlusion (24) | Imiquimod 5% 2x/wk with occlusion (21) | Imiquimod 5% 3x/wk without occlusion | Imiquimod 5% 3x/wk with occlusion | | | | “No significant differences of complete response rate were detected between the four treatment groups (P = 0.700).”^97^
Mixed lesions
8708151 Alpsoy | IFN alfa-2b (15) | IFN alfa-2a plus IFN alfa-2b (15) | | | | | Mixed | “IFN alfa provides a safe and effective treatment for nodular and superficial BCC…The effectiveness is not increased by combining IFN alfa-2a and 2b.”^48^
10570388 Beutner | Imiquimod 5% 2x/day (7) | Imiquimod 5% 1x/day (4) | Imiquimod 5% 3x/wk (4) | Imiquimod 5% 2x/wk (5) | Imiquimod 5% 1x/wk (4) | | Mixed | “The response of BCC to imiquimod noted in this pilot study appears to be excellent.”^54^
2107219 Edwards | IFN gamma 900,000 IU (14) | | | | | | Mixed | “Although 76% of our subjects had one or more side effects, these were generally minor and were not dose related. It is likely that higher doses of interferon gamma injected intralesionally into basal cell carcinomas would produce a higher, perhaps clinically important, cure rate but might not result in a significant increase in side effects.”^62^
2383027 Edwards | IFN alfa-2b 30 million IU 3x (32) | | | | | | Mixed | “Side effects were similar for both single and repeated dosage groups, and were those common to interferon… Side effects were similar for both single and repeated dosage groups, and were those common to interferon.”^61^
8996264 Miller | 5-FU 0.5 ml 1x/wk for 6 wk (21) | 5-FU 1.0 ml 2x/wk for 3 wk (18) | 5-FU 0.5 ml 2x/wk for 3 wk (19) | 5-FU 0.5 ml 2x/wk for 4 wk (21) | 5-FU 0.5 ml 3x/wk for 2 wk (17) | | Mixed | “The intralesional administration of 5-FU/epi gel proved to be safe and effective in treating nodular and superficial BCCs. All regimens appeared to work well and there were no statistically significant differences among them.”^76^
15606733 Torres | Mohs plus Imiquimod 5% 5x/wk for 2 wk (12) | Mohs plus Imiquimod 5% 5x/wk for 4 wk (12) | Mohs plus Imiquimod 5% 5x/wk for 6 wk (12) | | | | Mixed | “The application of 5% imiquimod cream before excision with Mohs micrographic surgery significantly reduced the size of the target tumor and resulted in a smaller surgical defect from the Mohs micrographic surgery excision (compared to vehicle groups)…the study was not designed and the sample sizes were not large enough to adequately characterize an imiquimod dose–duration response curve.”^100^
22511036 Tran | PDL 15 J/cm^2^ (7) | PDL 7.5 J/cm^2^ (7) | | | | | Mixed | Neither dose was statistically significantly different from the control group. “The results of our pilot study suggest that BCCs and SCCIS can be cleared in a single treatment using a pulsed-laser in a stacked pulse setting. However, given the small sample size of this pilot study, further larger scale studies will be needed to determine statistical significance and long-term recurrence rate and to further validate these findings.”^101^

PDL = pulsed-dye laser; BCC = basal cell carcinoma; SCCIS = squamous cell carcinoma; x/wk = times per week; FU = fluorouracil; IFN = interferon

### Special Populations

No studies reported comparative results in special populations of interest, specifically patients at the end of life or immunocompromised patients.

## Squamous Cell Carcinoma

The evidence graph in Figures 13 and 14 depict eight comparisons between 10 interventions organized in four intervention categories. Comparisons between individual interventions are sparse, suggesting that limited, if any, conclusions can be drawn about which individual treatment is best for each outcome. Figure 13 has two connected subgraphs. The smallest one compares a laser-based preparation of the lesion for PDT treatment (C5+E2) versus PDT alone (E2), and the other comprises all other treatments. Information on each comparison is provided by at most three RCTs, and for most comparisons, by a single RCT.

Figure 13 Evidence graph depicting compared treatments in RCTs of SCC lesions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 13. This is the topology map of the network meta-analysis of the interventions for all SCCs compared in six RCTs. Ten interventions are displayed, grouped by type of intervention. The interventions are: thermodynamic (cryotherapy, laser), PDT (MAL or ALA), drugs (5-FU, imiquimod), and placebo; or combinations of these (laser and MAL PDT, laser and ALA PDT, cryotherapy and 5-FU). Of the 45 possible pairwise comparisons, 7 are covered by direct study comparisons in the primary graph. Most comparisons were covered by only a single RCT, and most treatment were compared with only one or two (or in one case, MAL PDT, three) other treatments. The comparison for laser therapy plus ALA PDT versus ALA PDT alone is presented in a separate subgraph.

Figure 14 Evidence graph depicting compared treatment types in RCTs of SCC lesions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy

Figure 14. This is the topology map of the network meta-analysis of the types of interventions for all SCCs compared in six RCTs. Four types of interventions are displayed: thermodynamic, PDT, drugs, and placebo. Of the six possible pairwise comparisons, five are covered by direct study comparisons in the primary graph. Most comparisons were covered by only a single RCT, and most treatment were compared with only one or two (or in one case, PDT, three) other treatments.

The evidence is sparser when one considers the information that is actually available for specific outcomes. Figure 15 shows the corresponding evidence graphs for the outcomes for which we have the most data, namely recurrence, lack of histologic clearance, and lack of clinical clearance. RCT data exists for only 7, 4, and 8 of the 28 interventions, respectively. Evidence on other outcomes (quality of life, cosmetic outcomes, costs or resource use) is even sparser.

Figure 15 Evidence graphs for recurrence, histologic clearance, and clinical clearance for RCTs of SCC lesions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 15. (A) Recurrence: This is the topology map of the network meta-analysis of recurrence for all SCCs compared in four RCTs. Seven interventions are displayed, grouped by type of intervention. The interventions are: thermodynamic (cryotherapy, laser), PDT (MAL or ALA), drugs (5-FU), and placebo; or combinations of these (laser and MAL PDT, crypotherapy and 5-FU). Of the 21 possible pairwise comparisons, six are covered by direct study comparisons. MAL PDT is compared to cryotherapy plus 5-FU, laser plus MAL PDT, and placebo; ALA PDT is compared to cryotherapy and 5-FU; and cryotherapy plus 5-FU was also compared to placebo. (B) Lack of histological clearance: This topology map contains only two disconnected comparisons from two RCTs: laser is compared to laser plus ALA PDT, and imiquimod is compared to a placebo. (C) Lack of clinical clearance: This is the topology map of the network meta-analysis of lack of clinical clearance for all SCCs compared in five RCTs. Eight interventions are displayed, grouped by type of intervention. The interventions are: thermodynamic (cryotherapy, laser), PDT (MAL or ALA), drugs (5-FU, imiquimod), and placebo. Of the 28 possible pairwise comparisons, seven are covered by direct study comparisons. MAL PDT is compared to cryotherapy plus 5-FU, laser plus MAL PDT, and placebo; ALA PDT is compared to cryotherapy and 5-FU; and cryotherapy plus 5-FU was also compared to placebo, as was imiquimod.

We identified one NRCS comparing curettage (H) versus cryotherapy (C1) in patients with SCC lesions. This study is described separately.^141^

The characteristics of the six included RCTs are summarized in Table 59. All RCTS included only participants with SCC in situ (SCCIS).

Table 59 Characteristics of studies of SCC populations

Study | Arm | Age, Mean | Female % | Lesion Size, Mean | Lesion Location (%) | 1^*^ Adequate Randomization | 2^*^ Allocation Concealment | 3^*^ Arms Similar at Baseline | 4^*^ Patients Blinded | 5^*^ Providers Blinded | 6^*^ Outcome Assessors Blinded | 7^*^ <20% Loss to Followup
SCCIS
Cai 2015 25899562 | ALA-PDT + CO2 Laser | NR | 50 | 2.62 cm | NR | Unsure | Yes | Yes | Unsure | Yes | Yes | Yes
Cai 2015 25899562 | CO2 Laser | NR | 62.5 | 2.58 cm | NR | Unsure | Yes | Yes | Unsure | Yes | Yes | Yes
Ko 2014 24102369 | Er:YAG AFL PDT | 68.9 | 52.4 | NR | extremities (100) | Unsure | No | Yes | No | Unsure | Yes | Yes
Ko 2014 24102369 | MAL-PDT | 68.9 | 52.4 | NR | extremities (100) | Unsure | No | Yes | No | Unsure | Yes | Yes
Morton 1996 8977678 | cryotherapy | 76 | 84 | 82 mm^2^ | hands (5), face (15), legs (80) | No | No | Yes | No | No | No | No
Morton 1996 8977678 | ALA-PDT | 76 | 84 | 150 mm^2^ | hands (5), face (10), legs (85) | No | No | Yes | No | No | No | No
Morton 2006 16785375 | MAL PDT | 71.9 | 62 | 18.9 mm | face/scalp (23), extremities (65), trunk/neck (12) | No | No | Unsure | No | No | No | Yes
Morton 2006 16785375 | PDT placebo | 73.4 | 65 | 19.3 mm | face/scalp (25), extremities (67), trunk/neck (8) | No | No | Unsure | No | No | No | Yes
Morton 2006 16785375 | Cryotherapy | 74 | 59 | 19.4 mm | face/scalp (29), extremities (57), trunk/neck (14) | No | No | Unsure | No | No | No | Yes
Morton 2006 16785375 | Fluorouracil | 72.5 | 63 | 20.9 mm | face/scalp (19), extremities (69), trunk/neck (11) | No | No | Unsure | No | No | No | Yes
Patel 2006 16713457 | imiquimod 5% | 74 | 40 | 429 mm^2^ | NR | Yes | Yes | No | Yes | Yes | Yes | No
Patel 2006 16713457 | vehicle | 74 | 87.5 | 248 mm^2^ | NR | Yes | Yes | No | Yes | Yes | Yes | No
Salim 2003 12653747 | PDT | 76 | 80 | NR | extremities (100) | No | No | No | No | No | No | Yes
Salim 2003 12653747 | 5-FU | 76 | 80 | NR | face (12), extremities (88) | No | No | No | No | No | No | Yes
SCC microinvasive
Choi 2017 28199463 | MAL-PDT | 75.1 | 54.6 | 11.8 mm | Face or scalp (75.0), extremities (16.7), trunk/neck (8.3) | Yes | No | Yes | No | No | Yes | Yes
Choi 2017 28199463 | MAL-PDT + Er:YAG | 76.4 | 71.4 | 11.5 mm | Face or scalp (76.2), extremities (19.0), trunk/neck (4.8) | Yes | No | Yes | No | No | Yes | Yes

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon; SCC = squamous cell carcinoma; Er:YAG = ablative fractional laser; NR = not reported

* Design items: 1: Adequate generation of a randomized sequence reported; 2: Adequate allocation concealment reported; 3: Group similarity at baseline; 4: Adequate blinding of patients reported; 5: Adequate blinding of providers reported; 6: Adequate blinding of outcome assessors reported; 7: Less than 20% missing for any eligible outcome in any arm. PDT=photodynamic therapy.

Across all trials, the mean or median age of enrollees ranged between 68.9 and 76 (median 74, 25^th^–75^th^ percentile: 72.4 to 76). The proportion of female patients ranged between 40 and 87.5 percent (median 62.8, 25^th^–75^th^ percentile: 54 to 80). When reported, the mean or median lesion area was between 82 and 429 mm^2^, and the maximum diameter was between 18.9 and 26.2 mm. The majority of RCTs included lesions in various body locations, and only a few reported results stratified by lesion location (discussed separately). Based on this information, the RCTs included patients and lesions are typically encountered in clinical practice. No RCT focused on patients who were immunocompromised or had substantially limited life expectancy.

In terms of design characteristics, five RCTs had two arms and one had three arms. Analyzed sample sizes ranged between 18 and 209 (median=23.5, 25^th^–75^th^ percentile: 18.25 to 37); sample sizes per RCT arm ranged between 11 and 91. Based on what was reported in the RCTs, we deemed that the allocation sequence was randomized using formal methods in one and successfully concealed in two RCTs, and that patients, providers, and outcome assessors were successfully blinded to the received treatments in one, two, and three RCTs, respectively. Our consensus assessment of the reported baseline characteristics across the compared arms in each RCT was that half of the RCTs (n=3) had arms that were likely balanced at baseline. In four RCTs fewer than 20 percent of patients had missing outcomes for any eligible outcome in any arm.

### Recurrence, SCCIS Lesions

The evidence graph for recurrence with respect to individual treatments is sparse (Figure 15 (A) – reproduced in Figure 16 (A) for ease of reference). Detailed results at the RCT-level are in Appendix I.

Figure 16 Evidence graph of RCTs evaluating recurrence in SCCIS across (A) individual interventions and (B) types of interventions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon; SCCIS = squamous cell carcinoma in situ

Figure 16. (A) This is the topology map of the network meta-analysis of recurrence for all SCCs compared in four RCTs. Seven interventions are displayed, grouped by type of intervention. The interventions are: thermodynamic (cryotherapy, laser), PDT (MAL or ALA), drugs (5-FU), and placebo; or combinations of these (laser and MAL PDT, crypotherapy and 5-FU). Of the 21 possible pairwise comparisons, six are covered by direct study comparisons. MAL PDT was compared to cryotherapy plus 5-FU, laser plus MMAL PDT, and placebo; ALA PDT was compared to cryotherapy and 5-FU; and cryotherapy plus 5-FU was also compared to placebo. (B) This is the topology map for recurrence of the network meta-analysis of the types of interventions for all SCCs compared in four RCTs. Four types of interventions are displayed: thermodynamic, PDT, drugs, and placebo. Of the six possible pairwise comparisons, four are covered by direct study comparisons in the primary graph: PDT is compared to thermodynamic, drug, and placebo; and thermodynamic is compared to placebo.

#### Comparisons Across Intervention Categories

In total, 4 RCTs (348 lesions) were included in this analysis.^72, 79, 80, 89^ Two RCTs were deemed to be at low or moderate risk of bias. The comparisons are described in Table 60.

Table 60 Sample information, recurrence (SCCIS, intervention categories)

Studies (total sample) | 4 (348)
Total sample by intervention | (C): 136; (E): 175; (F): 33; (I,J): 4
Total sample by intervention, (min, max) | 4, 175
Data by comparison | (C--E): 3 (278); (C--I,J): 1 (101); (E--F): 1 (66); (E--I,J): 1 (107)
Studies by comparison (min, max) | 1, 3
Total sample by comparison (min, max) | 66, 278
Followup median (min, max) | 12 (12, 24) months

A = surgical excision, B = Mohs micrographic surgery; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo; SCCIS = squamous cell carcinoma in situ

Table 61 shows the relative odds ratios for recurrence across intervention categories. Based on direct data, the odds ratio for recurrence is not statistically significantly different between interventions that destroy the lesions with heat or cold (C) and PDT (E); however, the confidence interval does not exclude differences in the odds as large as 50 percent in either direction. Based on direct data, the odds ratio between PDT (E) and drugs (F) is statistically significant, favoring PDT.

Table 61 Relative odds ratios for recurrence between intervention categories (SCCIS lesions, Figure 16B)

Heat/cold (C) | 0.83 (0.33, 2.06) | 0.17 (0.05, 0.55) | 0.18 (0.02, 1.59)
1.21 (0.49, 3.01) | PDT (E) | 0.20 (0.07, 0.62) | 0.22 (0.03, 1.86)
5.96 (1.81, 19.61) | 4.93 (1.6, 15.15) | Drugs (F) | 1.06 (0.11, 10.44)
5.61 (0.63, 50.1) | 4.64 (0.54, 39.96) | 0.94 (0.1, 9.25) | No/sham treatment (I,J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates that the result is statistically significant. Results are given as odds ratios (95% confidence intervals).

PDT = photodynamic therapy; SCCIS = squamous cell carcinoma in situ.

In the table, shaded cells correspond to comparisons that have been inferred from the analysis model, but that have not been examined in the included RCTs. For example, comparisons of drugs (F) and interventions that destroy the lesion with heat or cold (E) are indirect, and have very wide confidence intervals. For all comparisons that are empirically observed (all nonshaded cells in the table), results using only head-to-head data agree well with the results from the network meta-analysis in Table 61.

Table 62 offers complementary information from the same analysis. For each intervention category, it shows the mean recurrence rate across the included RCTs. Interventions that destroy the lesion with heat or cold (C) and PDT (E) had on average lower recurrence rates (15.1% and 17.7%, respectively) compared to the other treatments. These estimates describe the outcome rates in the RCT arms, and are based on the relative effects in Table 61 and the observed baseline rates in the RCTs. Of note, the recurrence rate for drugs is 51.5 percent (95% CI 28.9 to 73.5), reflecting the high recurrence rates observed in the single RCT comparing 5-FU with PDT (ALA) in this analysis.

Table 62 Mean recurrence rates by intervention category (SCCIS lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
Heat/cold (C) | 15.1 (8.1, 26.5) | 15.1 (6.3, 32.1)
PDT (E) | 17.7 (10.8, 27.8) | 17.7 (8.1, 34.4)
Drugs (F) | 51.5 (28.9, 73.5) | 51.5 (24.7, 77.5)
No/sham treatment (I,J) | 50.0 (11.2, 88.8) | 50.0 (10.1, 89.9)

PDT = photodynamic therapy; SCCIS = squamous cell carcinoma in situ; CI = confidence interval

#### Comparisons Across Individual Interventions

As is evident from Figure 16, there are two connected subgraphs for this outcome: a smaller one comprising the comparison among cryotherapy (C1), MAL with ALA (E2), and 5-FU (F1), and a larger one among PDT with MAL with and without laser preparation (E1 and C5+E1), cryotherapy with 5-FU (C1+F1), and placebo. In total, 4 RCTs (348 lesions) were included in these analyses, as summarized in Table 63.

Table 63 Sample information, recurrence (SCCIS, interventions)

| First subgraph^72, 79^ | Second subgraph^80, 89^
Studies (total sample) | 2 (242) | 2 (106)
Total sample by intervention | (C5+E1): 19; (E1): 122; (C1+F1): 97; (J): 4 | (C1): 20; (E2): 53; (F1): 33
Total sample by intervention, (min, max) | 4, 122 | 20, 53
Data by comparison | (C5+E1--E1): 1 (38); (E1--C1+F1): 1 (200); (E1--J): 1 (107); (C1+F1--J): 1 (101) | (C1--E2): 1 (40); (E2--F1): 1 (66)
Studies by comparison (min, max) | 1, 1 | 1, 1
Total sample by comparison (min, max) | 38, 200 | 40, 66
Followup (min, max) | (12, 12) months | (12, 24) months

A = surgical excision; B = Mohs micrographic surgery; C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; C5 = laser; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F1 = 5-FU; F2 = Imiquimod; F3 = Interferon; F4 = Ingenol; H = curettage; J = placebo; SCCIS = squamous cell carcinoma in situ

Table 64 shows the relative effects for both subgraphs. Because the comparisons across individual observations are sparse, however, the confidence intervals of the odds ratios for most indirect comparisons are very broad and cannot exclude very large differences between the compared interventions.

Table 64 Relative odds ratios for recurrence between individual interventions (SCCIS lesions, Figure 16A)

Cryotherapy + 5-FU (C1+F1) | 6.14 (0.48, 77.78) | 1.12 (0.31, 3.96) | 0.24 (0.02, 2.48)
0.16 (0.01, 2.06) | Laser + PDT (MAL) (C5+E1) | 0.18 (0.02, 1.95) | 0.04 (<0.005, 0.94)
0.9 (0.25, 3.18) | 5.5 (0.51, 58.9) | PDT (MAL) (E1) | 0.22 (0.02, 2.13)
4.11 (0.4, 41.76) | 25.2 (1.06, 598.92) | 4.58 (0.47, 44.79) | Placebo/sham (J)
| | | | Cryotherapy (C1) | 1.34 (0.06, 28.22) | 0.19 (0.01, 5.5)
| | | | 0.75 (0.04, 15.75) | PDT (ALA) (E2) | 0.14 (0.01, 1.55)
| | | | 5.27 (0.18, 153) | 7.06 (0.65, 77.1) | 5-FU (F1)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates that the result is statistically significant. Results are given as odds ratios (95% confidence intervals).

PDT (MAL) = methyl aminolaevulinate photodynamic therapy; PDT (ALA )= aminolevulinic acid photodynamic therapy; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ

Table 65 shows, for each intervention, the mean recurrence rates across all RCTs; estimates for interventions in both subgraphs are listed in the table. It was not possible to compare statistically the estimated recurrence rates between an intervention in the first subgraph (e.g., PDT with MAL [E1]) and the second subgraph (e.g., cryotherapy [C1]), because they come from disjoint analyses.

Table 65 Mean and forecasted recurrence rates by intervention category (SCCIS lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
First subgraph (Figure 16)
Cryotherapy + 5-FU (C1+F1) | 22.4 (8.0, 48.8) | 22.4 (5.3, 60.0)
Laser + PDT (MAL) (C5+E1) | 4.5 (0.5, 31.6) | 4.5 (0.4, 37.6)
PDT (MAL) (E1) | 20.5 (9.0, 40.3) | 20.5 (5.5, 53.3)
Placebo/sham (J) | 54.2 (11.2, 91.8) | 54.2 (8.8, 93.6)
Second subgraph (Figure 16)
Cryotherapy (C1) | 13.0 (1.1, 67.2) | 13.0 (0.5, 82.5)
PDT (ALA) (E2) | 10.1 (1.5, 45.3) | 10.1 (0.5, 69.4)
5-FU (F1) | 44.1 (7.5, 88.5) | 44.1 (3.1, 95.1)

PDT (MAL) = methyl aminolaevulinate photodynamic therapy; PDT (ALA) = aminolevulinic acid photodynamic therapy; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ; CI = confidence interval

#### Recurrence, Other Subgroup Analyses (Lesion Location, Lesion Size)

##### Evidence From RCTS

Table 66 below shows results on subgroup analyses for a four-arm RCT.^77, 79^ Neither lesion location nor size were associated with differences in the treatment effect beyond what is expected by chance.

Table 66 Subgroup analyses by lesion location and size: results for recurrence (SCCIS lesions)

Study | Comparison | Timepoint | Subgroup | n/N Arm 1 vs. n/N Arm 2 vs. n/N arm 3 | OR (95% CI); P-Value Within | P-Value Between
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | 12 months | lesion location: extremities | 11/60 vs. 11/63 vs. 0/1 | 1.06 (0.42, 2.67); 0.70 (0.03, 18.23); 0.66 (0.03, 17.18); p=1.000 | p=0.483
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | 12 months | lesion location: face/scalp | 6/22 vs. 2/27 vs. 1/2 | 4.69 (0.84, 26.15); 0.38 (0.02, 7.00); 0.08 (0.00, 1.82); p=0.084 | p=0.483
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | 12 months | lesion location: neck/trunk | 2/15 vs. 2/13 vs. 1/1 | 0.85 (0.10, 7.04); 0.06 (0.00, 1.99); 0.07 (0.00, 2.35); p=0.209 | p=0.483
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | 12 months | lesion diameter: 5–14 mm | 0/27 vs. 4/40 vs. 1/1 | 0.15 (0.01, 2.86); 0.01 (0.00, 0.43), 0.04 (0.00, 1.17); p=0.018 | NA
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | 12 months | lesion diameter: 15–29 mm | 15/55 vs. 5/43 vs. 1/3 | 2.85 (0.94, 8.61); 0.75 (0.06, 8.89); 0.26 (0.02, 3.46); p=0.093 | NA
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | 12 months | lesion diameter: >= 30 mm | 3/12 vs. 6/20 vs. 0/0 | 0.78 (0.15, 3.93); NA; p=1.000 | NA

NA = not significant; PDT (MAL) = methyl aminolaevulinate photodynamic therapy; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ

##### Evidence From NRCSs

One NRCS reported recurrence for 80 SCCIS lesions in 67 people, treated with either curettage (44 lesions) or cryotherapy (36 lesions). This study was deemed to be of high risk of bias, primarily for lack of reporting (baseline data and dropout numbers were not given by arm), but also for lack of blinding and for a high long-term dropout rate. The mean age was 74 (range: 46 to 89), and the mean lesion area was 336 mm^2^ (range 30 to 1890 mm^2^). Eighty-two percent were female, and the lesions were located on the extremities (84%), trunk (7.5%), and head/neck (8.5%). The cryotherapy arm had a significantly higher rate of recurrence up to 22 months than the curettage arm (OR 5.65; 95% CI 1.65 to 19.39).^141^

### Lack of Histological Clearance, SCCIS Lesions

The evidence graph for recurrence with respect to individual treatments is sparse (Figure 15 (B) – reproduced in Figure 17 for ease of reference). For this outcome, one RCT compared between laser ablation (C5) versus a combination of laser ablation and PDT with ALA (C5+E2), and one RCT compared 5-FU (F2) versus placebo (J). An analysis of comparisons between intervention categories is superfluous, in that it would include the same evidence as in the latter comparison of 5-FU (F2) versus placebo (J). The comparisons in the two RCTs (50 lesions) are described in Table 67.

Figure 17 Evidence graph of RCTs evaluating lack of histological clearance in SCCIS lesions across individual interventions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon; SCCIS = squamous cell carcinoma in situ

Figure 17. The topology map for lack of histological clearance contains only two disconnected comparisons from two RCTs: laser is compared to laser plus ALA PDT, and imiquimod is compared to a placebo

Table 67 Sample information, lack of histological clearance (SCCIS)

| Figure 17, first subgraph^83^ | Figure 17, second subgraph^57^
Studies (total sample) | 1 (28) | 1 (22)
Total sample by intervention | (F2): 12; (J): 16 | (C5): 11; (C5+E2): 11
Total sample by intervention, (min, max) | 12, 16 | 11, 11
Data by comparison | (F2--J): 1 (28) | (C5--C5+E2): 1 (22)
Studies by comparison (min, max) | 1, 1 | 1, 1
Total sample by comparison (min, max) | 28, 28 | 22, 22
Followup | 7 months | 6 months

A = surgical excision; B = Mohs micrographic surgery; C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; C5 = laser; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F1 = 5-FU; F2 = Imiquimod; F3 = Interferon; F4 = Ingenol; H = curettage; J = placebo; SCCIS = squamous cell carcinoma in situ

Table 68 shows the relative odds ratios for lack of histological clearance between individual interventions. Because of the very small sample sizes, the confidence intervals are very large. Table 69 has the respective fractions for lack of histological clearance in the two RCTs.

Table 68 Relative odds ratios for lack of histological clearance between individual interventions (SCCIS lesions, Figure 17)

(F1) 5-FU | 0.01 (<0.005, 0.22)
99 (4.45, 2202.23) | (J) placebo
| | (C5) laser | 8.33 (0.78, 89.47)
| | 0.12 (0.01, 1.29) | (C5+E2) laser + PDT (ALA)

Note: Bold-italic indicates that the result is statistically significant; Results are given in odds ratios and 95% confidence intervals.

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ

Table 69 Mean lack of histological clearance (all SCCIS lesions)

Intervention Type | Mean Percent (95% CI)
First comparison
5-FU (F1) | 25.0 (8.3, 55.2)
Placebo (J) | 97.1 (66.4, 99.8)
Second comparison
Laser (C5) | 45.5 (20.3, 73.2)
Laser with PDT (ALA) (C5+E2) | 9.1 (1.3, 43.9)

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ; CI = confidence interval

### Lack of Clinical Clearance, SCCIS Lesions

The evidence graph for recurrence with respect to individual treatments is sparse (Figure 15 [C] – reproduced in Figure 18 [A] for ease of reference). Detailed results at the RCT-level are in Appendix I.

Figure 18 Evidence graph of RCTs evaluating lack of clinical clearance in SCCIS lesions across (A) individual interventions and (B) types of interventions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL=methyl aminolevulinate; FU = fluorouracil; INF = interferon; SCCIS = squamous cell carcinoma in situ

Figure 18. (A) This is the topology map of the network meta-analysis of lack of clinical clearance for all SCCs compared in five RCTs. Eight interventions are displayed, grouped by type of intervention. The interventions are: thermodynamic (cryotherapy, laser), PDT (MAL or ALA), drugs (5-FU, imiquimod), and placebo. Of the 28 possible pairwise comparisons, seven are covered by direct study comparisons. MAL PDT is compared to cryotherapy plus 5-FU, laser plus MAL PDT, and placebo; ALA PDT is compared to cryotherapy and 5-FU; and cryotherapy plus 5-FU was also compared to placebo, as was imiquimod. (B) This is the topology map for lack of clinical clearance of the network meta-analysis of the types of interventions for all SCCs compared in five RCTs. Four types of interventions are displayed: thermodynamic, PDT, drugs, and placebo. Of the six possible pairwise comparisons, five are covered by direct study comparisons in the primary graph: PDT is compared to thermodynamic, drug, and placebo; and thermodynamic and drug are both separately compared to placebo.

#### Comparisons Across Intervention Categories

In total, five RCTs (436 lesions) were included in this analysis.^72, 79, 80, 83, 89^ Three RCTs were deemed to be at low or moderate risk of bias. The comparisons are described in Table 70.

Table 70 Sample information, lack of clinical clearance (SCCIS, intervention categories)

Studies (total sample) | 5 (436)
Total sample by intervention | (C): 166; (E): 190; (F): 45; (I,J): 35
Total sample by intervention, (min, max) | 35, 190
Data by comparison | (C--E): 3 (323); (C--I,J): 1 (133); (E--F): 1 (66); (E--I,J): 1 (130); (F--I,J): 1 (28)
Studies by comparison (min, max) | 1, 3
Total sample by comparison (min, max) | 28, 323
Followup median (min, max) | 3 (2, 12) months

A = surgical excision; B = Mohs micrographic surgery; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo; SCCIS = squamous cell carcinoma in situ

Table 71 shows the relative odds ratios for clinical clearance across intervention categories. There were no statistically significant differences between the active interventions, although the confidence intervals for the odds ratios were wide and could not exclude large differences in the odds of the outcome in either direction. Nevertheless, all active interventions were favored beyond chance versus placebo.

Table 71 Relative odds ratios for lack of clinical clearance between intervention categories (SCCIS lesions, Figure 18B)

Heat/cold (C) | 0.69 (0.13, 3.6) | 0.29 (0.04, 2.17) | 0.02 (<0.005, 0.15)
1.45 (0.28, 7.52) | PDT (E) | 0.42 (0.07, 2.65) | 0.02 (<0.005, 0.19)
3.42 (0.46, 25.34) | 2.37 (0.38, 14.83) | Drugs (F) | 0.06 (0.01, 0.58)
60.64 (6.87, 535.12) | 41.96 (5.22, 337.2) | 17.73 (1.72, 182.98) | No/sham treatment (I,J)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates that the result is statistically significant. Results are given as odds ratios (95% confidence intervals).

PDT = photodynamic therapy; SCCIS = squamous cell carcinoma in situ

Table 72 offers complementary information from the same analysis. The fraction of lesions without clinical clearance was between 10.8 and 29.2 percent in the active treatments and 88 percent with placebo. The confidence intervals for each estimate are wide.

Table 72 Mean and forecasted lack of clinical clearance fractions by intervention category (SCCIS lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
Heat/cold (C) | 10.8 (3.1, 31.3) | 10.8 (1.2, 54.7)
PDT (E) | 14.9 (5.4, 34.9) | 14.9 (1.9, 61.0)
Drug (F) | 29.2 (8.4, 65.1) | 29.2 (3.6, 82.2)
No/sham treatment (I,J) | 88.0 (54.2, 97.8) | 88.0 (34.7, 99.0)

PDT = photodynamic therapy; SCCIS = squamous cell carcinoma in situ

#### Comparisons Across Individual Interventions

As is evident from Figure 18, there are two connected subgraphs: a smaller one comprising the comparison between cryotherapy (C1), MAL with ALA (E2) and 5-FU (F1), and a larger one between PDT with MAL with and without laser preparation (E1 and C5+E1), cryotherapy with 5-FU (C1+F1), and placebo. In total, five RCTs (436 lesions) were included in these analyses, as summarized in Table 73.

Table 73 Sample information, lack of clinical clearance (SCCIS, interventions)

| First subgraph^72, 79, 83^ | Second subgraph^80, 89^
Studies (total sample) | 3 (330) | 2 (106)
Total sample by intervention | (C5+E1): 32; (E1): 137; (C1+F1): 114; (J): 35; (F2): 12 | (C1): 20; (E2): 53; (F1): 33
Total sample by intervention, (min, max) | 12, 137 | 20, 53
Data by comparison | (C5+E1--E1): 1 (58); (E1--C1+F1): 1 (225); (E1--J): 1 (130); (C1+F1--J): 1 (133); (J--F2): 1 (28) | (C1--E2): 1 (40); (E2--F1): 1 (66)
Studies by comparison (min, max) | 1, 1 | 1, 1
Total sample by comparison (min, max) | 28, 225 | 40, 66
Followup median (min, max) | 7 (3, 12) months | 2.5 (2, 3) months

A = surgical excision; B = Mohs micrographic surgery; C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; C5 = laser; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F1 = 5-FU; F2 = Imiquimod; F3 = Interferon; F4 = Ingenol; H = curettage; J = placebo; SCCIS = squamous cell carcinoma in situ

Table 74 shows the relative effects for both subgraphs, respectively. Because the comparisons across individual observations are sparse, however, the confidence intervals of the odds ratios for most indirect comparisons are broad and cannot exclude very large differences between the compared interventions.

Table 74 Relative odds ratios for lack of clinical clearance between individual interventions (SCCIS lesions, Figure 18A)

Cryotherapy + 5-FU (C1+F1) | 13.7 (2.92, 64.25) | 2.11 (0.88, 5.06) | 3.04 (0.21, 44.58) | 0.04 (0.01, 0.15)
0.07 (0.02, 0.34) | Laser + PDT (MAL) (C5+E1) | 0.15 (0.04, 0.56) | 0.22 (0.01, 4.18) | <0.005 (<0.005, 0.02)
0.47 (0.2, 1.14) | 6.49 (1.79, 23.58) | PDT (MAL) (E1) | 1.44 (0.1, 21.22) | 0.02 (0.01, 0.07)
0.33 (0.02, 4.81) | 4.5 (0.24, 84.77) | 0.69 (0.05, 10.21) | Imiquimod (F2) | 0.01 (<0.005, 0.19)
22.62 (6.89, 74.26) | 310.05 (51.68, 1860.02) | 47.78 (13.39, 170.52) | 68.87 (5.18, 915.22) | Placebo/sham (J)
| | | | | Cryotherapy (C1) | 0.28 (0.01, 7.38) | 0.06 (<0.005, 1.59)
| | | | | 3.59 (0.14, 95.23) | PDT (ALA) (E2) | 0.21 (0.04, 1.08)
| | | | | 16.9 (0.63, 453.4) | 4.7 (0.93, 23.88) | 5-FU (F1)

Note: Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates that the result is statistically significant. Results are given as odds ratios (95% confidence intervals).

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ

Table 75 shows, for each intervention, the mean recurrence rates across all RCTs; estimates for interventions in both subgraphs are listed in Table 75. One cannot compare statistically the estimated recurrence rates between an intervention in the first subgraph (e.g., PDT with MAL [E1]) and the second subgraph (e.g., cryotherapy [C1]), because they come from disjoint analyses.

Table 75 Mean and forecasted lack of clinical clearance fractions by intervention (SCCIS lesions)

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
First subgraph
Cryotherapy + 5-FU (C1+F1) | 41.3 (9.4, 82.7) | 41.3 (2.3, 95.5)
Laser + PDT (MAL) (C5+E1) | 4.9 (0.6, 31.0) | 4.9 (0.1, 64.4)
PDT (MAL) (E1) | 25.0 (4.9, 68.5) | 25.0 (1.1, 90.8)
Imiquimod (F2) | 18.8 (1.7, 75.5) | 18.8 (0.5, 91.4)
Placebo (J) | 94.1 (67.9, 99.2) | 94.1 (33.1, 99.8)
Second subgraph
Cryotherapy (C1) | 2.6 (0.1, 35.5) | 2.6 (0.1, 40.3)
PDT (ALA) (E2) | 8.8 (2.4, 27.6) | 8.8 (1.6, 36.4)
5-FU (F1) | 31.2 (10.7, 63.2) | 31.2 (7.3, 72.3)

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ; CI = confidence interval

#### Lack of Clinical Clearance, Other Subgroup Analyses (Lesion Location, Lesion Size), SCCIS Lesions

##### Evidence From RCTS

Table 76 shows results on subgroup analyses for a four-arm RCT.^77, 79^ Neither lesion location nor size were associated with differences in the treatment effect beyond what is expected by chance.

Table 76 Subgroup analyses by lesion location and size: results for lack of clinical clearance (SCCIS lesions)

Study | Comparison | Time Point | Subgroup | n/N Arm 1 vs. n/N Arm 2 vs. n/N Arm 3 | OR (95% CI); P-Value Within | P- Value Between
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after first treatment | lesion diameter: 5–14 mm | 4/30 vs. 5/42 vs. 6/7 | 1.14 (0.28, 4.65); 0.03 (0.00, 0.27); 0.02 (0.00, 0.23); p<0.001 | p=0.457
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after first treatment | lesion diameter: 15–29 mm | 21/65 vs. 11/48 vs. 7/10 | 1.61 (0.69, 3.76); 0.20 (0.05, 0.87); 0.13 (0.03, 0.58); p=0.016 | p=0.457
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after first treatment | lesion diameter: >= 30 mm | 10/18 vs. 7/21 vs. 2/2 | 2.50 (0.68, 9.16); 0.25 (0.01, 5.87); 0.10 (0.00, 2.44); p=0.102 | p=0.457
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after last treatment | lesion diameter: 5–14 mm | 3/30 vs. 2/42 vs. 6/7 | 2.22 (0.35, 14.20); 0.02 (0.00, 0.21); 0.01 (0.00, 0.11); p<0.001 | p=0.522
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after last treatment | lesion diameter: 15–29 mm | 10/65 vs. 5/48 vs. 7/10 | 1.56 (0.50, 4.91); 0.08 (0.02, 0.35); 0.05 (0.01, 0.26); p<0.001 | p=0.522
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after last treatment | lesion diameter: >= 30 mm | 4/18 vs. 1/21 vs. 2/2 | 5.71 (0.58, 56.73); 0.06 (0.00, 1.55); 0.01 (0.00, 0.47); p=0.007 | p=0.522
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after last treatment | lesion location: extremities | 12/72 vs. 6/69 vs. 11/12 | 2.10 (0.74, 5.95); 0.02 (0.00, 0.15); 0.01 (0.00, 0.08); p<0.001 | NA
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after last treatment | lesion location: face/scalp | 5/27 vs. 1/28 vs. 3/5 | 1.56 (0.50, 56.48); 0.15 (0.02, 1.16); 0.02 (0.00, 0.36); p=0.007 | NA
Morton 2006 16785375 | Cryotherapy (C1) or 5-FU (F1) vs. MAL-PDT (E1) vs. sham PDT (J) | after last treatment | lesion location: neck/trunk | 0/15 vs. 1/14 vs. 1/2 | 0.29 (0.01, 7.74); 0.03 (0.00, 1.20); 0.08 (0.00, 2.39); p=0.062 | NA

PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; NA = not significant; SCCIS = squamous cell carcinoma in situ

##### Evidence From NRCSs

One NRCS reported lack of clinical clearance for 80 SCCIS lesions in 67 people, treated with either curettage (44 lesions) or cryotherapy (36 lesions). This study was deemed to be of high risk of bias, primarily for lack of reporting (baseline data and dropout numbers were not given by arm), but also for lack of blinding. The mean age was 74 (range: 46 to 89), and the mean lesion area was 336 mm^2^ (range 30 to 1890 mm^2^). Eighty-two percent were female, and the lesions were located on the extremities (84%), trunk (7.5%), and head/neck (8.5%). The cryotherapy arm had a higher rate of lack of clinical clearance at 2 weeks (2 of 36 vs. 0 of 44).^141^

### Patient-Reported Cosmetic Outcomes, SCCIS Lesions

We did not identify any studies with results for this outcome in this population.

### Observer-Reported Cosmetic Outcomes, SCCIS Lesions

In this section, we describe only the results between intervention categories, because data are sparse for the comparison of individual observations. In total, two RCTs (204 lesions) were included in this analysis, both at low to moderate risk of bias for this outcome.^72, 79^ The evidence graph in Figure 19 shows the observed comparisons based on RCTs that report observers’ (investigators’ or providers’) assessments of “at least good” cosmetic outcome. The cosmetic outcome was assessed using different scales in each RCT. The evidence graph is sparsely connected. Details about the comparisons are in Table 77.

Figure 19 Evidence graph of RCTs comparing observer-assessed cosmetic outcomes (all SCC lesions)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 19. The topology map observer-reported cosmetic outcomes contains only three comparisons from two RCTs: MAL PDT is compared to cryotherapy plus 5-FU and (separately) to laser plus MAL PDT.

Table 77 Sample information, observer-reported cosmetic outcomes (SCCIS)

Studies (total sample) | 2 (204)
Total sample by intervention | (C5+E1): 18; (E1): 100; (C1+F1): 86
Total sample by intervention, (min, max) | 18, 100
Data by comparison | (C5+E1--E1): 1 (36); (E1--C1+F1): 1 (168)
Studies by comparison (min, max) | 1, 1
Total sample by comparison (min, max) | 36, 168
Followup (min, max) | 12, 12 months

C1 = cryotherapy; C3 = diathermy and curettage; C4 = cryotherapy and curettage; C5 = laser; D1 = external radiation; E1 = MAL photodynamic therapy; E2 = ALA photodynamic therapy; F1 = 5-FU; F2 = Imiquimod; F3 = Interferon; F4 = Ingenol; H = curettage; J = placebo; SCCIS = squamous cell carcinoma in situ

Table 78 has the results of the comparisons between intervention categories based on a network meta-analysis. Based on the odds ratios in Table 78, the combination of cryotherapy and 5-FU (C1+F1) had statistically significantly better observer-assessed cosmetic outcomes than PDT with MAL (E1). The other two comparisons were not statistically significant. However, based on their confidence intervals one could not exclude differences in the odds of the outcome as large as 50 percent in either direction.

Table 78 Relative odds ratios between interventions for at least good cosmetic outcome, as assessed by an observer (SCCIS lesions, Figure 19)

Cryotherapy+5-FU (C1+F1) | 0.32 (0.07, 1.51) | 0.09 (0.02, 0.30)
3.1 (0.66, 14.5) | Laser + PDT (MAL) (C5+E1) | 0.26 (0.04, 1.71)
11.71 (3.37, 40.66) | 3.78 (0.58, 24.48) | PDT (MAL) (E1)

PDT = photodynamic therapy; MAL=methyl aminolevulinate, FU= fluorouracil; SCCIS=squamous cell carcinoma in situ. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic indicates that the result is statistically significant. Results are given as odds ratios (95% confidence intervals).

Table 79 shows the average percentage of patients with at least good cosmetic outcomes in the RCTs, based on the same network meta-analysis as the Table 78. The average number of lesions with cosmetic outcomes rated as good or excellent ranged between 72.1 and 96.8; however, the confidence intervals for these proportions were wide. Refer to Table 78 for a pairwise comparison between these treatments.

Table 79 Mean fractions of lesions with at least good cosmetic outcome, as assessed by an observer (SCCIS lesions)

Intervention | Mean percent (95% CI)
Cryotherapy + 5-FU (C1+F1) | 72.1 (61.7, 80.5)
Laser + PDT (MAL) (C5+E1) | 88.9 (64.8, 97.2)
PDT (MAL) (E1) | 96.8 (90.5, 99.0)

PDT = photodynamic therapy; MAL = methyl aminolevulinate; FU = fluorouracil; SCCIS = squamous cell carcinoma in situ; CI = confidence interval

#### Evidence From NRCSs

No NRCS reported the outcome of interest in populations where the majority of lesions were SCCs. Refer to the section on this outcome in the BCC section for a description of an NRCS that included SCCs (29%) and compared a lower dose of radiation (37 Gy) with a higher dose (45 Gy). For observer assessed cosmetic outcomes and among all lesions, the relative risk favored the lower dose, but not statistically significantly so.^151^

### Quality of Life, SCCIS Lesions

We did not identify any studies with results for this outcome in this population.

### Mental Health, SCCIS Lesions

We did not identify any studies with results for this outcome in this population.

### Patient Satisfaction, SCCIS Lesions

We did not identify any studies with results for this outcome in this population.

### Mortality, SCCIS Lesions

We did not identify any studies with results for this outcome in this population.

### Costs and Resource Use, SCCIS Lesions

We did not identify any studies with results for this outcome in this population.

### Adverse Events, All SCCIS Lesions

We describe only results between intervention categories, because data are sparse for the comparison of individual observations. Figure 20 shows the evidence graph for the comparison of the frequency of adverse events leading to discontinuation, serious adverse events, pain after treatment completion, and infection of the treated site. Reporting of adverse events was not consistent across RCTs. Appendix I enumerates other types of adverse events that were reported.

Figure 20 Evidence graph of RCTs comparing frequency of adverse events (SCCIS lesions)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 20. (A) This is the coarse topology map of the network meta-analysis of the different types of interventions for adverse events leading to treatment discontinuation for all SCCs in three RCTs. It contains four types of treatment and four comparisons: PDT is compared to thermodynamic and placebo; drug is compared to placebo. (B) This is the coarse topology map of the network meta-analysis of the different types of interventions for serious adverse events for all SCCs in one RCT. It contains three types of treatment and three comparisons: PDT is compared to thermodynamic and placebo; and thermodynamic is compared to placebo. (C) This is the coarse topology map of the network meta-analysis of the different types of interventions for pain for all SCCs in two RCTs. It contains three types of treatment and three comparisons: PDT is compared to thermodynamic and placebo; and thermodynamic is compared to placebo. (D) The coarse topology map of the network meta-analysis of the different types of interventions for infection at the treatment site contains only one comparison from 1 RCT: PDT is compared to thermodynamic.

The evidence graphs in Figure 20 are sparsely connected. For parsimony, we do not report relative effects for comparisons of the frequency of each type of adverse event. Table 80 has details about the comparisons by type of adverse event.

Table 80 Sample information, adverse events (SCCIS)

| Adverse Events Leading to Treatment Discontinuation ^72, 79, 83^ | Serious Adverse Events^79^ | Pain After Treatment^79, 80^ | Infection of Treated Site^72^
Studies (total sample) | 3 (292) | 1 (225) | 2 (265) | 1 (36)
Total sample by intervention | (C): 130; (E): 114; (I,J): 33; (F): 15 | (C): 112; (E): 96; (I,J): 17 | (C): 132; (E): 116; (I,J): 17 | (C): 18; (E): 18
Total sample by intervention, (min, max) | 15, 130 | 17, 112 | 17, 132 | 18, 18
Data by comparison | (C--E): 2 (244); (C--I,J): 1 (129); (E--I,J): 1 (113); (I,J--F): 1 (31) | (C--E): 1 (208); (C--I,J): 1 (129); (E--I,J): 1 (113) | (C--E): 2 (248); (C--I,J): 1 (129); (E--I,J): 1 (113) | (C--E): 1 (36)
Studies by comparison (min, max) | 1, 2 | 1, 1 | 1, 2 | 1, 1
Total sample by comparison (min, max) | 31, 244 | 113, 208 | 113, 248 | 36, 36
Followup median (min, max) | [during treatment] | 3 (3, 3) months | 1.5 (0.3, 3) months | 1 week

A = surgical excision; B = Mohs micrographic surgery; C = heat/cold; D = radiation; E = photodynamic therapy; F = drugs; H = curettage; I = no treatment; J = placebo

We report rates of adverse events per intervention category, based on a joint analysis of all RCTs reporting the same outcome. Most likely, adverse events were defined differently across studies, but these definitions were often not clearly described. Results for different types of adverse events, as defined by each study, are in Table 81 and come from different analyses.

Table 81 Mean fractions of adverse events, using each RCT’s definitions (SCCIS lesions)

Intervention Type | Leading to Discontinuation (Figure 20 A) | | Serious (Figure 20 B)^*^ | Pain After Treatment (Figure 20 C) | | Infection of the Treated Site (Figure 20 D)^*^
Intervention Type | Mean | Forecast | Mean | Mean | Forecast | Mean
Heat/cold (C) | 1.9 (0.6, 6.4) | 1.9 (0.6, 6.4) | 0.9 (0.1, 6.1) | 34.1 (20.0, 51.6) | 34.1 (14.7, 60.9) | 0 (0, 31)
PDT (E) | Not defined^**^ | Not defined^**^ | 0.5 (0.0, 7.7) | 23.4 (12.4, 39.5) | 23.4 (9.0, 48.5) | 0 (0, 31)
Drugs (F) | 13.3 (3.4, 40.5) | 13.3 (3.4, 40.5) | NA | NA | NA | NA
No/sham treatment (I,J) | 4.7 (0.9, 20.1) | 4.7 (0.9, 20.1) | 0 (0, 32.2) | 28.4 (9.7, 59.3) | 28.4 (7.8, 65.0) | NA

Note: Letters in outcomes refer to Figure 20. Results are given as percent and 95 percent confidence interval.

PDT = photodynamic therapy; NA = not applicable; SCCIS = squamous cell carcinoma in situ; RCT = randomized controlled trial

* No forecasts for these outcomes (fixed effects analyses only).

** PDT is a one-time treatment; discontinuation is not defined, but for parsimony, it was entered as 0 in the analysis.

Drugs had the highest rate of adverse events leading to treatment discontinuation was (13.3%; 95% CI, 3.4 to 40.5); the rate for interventions destroying the lesion with heat or cold was 2.0 percent (C). This outcome was not applicable for PDT, because it is a one-time intervention.

The frequency of adverse events characterized as “serious” by the investigators was smaller than 1 percent for all intervention categories.

Rates of pain after treatment ranged between 23.4 and 34.1 percent (including sham treatments).

The outcome of infection at the treatment site was reported in a single RCT at 0 percent.^68^

#### Evidence From NRCSs

One NRCS reported pain for 80 SCCIS lesions in 67 people, treated with either curettage (44 lesions) or cryotherapy (36 lesions). The mean age was 74 (range: 46 to 89), and the mean lesion area was 336 mm2 (range 30 to 1890 mm2). Eighty-two percent were female, and the lesions were located on the extremities (84%), trunk (7.5%), and head/neck (8.5%). The cryotherapy arm had a significantly higher patient-reported pain during the treatment to 1 day after the procedure (OR 10.4; P-value <0.001).^141^

## Microinvasive SCC Lesions

We found one RCT that compared MAL-PDT with laser-primed PDT in 45 people. The mean age was 76 and the majority of lesions were on the face or scalp in both arms (75% in the MAL-PDT arm and 76.2% in the laser-primed PDT arm). The rest of the lesions were on the extremities (16.7% and 19%, respectively) and trunk/neck (8.3% and 4.8%, respectively). The majority of tumors were moderately differentiated (75% in the MAL-PDT arm and 81% in the laser-primed PDT arm), while the rest were poorly differentiated. Risk of bias for this study was judged to be low (details in Table 59).^43^

### Recurrence, Microinvasive SCC Lesions

At 12 months, recurrence rates were significantly lower in the laser-primed PDT arm (2 of 16 patients; 12.5%; 95% CI 0.1%, 29.2%) than in the MAL-PDT arm (7 of 11 patients; 63.6%; 95% CI 33.8%; 93.5%; P between arms 0.006). At 24 months, the difference remained significantly lower in the laser-primed PDT arm (3 of 16 patients; 18.8%; 95% CI 0.1%, 38.5%) than in the MAL-PDT arm (8 of 11 patients; 95% CI 45.1%, 99.9%; P between arms 0.005).^43^

### Lack of Histological Clearance, Microinvasive SCC Lesions

Lack of histological clearance was measured at 3, 12, and 24 months. At each time point, lack of histological clearance was lower in the laser-primed arm. At three months, 3 of 19 participants in the laser-primed PDT arm showed a lack of histological clearance (15.8%) compared to 47.6% in the MAL-PDT arm (P=0.03). At 12 months, 5 of 19 participants in the laser-primed PDT arm showed a lack of histological clearance (26.3%) compared to 17 of 21 (80.9%) in the MAL-PDT arm (P=0.001). Finally, at 24 months, 6 of 19 participants in the laser-primed PDT arm showed a lack of histological clearance (31.6%) compared to 18 of 21 (85.7%) in the MAL-PDT arm (P=0.001).^43^

### Observer-Reported Cosmetic Outcomes, Microinvasive SCC Lesions

Cosmetic outcomes were only reported for patients who had a complete response at 24 months, so the sample sizes were too small to detect statistical significance. In the laser-primed PDT arm, observer-reported cosmetic outcome were at least good in 10 of 13 people (77%). In the MAL-PDT arm, they were at least good in 2 of 3 (67%).^43^

### Adverse Events, Microinvasive SCC Lesions

Everyone in both arms reported at least one adverse event, which included erythema, crusting, hyperpigmentation, pruritus, edema, bullae, and burning sensations. A higher percentage of patients in the laser-primed PDT arm reported each adverse event than in the MAL-PDT arm, but the difference was not statistically significant.

Everyone in both arms also reported experiencing pain during the procedure, with similar mean VAS scores for laser-primed PDT (6.0; SD, 1.7) and MAL-PDT (5.7; SD, 1.7; P = 0.59).^43^