# References

1 Centers for Disease Control and Prevention Skin Cancer Statistics. 2015. http://www.cdc.gov/cancer/skin/statistics/index.htm.
2 Rogers HW, Weinstock MA, Feldman SR, . Incidence Estimate of Nonmelanoma Skin Cancer (Keratinocyte Carcinomas) in the US Population, 2012. JAMA Dermatol. 2015 Oct 1;151(10):1081–6. doi: 10.1001/jamadermatol.2015.1187. PMID: 25928283.25928283
3 Bickers DR, Lim HW, Margolis D, . The burden of skin diseases: 2004 a joint project of the American Academy of Dermatology Association and the Society for Investigative Dermatology. J Am Acad Dermatol. 2006 Sep;55(3):490–500. doi: 10.1016/j.jaad.2006.05.048. PMID: 16908356.16908356
4 Karimkhani C, Dellavalle RP, Coffeng LE, . Global Skin Disease Morbidity and Mortality: An Update From the Global Burden of Disease Study 2013. JAMA Dermatol. 2017 Mar 01doi: 10.1001/jamadermatol.2016.5538. PMID: 28249066.28249066
5 Wu W, Weinstock MA. Trends of keratinocyte carcinoma mortality rates in the United States as reported on death certificates, 1999 through 2010. Dermatol Surg. 2014 Dec;40(12):1395–401. doi: 10.1097/DSS.0000000000000194. PMID: 25393350.25393350
6 Karia PS, Han J, Schmults CD. Cutaneous squamous cell carcinoma: estimated incidence of disease, nodal metastasis, and deaths from disease in the United States, 2012. J Am Acad Dermatol. 2013 Jun;68(6):957–66. doi: 10.1016/j.jaad.2012.11.037. PMID: 23375456.23375456
7 Oh CC, Hofbauer GF, Serra AL. . Painful skin lesions and squamous cell carcinoma predict overall mortality risk in organ transplant recipients: A cohort study. Br J Dermatol. 2016 Dec 23doi: 10.1111/bjd.15269. PMID: 28012178.28012178
8 U. S. Department of Health and Human Services. Reports of the Surgeon General. The Surgeon General’s Call to Action to Prevent Skin Cancer. Washington (DC): Office of the Surgeon General (US); 2014.
9 Cakir BO, Adamson P, Cingi C. Epidemiology and economic burden of nonmelanoma skin cancer. Facial Plast Surg Clin North Am. 2012 Nov;20(4):419–22. doi: 10.1016/j.fsc.2012.07.004. PMID: 23084294.23084294
10 Casey S, Best L, Vujovic O, . Use of Protoporphyrin Fluorescence to Determine Clinical Target Volume for Non-melanotic Skin Cancers Treated with Primary Radiotherapy. Cureus. 2016 Sep 04;8(9):e767. doi: 10.7759/cureus.767. PMID: 27725923.27725923
11 Lucena SR, Salazar N, Gracia-Cazana T, . Combined Treatments with Photodynamic Therapy for Non-Melanoma Skin Cancer. Int J Mol Sci. 2015 Oct 28;16(10):25912–33. doi: 10.3390/ijms161025912. PMID: 26516853.26516853
12 Yoon J, Phibbs CS, Chow A, . Costs of Keratinocyte Carcinoma (Nonmelanoma Skin Cancer) and Actinic Keratosis Treatment in the Veterans Health Administration. Dermatol Surg. 2016 Sep;42(9):1041–7. doi: 10.1097/dss.0000000000000820. PMID: 27465252.27465252
13 Linos E, Chren MM, Stijacic Cenzer I, . Skin Cancer in U.S. . Elderly Adults: Does Life Expectancy Play a Role in Treatment Decisions? J Am Geriatr Soc. 2016 Aug;64(8):1610–5. doi: 10.1111/jgs.14202. PMID: 27303932.27303932
14 Neville JA, Welch E, Leffell DJ. Management of nonmelanoma skin cancer in 2007. Nat Clin Pract Oncol. 2007 Aug;4(8):462–9. doi: 10.1038/ncponc0883. PMID: 17657251.17657251
15 Jacobsen AA, Aldahan AS, Hughes OB, . Hedgehog Pathway Inhibitor Therapy for Locally Advanced and Metastatic Basal Cell Carcinoma: A Systematic Review and Pooled Analysis of Interventional Studies. JAMA Dermatol. 2016 Apr 20doi: 10.1001/jamadermatol.2016.0780. PMID: 27096888.27096888
16 Jung JY, Linos E. Adding active surveillance as a treatment option for low risk skin cancers in patients with limited life expectancy. J Geriatr Oncol. 2016 May;7(3):221–2. doi: 10.1016/j.jgo.2016.03.008. PMID: 27133284.27133284
17 Linos E, Parvataneni R, Stuart SE, . Treatment of nonfatal conditions at the end of life: nonmelanoma skin cancer. JAMA Intern Med. 2013 Jun 10;173(11):1006–12. doi: 10.1001/jamainternmed.2013.639. PMID: 23699934.23699934
18 Bath-Hextall F, Ozolins M, Armstrong SJ, . Surgical excision versus imiquimod 5% cream for nodular and superficial basal-cell carcinoma (SINS): a multicentre, non-inferiority, randomised controlled trial. Lancet Oncol. 2014 Jan;15(1):96–105. doi: 10.1016/S1470-2045(13)70530-8. PMID: 24332516.24332516
19 Kuijpers DI, Thissen MR, Berretty PJ, . Surgical excision versus curettage plus cryosurgery in the treatment of basal cell carcinoma. Dermatol Surg. 2007 May;33(5):579–87. doi: 10.1111/j.1524-4725.2007.33117.x. PMID: 17451581.17451581
20 Mosterd K, Thissen MR, Nelemans P, . Fractionated 5-aminolaevulinic acid-photodynamic therapy vs. surgical excision in the treatment of nodular basal cell carcinoma: results of a randomized controlled trial. Br J Dermatol. 2008 Sep;159(4):864–70. doi: 10.1111/j.1365-2133.2008.08787.x. PMID: 18717680.18717680
21 Ozolins M, Williams HC, Armstrong SJ, . The SINS trial: a randomised controlled trial of excisional surgery versus imiquimod 5% cream for nodular and superficial basal cell carcinoma. Trials. 2010;11:42. doi: 10.1186/1745-6215-11-42. PMID: 20409337.20409337
22 Rhodes LE, de Rie MA, Leifsdottir R, . Five-year follow-up of a randomized, prospective trial of topical methyl aminolevulinate photodynamic therapy vs surgery for nodular basal cell carcinoma. Arch Dermatol. 2007 Sep;143(9):1131–6. doi: 10.1001/archderm.143.9.1131. PMID: 17875873.17875873
23 Smucler R, Vlk M. Combination of Er:YAG laser and photodynamic therapy in the treatment of nodular basal cell carcinoma. Lasers Surg Med. 2008 Feb;40(2):153–8. doi: 10.1002/lsm.20606. PMID: 18306163.18306163
24 Bath-Hextall FJ, Perkins W, Bong J, . Interventions for basal cell carcinoma of the skin. Cochrane Database Syst Rev. 2007(1):CD003412. doi: 10.1002/14651858.CD003412.pub2. PMID: 17253489.17253489
25 Clark CM, Furniss M, Mackay-Wiggan JM. Basal cell carcinoma: an evidence-based treatment update. Am J Clin Dermatol. 2014 Jul;15(3):197–216. doi: 10.1007/s40257-014-0070-z. PMID: 24733429.24733429
26 Lansbury L, Bath-Hextall F, Perkins W, . Interventions for non-metastatic squamous cell carcinoma of the skin: systematic review and pooled analysis of observational studies. BMJ. 2013;347:f6153. doi: 10.1136/bmj.f6153. PMID: 24191270.24191270
27 Lansbury L, Leonardi-Bee J, Perkins W, . Interventions for non-metastatic squamous cell carcinoma of the skin. Cochrane Database Syst Rev. 2010(4):CD007869. doi: 10.1002/14651858.CD007869.pub2. PMID: 20393962.20393962
28 Love WE, Bernhard JD, Bordeaux JS. Topical imiquimod or fluorouracil therapy for basal and squamous cell carcinoma: a systematic review. Arch Dermatol. 2009 Dec;145(12):1431–8. doi: 10.1001/archdermatol.2009.291. PMID: 20026854.20026854
29 Mosterd K, Arits AH, Thissen MR, . Histology-based treatment of basal cell carcinoma. Acta Derm Venereol. 2009;89(5):454–8. doi: 10.2340/00015555-0710. PMID: 19734968.19734968
30 Roozeboom MH, Arits AH, Nelemans PJ, . Overall treatment success after treatment of primary superficial basal cell carcinoma: a systematic review and meta-analysis of randomized and nonrandomized trials. Br J Dermatol. 2012 Oct;167(4):733–56. doi: 10.1111/j.1365-2133.2012.11061.x. PMID: 22612571.22612571
31 Thissen MR, Neumann MH, Schouten LJ. A systematic review of treatment modalities for primary basal cell carcinomas. Arch Dermatol. 1999 Oct;135(10):1177–83. PMID: 10522664.10522664
32 Basal Cell Carcinoma, Squamous Cell Carcinoma, and Related Lesions: A Guide to Clinical Management in Australia. Cancer Council Australia and Australian Cancer Network. 2008.
33 Finnish Medical Society Duodecim. Naevi and skin cancer (basal cell and epidermoid carcinoma). In: EBM Guidelines. Evidence-Based Medicine [Internet]. Helsinki, Finland: Wiley Interscience. John Wiley & Sons; 2010.
34 US Department of Health Human Services. The surgeon general’s call to action to prevent skin cancer. 2014.
35 Mudigonda T, Pearce DJ, Yentzer BA, . The economic impact of non-melanoma skin cancer: a review. J Natl Compr Canc Netw. 2010 Aug;8(8):888–96. PMID: 20870635.20870635
36 Linos E, VanBeek M, Resneck JS, Jr. A Sudden and Concerning Increase in the Use of Electronic Brachytherapy for Skin Cancer. JAMA Dermatol. 2015 Jul;151(7):699–700. doi: 10.1001/jamadermatol.2015.0385. PMID: 25785818.25785818
37 AHRQ Methods for Effective Health Care. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2011.
38 Halladay CW, Trikalinos TA, Schmid IT, . Using data sources beyond PubMed has a modest impact on the results of systematic reviews of therapeutic interventions. J Clin Epidemiol. 2015 Sep;68(9):1076–84. doi: 10.1016/j.jclinepi.2014.12.017. PMID: 26279401.26279401
39 Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium; 2012. ACM.
40 Higgins JP, Altman DG, Gotzsche PC, . The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. Bmj. 2011;343:d5928. doi: 10.1136/bmj.d5928. PMID: 22008217.22008217
41 Wells GAS, B.;O’Connell, D.;Peterson, J.; Welch, V.; Losos, M.; Tugwell, P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
42 Carija A, Puizina-Ivic N, Vukovic D, . Single treatment of low-risk basal cell carcinomas with pulsed dye laser-mediated photodynamic therapy (PDL-PDT) compared with photodynamic therapy (PDT): A controlled, investigator-blinded, intra-individual prospective study. Photodiagnosis Photodyn Ther. 2016 Dec;16:60–5. doi: 10.1016/j.pdpdt.2016.08.003. PMID: 27516420.27516420
43 Choi SH, Kim KH, Song KH. Effect of Methyl Aminolevulinate Photodynamic Therapy With and Without Ablative Fractional Laser Treatment in Patients With Microinvasive Squamous Cell Carcinoma: A Randomized Clinical Trial. JAMA Dermatol. 2017 Feb 15doi: 10.1001/jamadermatol.2016.4463. PMID: 28199463.28199463
44 Dummer R, Migden M, Guminski A, . Investigator-assessed efficacy and safety of sonidegib in patients with locally advanced basal cell carcinoma and metastatic basal cell carcinoma: Results of the BOLT 30-month analysis. Melanoma Research. 2016;26:e3. doi: 10.1097/CMR.0000000000000285.
45 Abbade L, Gige T, Amaral V, . Higher recurrence rates of head and neck nodular basal cell carcinoma treated with topical photodynamic therapy (MAL-PDT) compared to surgical excision: A randomized controlled study. Journal of the American Academy of Dermatology; 2015. p. Ab185.
46 Al-Niaimi F, Sheth N, Kurwa HA, . Photodynamic Therapy Followed by Mohs Micrographic Surgery Compared to Mohs Micrographic Surgery Alone for the Treatment of Basal Cell Carcinoma: Results of a Pilot Single-Blinded Randomised Controlled Trial. J Cutan Aesthet Surg. 2015 Apr–Jun;8(2):88–91. doi: 10.4103/0974-2077.158443. PMID: 26157307.26157307
47 Allen ED, McGill JI, Hall VL, . Cryotherapy of basal cell lesions. Trans Ophthalmol Soc U K. 1979 Jul;99(2):264–8. PMID: 298425.298425
48 Alpsoy E, Yilmaz E, Basaran E, . Comparison of the effects of intralesional interferon alfa-2a, 2b and the combination of 2a and 2b in the treatment of basal cell carcinoma. J Dermatol. 1996 Jun;23(6):394–6. PMID: 8708151.8708151
49 Arits AH, Mosterd K, Essers BA, . Photodynamic therapy versus topical imiquimod versus topical fluorouracil for treatment of superficial basal-cell carcinoma: a single blind, non-inferiority, randomised controlled trial. Lancet Oncol. 2013 Jun;14(7):647–54. doi: 10.1016/s1470-2045(13)70143-8. PMID: 23683751.23683751
50 Avril MF, Auperin A, Margulis A, . Basal cell carcinoma of the face: surgery or radiotherapy? Results of a randomized study. Br J Cancer. 1997;76(1):100–6. PMID: 9218740.9218740
51 Basset-Seguin N, Ibbotson SH, Emtestam L, . Topical methyl aminolaevulinate photodynamic therapy versus cryotherapy for superficial basal cell carcinoma: a 5 year randomized trial. Eur J Dermatol. 2008 Sep–Oct;18(5):547–53. doi: 10.1684/ejd.2008.0472. PMID: 18693158.18693158
52 Bath-Hextall F, Ozolins M, Armstrong SJ, . Surgical excision versus imiquimod 5% cream for nodular and superficial basal-cell carcinoma (SINS): a multicentre, non-inferiority, randomised controlled trial. Lancet Oncol. 2014 Jan;15(1):96–105. doi: 10.1016/s1470-2045(13)70530-8. PMID: 24332516.24332516
53 Berroeta L, Clark C, Dawe RS, . A randomized study of minimal curettage followed by topical photodynamic therapy compared with surgical excision for low-risk nodular basal cell carcinoma. Br J Dermatol. 2007 Aug;157(2):401–3. doi: 10.1111/j.1365-2133.2007.07996.x. PMID: 17573890.17573890
54 Beutner KR, Geisse JK, Helman D, . Therapeutic response of basal cell carcinoma to the immune response modifier imiquimod 5% cream. J Am Acad Dermatol. 1999 Dec;41(6):1002–7. PMID: 10570388.10570388
55 Brinkhuizen T, Frencken KJ, Nelemans PJ, . The effect of topical diclofenac 3% and calcitriol 3 mug/g on superficial basal cell carcinoma (sBCC) and nodular basal cell carcinoma (nBCC): A phase II, randomized controlled trial. J Am Acad Dermatol. 2016 Jul;75(1):126–34. doi: 10.1016/j.jaad.2016.01.050. PMID: 27067393.27067393
56 Butler DF, Parekh PK, Lenis A. Imiquimod 5% cream as adjunctive therapy for primary, solitary, nodular nasal basal cell carcinomas before Mohs micrographic surgery: a randomized, double blind, vehicle-controlled study. Dermatol Surg. 2009 Jan;35(1):24–9. doi: 10.1111/j.1524-4725.2008.34378.x. PMID: 19018814.19018814
57 Cai H, Wang YX, Zheng JC, . Photodynamic therapy in combination with CO2 laser for the treatment of Bowen’s disease. Lasers Med Sci. 2015 Jul;30(5):1505–10. doi: 10.1007/s10103-015-1754-1. PMID: 25899562.25899562
58 Choi SH, Kim KH, Song KH. Er:YAG ablative fractional laser-primed photodynamic therapy with methyl aminolevulinate as an alternative treatment option for patients with thin nodular basal cell carcinoma: 12-month follow-up results of a randomized, prospective, comparative trial. J Eur Acad Dermatol Venereol. 2016 May;30(5):783–8. doi: 10.1111/jdv.13453. PMID: 26551044.26551044
59 Cornell RC, Greenway HT, Tucker SB, . Intralesional interferon therapy for basal cell carcinoma. J Am Acad Dermatol. 1990 Oct;23(4 Pt 1):694–700. PMID: 2229497.2229497
60 Dummer R, Guminski A, Gutzmer R, . The 12-month analysis from Basal Cell Carcinoma Outcomes with LDE225 Treatment (BOLT): A phase II, randomized, double-blind study of sonidegib in patients with advanced basal cell carcinoma. J Am Acad Dermatol. 2016 Jul;75(1):113–25.e5. doi: 10.1016/j.jaad.2016.02.1226. PMID: 27067394.27067394
61 Edwards L, Tucker SB, Perednia D, . The effect of an intralesional sustained-release formulation of interferon alfa-2b on basal cell carcinomas. Arch Dermatol. 1990 Aug;126(8):1029–32. PMID: 2383027.2383027
62 Edwards L, Whiting D, Rogers D, . The effect of intralesional interferon gamma on basal cell carcinomas. J Am Acad Dermatol. 1990 Mar;22(3):496–500. PMID: 2107219.2107219
63 Eigentler TK, Kamin A, Weide BM, . A phase III, randomized, open label study to evaluate the safety and efficacy of imiquimod 5% cream applied thrice weekly for 8 and 12 weeks in the treatment of low-risk nodular basal cell carcinoma. J Am Acad Dermatol. 2007 Oct;57(4):616–21. doi: 10.1016/j.jaad.2007.05.022. PMID: 17610993.17610993
64 Eimpunth S, Oganesyan G, Hamman MS, . Effectiveness of a 595-nm pulsed dye laser for the treatment of basal cell carcinoma using 1 stacked-pulse session. Journal of the American Academy of Dermatology; 2014. p. Ab134.
65 Essers BA, Dirksen CD, Nieman FH, . Cost-effectiveness of Mohs Micrographic Surgery vs Surgical Excision for Basal Cell Carcinoma of the Face. Arch Dermatol. 2006 Feb;142(2):187–94. doi: 10.1001/archderm.142.2.187. PMID: 16490846.16490846
66 Foley P, Freeman M, Menter A, . Photodynamic therapy with methyl aminolevulinate for primary nodular basal cell carcinoma: results of two randomized studies. Int J Dermatol. 2009 Nov;48(11):1236–45. doi: 10.1111/j.1365-4632.2008.04022.x. PMID: 20064185.20064185
67 Garcia-Martin E, Gil-Arribas LM, Idoipe M, . Comparison of imiquimod 5% cream versus radiotherapy as treatment for eyelid basal cell carcinoma. Br J Ophthalmol. 2011 Oct;95(10):1393–6. doi: 10.1136/bjo.2010.193078. PMID: 21242584.21242584
68 Geisse J, Caro I, Lindholm J, . Imiquimod 5% cream for the treatment of superficial basal cell carcinoma: results from two phase III, randomized, vehicle-controlled studies. J Am Acad Dermatol. 2004 May;50(5):722–33. doi: 10.1016/j.jaad.2003.11.066. PMID: 15097956.15097956
69 Geisse JK, Rich P, Pandya A, . Imiquimod 5% cream for the treatment of superficial basal cell carcinoma: a double-blind, randomized, vehicle-controlled study. J Am Acad Dermatol. 2002 Sep;47(3):390–8. PMID: 12196749.12196749
70 Haak CS, Togsverd-Bo K, Thaysen-Petersen D, . Fractional laser-mediated photodynamic therapy of high-risk basal cell carcinomas--a randomized clinical trial. Br J Dermatol. 2015 Jan;172(1):215–22. doi: 10.1111/bjd.13166. PMID: 24903544.24903544
71 Hall VL, Leppard BJ, McGill J, . Treatment of basal-cell carcinoma: comparison of radiotherapy and cryotherapy. Clin Radiol. 1986 Jan;37(1):33–4. PMID: 3514075.3514075
72 Ko DY, Kim KH, Song KH. A randomized trial comparing methyl aminolaevulinate photodynamic therapy with and without Er:YAG ablative fractional laser treatment in Asian patients with lower extremity Bowen disease: results from a 12-month follow-up. Br J Dermatol. 2014 Jan;170(1):165–72. doi: 10.1111/bjd.12627. PMID: 24102369.24102369
73 Kuijpers DI, Thissen MR, Thissen CA, . Similar effectiveness of methyl aminolevulinate and 5-aminolevulinate in topical photodynamic therapy for nodular basal cell carcinoma. J Drugs Dermatol. 2006 Jul–Aug;5(7):642–5. PMID: 16865869.16865869
74 Marks R, Gebauer K, Shumack S, . Imiquimod 5% cream in the treatment of superficial basal cell carcinoma: results of a multicenter 6-week dose-response trial. J Am Acad Dermatol. 2001 May;44(5):807–13. doi: 10.1067/mjd.2001.113689. PMID: 11312429.11312429
75 Migden MR, Guminski A, Gutzmer R, . Treatment with two different doses of sonidegib in patients with locally advanced or metastatic basal cell carcinoma (BOLT): a multicentre, randomised, double-blind phase 2 trial. Lancet Oncol. 2015 Jun;16(6):716–28. doi: 10.1016/s1470-2045(15)70100-2. PMID: 25981810.25981810
76 Miller BH, Shavin JS, Cognetta A, . Nonsurgical treatment of basal cell carcinomas with intralesional 5-fluorouracil/epinephrine injectable gel. J Am Acad Dermatol. 1997 Jan;36(1):72–7. PMID: 8996264.8996264
77 Morton C, Horn M, Lehman J, . A 24-month update of a placebo controlled European study comparing MAL-PDT with cryotherapy and 5-fluoracil in patients with Bowen’s disease (Abstract P08.73) The 14th Congress of the European Academy of Dermatology and Venereology, London, UK. 12–15th October 2005. Journal of the European Academy of Dermatology and Venereology: JEADV; 2005. p. 237–8.
78 Morton C, Horn M, Leman J, . A placebo controlled European study controlling methylaminolaevulinate photodynamic therapy with cryotherapy and 5-fluorocaril in patients with Bowen’s disease. Abstract P-33 The 85th BAD Annual Meeting 5–8th July 2005, Glasgow, UK. British journal of dermatology; 2005. p. 30.
79 Morton C, Horn M, Leman J, . Comparison of topical methyl aminolevulinate photodynamic therapy with cryotherapy or Fluorouracil for treatment of squamous cell carcinoma in situ: Results of a multicenter randomized trial. Arch Dermatol. 2006 Jun;142(6):729–35. doi: 10.1001/archderm.142.6.729. PMID: 16785375.16785375
80 Morton CA, Whitehurst C, Moseley H, . Comparison of photodynamic therapy with cryotherapy in the treatment of Bowen’s disease. Br J Dermatol. 1996 Nov;135(5):766–71. PMID: 8977678.8977678
81 Mosterd K, Krekels GA, Nieman FH, . Surgical excision versus Mohs’ micrographic surgery for primary and recurrent basal-cell carcinoma of the face: a prospective randomised controlled trial with 5-years’ follow-up. Lancet Oncol. 2008 Dec;9(12):1149–56. doi: 10.1016/s1470-2045(08)70260-2. PMID: 19010733.19010733
82 Orenberg EK, Miller BH, Greenway HT, . The effect of intralesional 5-fluorouracil therapeutic implant (MPI 5003) for treatment of basal cell carcinoma. J Am Acad Dermatol. 1992 Nov;27(5 Pt 1):723–8. PMID: 1430394.1430394
83 Patel GK, Goodwin R, Chawla M, . Imiquimod 5% cream monotherapy for cutaneous squamous cell carcinoma in situ (Bowen’s disease): a randomized, double-blind, placebo-controlled trial. J Am Acad Dermatol. 2006 Jun;54(6):1025–32. doi: 10.1016/j.jaad.2006.01.055. PMID: 16713457.16713457
84 Petit JY, Avril MF, Margulis A, . Evaluation of cosmetic results of a randomized trial comparing surgery and radiotherapy in the treatment of basal cell carcinoma of the face. Plast Reconstr Surg. 2000 Jun;105(7):2544–51. PMID: 10845311.10845311
85 Rhodes LE, de Rie M, Enstrom Y, . Photodynamic therapy using topical methyl aminolevulinate vs surgery for nodular basal cell carcinoma: results of a multicenter randomized prospective trial. Arch Dermatol. 2004 Jan;140(1):17–23. doi: 10.1001/archderm.140.1.17. PMID: 14732655.14732655
86 Roozeboom MH, Aardoom MA, Nelemans PJ, . Fractionated 5-aminolevulinic acid photodynamic therapy after partial debulking versus surgical excision for nodular basal cell carcinoma: a randomized controlled trial with at least 5-year follow-up. J Am Acad Dermatol. 2013 Aug;69(2):280–7. doi: 10.1016/j.jaad.2013.02.014. PMID: 23566914.23566914
87 Roozeboom MH, Arits AH, Mosterd K, . Three-Year Follow-Up Results of Photodynamic Therapy vs. Imiquimod vs. Fluorouracil for Treatment of Superficial Basal Cell Carcinoma: A Single-Blind, Noninferiority, Randomized Controlled Trial. J Invest Dermatol. 2016 Aug;136(8):1568–74. doi: 10.1016/j.jid.2016.03.043. PMID: 27113429.27113429
88 Roozeboom MH, Nelemans PJ, Mosterd K, . Photodynamic therapy vs. topical imiquimod for treatment of superficial basal cell carcinoma: a subgroup analysis within a noninferiority randomized controlled trial. Br J Dermatol. 2015 Mar;172(3):739–45. doi: 10.1111/bjd.13299. PMID: 25066012.25066012
89 Salim A, Leman JA, McColl JH, . Randomized comparison of photodynamic therapy with topical 5-fluorouracil in Bowen’s disease. Br J Dermatol. 2003 Mar;148(3):539–43. PMID: 12653747.12653747
90 Salmanpoor R, Motevalli D, Saki N, . Efficacy of excisional surgery, curettage and combined curettage and electrodessication in treatment of basal cell carcinoma. Iranian Journal of Dermatology. 2012;15(60):66–7. PMID: 2013120389.
91 Schleier P, Berndt A, Kolossa S, . Comparison of aminolevulinic acid (ALA)-thermogel-PDT with methyl-ALA-thermogel-PDT in basal cell carcinoma. Photodiagnosis Photodyn Ther. 2007 Sep;4(3):197–201. doi: 10.1016/j.pdpdt.2007.04.004. PMID: 25047438.25047438
92 Schulze HJ, Cribier B, Requena L, . Imiquimod 5% cream for the treatment of superficial basal cell carcinoma: results from a randomized vehicle-controlled phase III study in Europe. Br J Dermatol. 2005 May;152(5):939–47. doi: 10.1111/j.1365-2133.2005.06486.x. PMID: 15888150.15888150
93 Shumack S, Robinson J, Kossard S, . Efficacy of topical 5% imiquimod cream for the treatment of nodular basal cell carcinoma: comparison of dosing regimens. Arch Dermatol. 2002 Sep;138(9):1165–71. PMID: 12224977.12224977
94 Siller G, Rosen R, Freeman M, . PEP005 (ingenol mebutate) gel for the topical treatment of superficial basal cell carcinoma: results of a randomized phase IIa trial. Australas J Dermatol. 2010 May;51(2):99–105. doi: 10.1111/j.1440-0960.2010.00626.x. PMID: 20546215.20546215
95 Smeets NW, Krekels GA, Ostertag JU, . Surgical excision vs Mohs’ micrographic surgery for basal-cell carcinoma of the face: randomised controlled trial. Lancet. 2004 Nov 13–19;364(9447):1766–72. doi: 10.1016/s0140-6736(04)17399-6. PMID: 15541449.15541449
96 Spencer JM. Pilot study of imiquimod 5% cream as adjunctive therapy to curettage and electrodesiccation for nodular basal cell carcinoma. Dermatol Surg. 2006 Jan;32(1):63–9. PMID: 16393600.16393600
97 Sterry W, Ruzicka T, Herrera E, . Imiquimod 5% cream for the treatment of superficial and nodular basal cell carcinoma: randomized studies comparing low-frequency dosing with and without occlusion. Br J Dermatol. 2002 Dec;147(6):1227–36. PMID: 12452875.12452875
98 Szeimies RM, Ibbotson S, Murrell DF, . A clinical study comparing methyl aminolevulinate photodynamic therapy and surgery in small superficial basal cell carcinoma (8–20 mm), with a 12-month follow-up. J Eur Acad Dermatol Venereol. 2008 Nov;22(11):1302–11. doi: 10.1111/j.1468-3083.2008.02803.x. PMID: 18624836.18624836
99 Thissen MR, Nieman FH, Ideler AH, . Cosmetic results of cryosurgery versus surgical excision for primary uncomplicated basal cell carcinomas of the head and neck. Dermatol Surg. 2000 Aug;26(8):759–64. PMID: 10940063.10940063
100 Torres A, Niemeyer A, Berkes B, . 5% imiquimod cream and reflectance-mode confocal microscopy as adjunct modalities to Mohs micrographic surgery for treatment of basal cell carcinoma. Dermatol Surg. 2004 Dec;30(12 Pt 1):1462–9. doi: 10.1111/j.1524-4725.2004.30504.x. PMID: 15606733.15606733
101 Tran HT, Lee RA, Oganesyan G, . Single treatment of non-melanoma skin cancers using a pulsed-dye laser with stacked pulses. Lasers Surg Med. 2012 Aug;44(6):459–67. doi: 10.1002/lsm.22032. PMID: 22511036.22511036
102 van der Geer S, Martens J, van Roij J, . Imiquimod 5% cream as pretreatment of Mohs micrographic surgery for nodular basal cell carcinoma in the face: a prospective randomized controlled study. Br J Dermatol. 2012 Jul;167(1):110–5. doi: 10.1111/j.1365-2133.2012.10924.x. PMID: 22385074.22385074
103 van Loo E, Mosterd K, Krekels GA, . Surgical excision versus Mohs’ micrographic surgery for basal cell carcinoma of the face: A randomised clinical trial with 10 year follow-up. Eur J Cancer. 2014 Nov;50(17):3011–20. doi: 10.1016/j.ejca.2014.08.018. PMID: 25262378.25262378
104 Wang I, Bendsoe N, Klinteberg CA, . Photodynamic therapy vs. cryosurgery of basal cell carcinomas: results of a phase III clinical trial. Br J Dermatol. 2001 Apr;144(4):832–40. PMID: 11298545.11298545
105 Wettstein R, Erba P, Itin P, . Treatment of basal cell carcinoma with surgical excision and perilesional interferon-alpha. J Plast Reconstr Aesthet Surg. 2013 Jul;66(7):912–6. doi: 10.1016/j.bjps.2013.03.008. PMID: 23566745.23566745
106 The use of laboratory animals. Notes for the guidance of research workers. Ann R Coll Surg Engl. 1973 Mar;52(3):193–7. PMID: 4700674.4700674
107 Aguilar M, de Troya M, Martin L, . A cost analysis of photodynamic therapy with methyl aminolevulinate and imiquimod compared with conventional surgery for the treatment of superficial basal cell carcinoma and Bowen’s disease of the lower extremities. J Eur Acad Dermatol Venereol. 2010 Dec;24(12):1431–6. doi: 10.1111/j.1468-3083.2010.03664.x. PMID: 20456549.20456549
108 Ashby MA, Smith J, Ainslie J, . Treatment of nonmelanoma skin cancer at a large Australian center. Cancer. 1989 May 01;63(9):1863–71. PMID: 2702595.2702595
109 Avila J, Bosch A, Aristizabal S, . Carcinoma of the pinna. Cancer. 1977 Dec;40(6):2891–5. PMID: 589557.589557
110 Bean DJ, Rees RS, O’Leary JP, . Carcinoma of the hand: a 20-year experience. South Med J. 1984 Aug;77(8):998–1000. PMID: 6463702.6463702
111 Cham BE, Daunter B, Evans RA. Topical treatment of malignant and premalignant skin lesions by very low concentrations of a standard mixture (BEC) of solasodine glycosides. Cancer Lett. 1991 Sep;59(3):183–92. PMID: 1913614.1913614
112 Chernosky ME. Squamous cell and basal cell carcinomas: preliminary study of 3,817 primary skin cancers. South Med J. 1978 Jul;71(7):802–3, 6. PMID: 663726.663726
113 Cox NH, Dyson P. Wound healing on the lower leg after radiotherapy or cryotherapy of Bowen’s disease and other malignant skin lesions. Br J Dermatol. 1995 Jul;133(1):60–5. PMID: 7669642.7669642
114 Futoryan T, Grande D. Postoperative wound infection rates in dermatologic surgery. Dermatol Surg. 1995 Jun;21(6):509–14. PMID: 7773598.7773598
115 Glass RL, Perez-Mesa CM. Management of inadequately excised epidermoid carcinoma. Arch Surg. 1974 Jan;108(1):50–1. PMID: 4808574.4808574
116 Halnan KE, Britten MJ. Late functional and cosmetic results of treatment of eyelid tumours. Br J Ophthalmol. 1968 Jan;52(1):43–53. PMID: 5710508.5710508
117 Hansen JP, Drake AL, Walling HW. Bowen’s Disease: a four-year retrospective review of epidemiology and treatment at a university center. Dermatol Surg. 2008 Jul;34(7):878–83. doi: 10.1111/j.1524-4725.2008.34172.x. PMID: 18363722.18363722
118 Harrison PV. Therapy of basal cell carcinoma--treatment in 1980–81 compared with 1985–86 and advantages of shave excision for smaller tumours. Br J Dermatol. 1987 Sep;117(3):349–57. PMID: 3676083.3676083
119 Honeycutt WM, Jansen GT. Treatment of squamous cell carcinoma of the skin. Arch Dermatol. 1973 Nov;108(5):670–2. PMID: 4750203.4750203
120 Ibbotson SH, Valentine R, Hearn R. Is the pain of topical photodynamic therapy with methyl aminolevulinate any different from that with 5-aminolaevulinic acid? Photodermatol Photoimmunol Photomed. 2012 Oct;28(5):272–3. doi: 10.1111/j.1600-0781.2012.00684.x. PMID: 22971196.22971196
121 Jebodhsingh KN, Calafati J, Farrokhyar F, . Recurrence rates of basal cell carcinoma of the periocular skin: what to do with patients who have positive margins after resection. Can J Ophthalmol. 2012 Apr;47(2):181–4. doi: 10.1016/j.jcjo.2012.01.024. PMID: 22560426.22560426
122 Kadakia S, Ducic Y, Marra D, . Cutaneous squamous cell carcinoma of the scalp in the immunocompromised patient: review of 53 cases. Oral Maxillofac Surg. 2016 Jun;20(2):171–5. doi: 10.1007/s10006-016-0545-6. PMID: 26780196.26780196
123 Knox JM, Freeman RG, Duncan WC, . Treatment of skin cancer. South Med J. 1967 Mar;60(3):241–6. PMID: 6020491.6020491
124 Kowalzick L, Rogozinski T, Schober C, . Treatment of basal cell carcinoma with intralesional recombinant interferon beta: A dose-finding study. European Journal of Dermatology. 1994;4(6):430–3. PMID: 1994253804.
125 Marks R, Owens M, Walters SA. Efficacy and safely of 5% imiquimod cream in treating patients with multiple superficial basal cell carcinomas. Archives of Dermatology. 2004 October;140(10):1284–5. PMID: 2004440056.
126 Mazeron JJ, Chassagne D, Crook J, . Radiation therapy of carcinomas of the skin of nose and nasal vestibule: a report of 1676 cases by the Groupe Europeen de Curietherapie. Radiother Oncol. 1988 Nov;13(3):165–73. PMID: 3146781.3146781
127 McIntosh GS, Osborne DR, Li AK, . Basal cell carcinoma--a review of treatment results with special reference to cryotherapy. Postgrad Med J. 1983 Nov;59(697):698–701. PMID: 6647186.6647186
128 Mebed AH, Soliman HO, Gad ZS, . Multimodality treatment for non melanoma skin cancer: a prospective study done on 120 egyptian patients. J Egypt Natl Canc Inst. 2010 Mar;22(1):49–55. PMID: 21503006.21503006
129 Nevrkla E, Newton KA. A survey of the treatment of 200 cases of basal cell carcinoma (1959–1966 inclusive). Br J Dermatol. 1974 Oct;91(4):429–33. PMID: 4425623.4425623
130 Pereira CT, Kruger EA, Sayer G, . Mohs versus surgical excision in nonmelanoma skin cancers: does location matter? Ann Plast Surg. 2013 Apr;70(4):432–4. doi: 10.1097/SAP.0b013e3182834b47. PMID: 23486132.23486132
131 Rank B. Surgery and skin cancer. Ann R Coll Surg Engl. 1973 Mar;52(3):148–64. PMID: 4700671.4700671
132 Reschly MJ, Shenefelt PD. Controversies in skin surgery: electrodessication and curettage versus excision for low-risk, small, well-differentiated squamous cell carcinomas. J Drugs Dermatol. 2010 Jul;9(7):773–6. PMID: 20677531.20677531
133 Shiffman NJ. Squamous cell carcinomas of the skin of the pinna. Can J Surg. 1975 May;18(3):279–83. PMID: 1125865.1125865
134 Tarstedt M, Gillstedt M, Wennberg Larko AM, . Aminolevulinic acid and methyl aminolevulinate equally effective in topical photodynamic therapy for non-melanoma skin cancers. J Eur Acad Dermatol Venereol. 2016 Mar;30(3):420–3. doi: 10.1111/jdv.13558. PMID: 26841041.26841041
135 Tourli I, Langner D, Haroske G, . BASAL CELL CARCINOMA OF THE HEAD-AND-NECK REGION: A SINGLE CENTER ANALYSIS OF 1,750 TUMORS. Georgian Med News. 2016 Jan(250):33–9. PMID: 26870972.26870972
136 Valentine RM, Ibbotson SH, Brown CT, . A quantitative comparison of 5-aminolaevulinic acid- and methyl aminolevulinate-induced fluorescence, photobleaching and pain during photodynamic therapy. Photochem Photobiol. 2011 Jan–Feb;87(1):242–9. doi: 10.1111/j.1751-1097.2010.00829.x. PMID: 21077899.21077899
137 Van Hezewijk M, Creutzberg CL, Putter H, . Efficacy of a hypofractionated schedule in electron beam radiotherapy for epithelial skin cancer: Analysis of 434 cases. Radiotherapy and Oncology. 2010 May;95(2):245–9. PMID: 2012354969.20334941
138 Wang Y, Lin Y, Zhang HG, . A photodynamic therapy combined with topical 5-aminolevulinic acid and systemic hematoporphyrin derivative is more efficient but less phototoxic for cancer. Journal of Cancer Research and Clinical Oncology. 2016 01 Apr;142(4):813–21. PMID: 2015524013.26581214
139 Werlinger KD, Upton G, Moore AY. Recurrence rates of primary nonmelanoma skin cancers treated by surgical excision compared to electrodesiccation-curettage in a private dermatological practice. Dermatol Surg. 2002 Dec;28(12):1138–42; discussion 42. PMID: 12472494.12472494
140 Yoon M, Chougule P, Dufresne R, . Localized carcinoma of the external ear is an unrecognized aggressive disease with a high propensity for local regional recurrence. Am J Surg. 1992 Dec;164(6):574–7. PMID: 1463102.1463102
141 Ahmed I, Berth-Jones J, Charles-Holmes S, . Comparison of cryotherapy with curettage in the treatment of Bowen’s disease: a prospective study. Br J Dermatol. 2000 Oct;143(4):759–66. PMID: 11069453.11069453
142 Asgari MM, Bertenthal D, Sen S, . Patient satisfaction after treatment of nonmelanoma skin cancer. Dermatol Surg. 2009 Jul;35(7):1041–9. doi: 10.1111/j.1524-4725.2009.01181.x. PMID: 19438672.19438672
143 Ballester-Sanchez R, Pons-Llanas O, Candela-Juan C, . Electronic brachytherapy for superficial and nodular basal cell carcinoma: a report of two prospective pilot trials using different doses. J Contemp Brachytherapy. 2016 Feb;8(1):48–55. doi: 10.5114/jcb.2016.57531. PMID: 26985197.26985197
144 Chren MM, Linos E, Torres JS, . Tumor recurrence 5 years after treatment of cutaneous basal cell carcinoma and squamous cell carcinoma. J Invest Dermatol. 2013 May;133(5):1188–96. doi: 10.1038/jid.2012.403. PMID: 23190903.23190903
145 Chren MM, Sahay AP, Bertenthal DS, . Quality-of-life outcomes of treatments for cutaneous basal cell carcinoma and squamous cell carcinoma. J Invest Dermatol. 2007 Jun;127(6):1351–7. doi: 10.1038/sj.jid.5700740. PMID: 17301830.17301830
146 Chren MM, Sahay AP, Sands LP, . Variation in care for nonmelanoma skin cancer in a private practice and a veterans affairs clinic. Med Care. 2004 Oct;42(10):1019–26. PMID: 15377935.15377935
147 Chren MM, Torres JS, Stuart SE, . Recurrence after treatment of nonmelanoma skin cancer: a prospective cohort study. Arch Dermatol. 2011 May;147(5):540–6. doi: 10.1001/archdermatol.2011.109. PMID: 21576572.21576572
148 Cosgarea R, Susan M, Crisan M, . Photodynamic therapy using topical 5-aminolaevulinic acid vs. surgery for basal cell carcinoma. J Eur Acad Dermatol Venereol. 2013 Aug;27(8):980–4. doi: 10.1111/j.1468-3083.2012.04619.x. PMID: 22738399.22738399
149 Graells J, Ojeda RM, Garcia-Cruz A. Effect of imiquimod as compared with surgery on the cancerization field in basal cell carcinoma. Actas Dermosifiliogr. 2014 Jan–Feb;105(1):53–9. doi: 10.1016/j.ad.2013.09.001. PMID: 24139468.24139468
150 Lippert J, Smucler R, Vlk M. Fractional carbon dioxide laser improves nodular basal cell carcinoma treatment with photodynamic therapy with methyl 5-aminolevulinate. Dermatol Surg. 2013 Aug;39(8):1202–8. doi: 10.1111/dsu.12242. PMID: 23725586.23725586
151 Pampena R, Palmieri T, Kyrgidis A, . Orthovoltage radiotherapy for nonmelanoma skin cancer (NMSC): Comparison between 2 different schedules. J Am Acad Dermatol. 2016 Feb;74(2):341–7. doi: 10.1016/j.jaad.2015.09.031. PMID: 26589877.26589877
152 Shah SM, Konnikov N, Duncan LM, . The effect of 595 nm pulsed dye laser on superficial and nodular basal cell carcinomas. Lasers Surg Med. 2009 Aug;41(6):417–22. doi: 10.1002/lsm.20787. PMID: 19588534.19588534
153 Sofen H, Gross KG, Goldberg LH, . A phase II, multicenter, open-label, 3-cohort trial evaluating the efficacy and safety of vismodegib in operable basal cell carcinoma. J Am Acad Dermatol. 2015 Jul;73(1):99–105.e1. doi: 10.1016/j.jaad.2015.03.013. PMID: 25913533.25913533
154 Sullivan TP, Dearaujo T, Vincek V, . Evaluation of superficial basal cell carcinomas after treatment with imiquimod 5% cream or vehicle for apoptosis and lymphocyte phenotyping. Dermatol Surg. 2003 Dec;29(12):1181–6. PMID: 14725659.14725659
155 Wilson LS, Pregenzer M, Basu R, . Fee comparisons of treatments for nonmelanoma skin cancer in a private practice academic setting. Dermatol Surg. 2012 Apr;38(4):570–84. doi: 10.1111/j.1524-4725.2011.02231.x. PMID: 22145798.22145798
156 Stuart SE, Schoen P, Jin C, . Tumor recurrence of keratinocyte carcinomas judged appropriate for Mohs micrographic surgery using Appropriate Use Criteria. J Am Acad Dermatol. 2017 Mar 29doi: 10.1016/j.jaad.2016.12.045. PMID: 28365039.28365039
157 Chren MM, Lasek RJ, Sahay AP, . Measurement properties of Skindex-16: a brief quality-of-life measure for patients with skin diseases. J Cutan Med Surg. 2001 Mar–Apr;5(2):105–10. doi: 10.1007/s102270000010. PMID: 11443481.11443481
158 Chren MM, Lasek RJ, Quinn LM, . Skindex, a quality-of-life measure for patients with skin disease: reliability, validity, and responsiveness. J Invest Dermatol. 1996 Nov;107(5):707–13. PMID: 8875954.8875954
159 Connolly SM, Baker DR, Coldiron BM, . AAD/ACMS/ASDSA/ASMS 2012 appropriate use criteria for Mohs micrographic surgery: a report of the American Academy of Dermatology, American College of Mohs Surgery, American Society for Dermatologic Surgery Association, and the American Society for Mohs Surgery. J Am Acad Dermatol. 2012 Oct;67(4):531–50. doi: 10.1016/j.jaad.2012.06.009. PMID: 22959232.22959232
160 Chaimani A, Vasiliadis HS, Pandis N, . Effects of study precision and risk of bias in networks of interventions: a network meta-epidemiological study. Int J Epidemiol. 2013 Aug;42(4):1120–31. doi: 10.1093/ije/dyt074. PMID: 23811232.23811232
161 Salanti G, Del Giovane C, Chaimani A, . Evaluating the quality of evidence from a network meta-analysis. PLoS One. 2014;9(7):e99682. doi: 10.1371/journal.pone.0099682. PMID: 24992266.24992266
162 American Academy of Dermatology and AAD Association. Position Statement on Superficial Radiation Therapy for Basal Cell Carcinoma (BCC) and Squamous Cell Carcinomas (SCC). 2014.
163 American Academy of Dermatology and AAD Association. Position Statement on Electronic Surface Brachytherapy for Basal Cell Carcinoma (BCC) and Squamous Cell Carcinomas (SCC). 2016.
164 Merola JF, Armstrong AW, Saraiya A, . International Dermatology Outcome Measures Initiative as Applied to Psoriatic Disease Outcomes: An Update. J Rheumatol. 2016 May;43(5):959–60. doi: 10.3899/jrheum.160114. PMID: 27134269.27134269
165 Chan AW, Fung K, Tran JM, . Application of Recursive Partitioning to Derive and Validate a Claims-Based Algorithm for Identifying Keratinocyte Carcinoma (Nonmelanoma Skin Cancer). JAMA Dermatol. 2016 Oct 01;152(10):1122–7. doi: 10.1001/jamadermatol.2016.2609. PMID: 27533718.27533718