# Methods

The Brown Evidence-based Practice Center (EPC) conducted this review based on a systematic review of the published scientific literature, using established methodologies as outlined in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^37^ The Prospero registration number is CRD42016043353.

## Eligibility Criteria

We use the population, intervention, comparator, outcomes, and designs (PICOTS) formalism to define the characteristics of the eligible studies for this review.

### Population

The population of interest is people with primary squamous cell carcinoma (SCC) and basal cell carcinoma (BCC). This specifically excludes recurrent or metastatic disease. If populations were mixed, we included studies with at least 80 percent primary, nonmetastatic BCC or SCC. We excluded studies of recurrent or metastatic cancers in which it was not clear whether the advanced lesions were less than 20 percent of the total lesions studied.

We were also interested in the following specific subpopulations: (1) people who are immunocompromised, including those who have had a solid organ or bone marrow transplant, human immunodeficiency virus (HIV), chemotherapy, Chronic Lymphocytic Leukemia (CLL) or other leukemias and lymphomas, or other iatrogenic; (2) people with a limited life expectancy (e.g., the very elderly, those with terminal cancer, those with end stage renal disease). We have excluded subpopulations based on rare genetic factors (e.g., basal-cell nevus syndrome and xeroderma pigmentosa).

In addition, we were interested in the effects of treatments in subgroups as defined by location (e.g. face, hands, trunk, or extremities) and grade of lesion (e.g. superficial or nodular BCC or SCC in situ [Bowen’s Disease] in SCC).

### Interventions

The interventions of interest are organized into intervention categories (A through J):

A. Surgical excision without intraoperative evaluation of the margins
B. Surgical excision with intraoperative evaluation of the margins
  - Mohs micrographically controlled surgery
  - Surgery with examination of frozen sections
C. Interventions that destroy the lesion via temperature gradients
  C1 Cryotherapy
  C2 Diathermy/electrodesiccation
  C3 Curettage of the lesion plus diathermy (cauterization) of margins
  C4 Curettage of the lesion plus cryotherapy
  C5 CO_2_ laser therapy
D. Interventions that destroy the lesion with ionizing radiation
  D1 External beam radiation with photons (X or gamma rays), electrons (beta rays), or positively charged particles (e.g., protons, helium nuclei/alpha rays), at orthovoltage or megavoltage energies, or using in-office radiation machines
  D2 Brachytherapy with superficial application or interstitial application (pleisiotherapy) of radiation sources (usually emitting beta or alpha rays)
E. Photodynamic interventions
  E1 5-aminolevulinic acid (ALA) + blue light
  E2 Methyl aminolevulinate (MAL) + red light
  E3 Other forms of PDT
F. Medical interventions
  F1 5-fluorouracil (5-FU)
  F2 Imiquimod
  F3 Interferon (IFN alpha-2a/2b or INF beta)
  F4 Ingenol mebutate
  F5 Other medical interventions, including BEC-5 cream, Bleomycin, Methotrexate, Diclofenac, and Hedgehog inhibitors (Vismodegib, Sonidegib)
G. Shave excision
H. Curettage without diathermy
I. Placebo
J. No treatment

### Outcomes

We evaluated the outcomes in the following list. We did not use strict a priori definitions of the outcomes, but included all reported outcomes as defined by study researchers. We evaluated outcomes at any and all time points given in a specific study. We used our best judgment to categorize outcomes when studies failed to clearly define their reported outcomes.

- Recurrence/cure rate (as defined in studies)
- Disfigurement/cosmetic outcome
- Quality of Life (only if they use validated instruments to measure – e.g. Short Form Health Survey-36, Skindex, Skin Cancer Index, Skin Cancer Quality of Life Impact Tool)
- Mental health, anxiety, depression, intrusive thoughts (only if they use validated instruments to measure – e.g. State-Trait Anxiety Inventory, Hospital Anxiety and Depression Scale, Impact of Event Scale)
- Patient satisfaction with treatment (only if they use validated instruments to measure – e.g. Patient Satisfaction Questionnaire-18, Skin Cancer Index patient satisfaction subscale)
- Mortality
- Adverse events, including those that are reported by patients and clinically, as well as actively and passively. Both short-term (e.g. pain, skin irritation) and long-term (e.g. radiation exposure, scarring) adverse events were recorded. We systematically reviewed the following endpoints: “any serious adverse event” (leading to treatment discontinuation, or as defined by each study), “pain” and “infection”. We enumerated the set of other reported events.

### Design

We evaluated all randomized controlled studies and all comparative nonrandomized controlled studies. We excluded studies enrolling fewer than 10 people total because they were unlikely to yield precise or broadly applicable conclusions. We excluded non-English studies, as there were very few of them and there is empirical evidence that excluding them typically has minimal impact on conclusions.^38^ Studies in any setting were acceptable.

As described by Linos et al.,^17^ patient treatment is often determined by factors, such as disease stage, medical history, age and education, that could confound assessment of the outcomes of interest. Thus for the nonrandomized comparative studies (NRCSs), we required that studies included an analysis that accounted for confounders, such as inclusion in a multivariate model, balancing or quasi-randomization, or clearly matched groups. NRCSs that report only crude results were identified and tabulated but were excluded from the analysis in the full report.

## Evidence Identification

We conducted literature searches of studies in PubMed, the Cochrane Central Trials Registry, the Cochrane Database of Systematic Reviews, and Embase to identify primary research studies meeting our criteria through March 8, 2017. These databases should adequately cover the published literature on this topic. The full search strategy for all databases is in Appendix A. We screened all references in published clinical practice guidelines, relevant narrative and systematic reviews, and Scientific Information Packages from manufacturers or other stakeholders. We searched ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform (ICTRP) for ongoing studies and studies that are not published in the medical literature. In addition, we searched the Food and Drug Administration drugs and devices portals for unpublished data. We did not find any studies with results that were not included in the published literature. Our requests to manufacturers for scientific information packets also did not yield any new data. We have extracted and incorporated all studies de novo and have not summarized or incorporated existing systematic reviews, per se. All articles identified through these sources have been screened for eligibility, using the same criteria as was used for articles identified through literature searches. The search will be updated upon submission of the draft report for peer and public review.

All citations found by literature searches and other sources were independently screened by two researchers. At the start of abstract screening, we implemented a training session, in which all researchers screened the same articles and conflicts were discussed. During title and abstract double-screening, we resolved conflicts as a group. All title and abstract screening was done in the open-source, online software Abstrackr (http://abstrackr.cebm.brown.edu/).^39^ All potentially relevant studies were rescreened in full text with double-screening to ensure eligibility.

## Data Extraction and Data Management

Each study has been extracted by one member of the review team, which includes clinicians and methodologists. The extraction was reviewed and confirmed by at least one other experienced methodologist. Any disagreements were resolved by discussion among the team. Data was extracted into a customized form in Systematic Review Data Repository (SRDR) online system (http://srdr.ahrq.gov) designed to capture all elements relevant to the Key Questions. Upon completion of the review, the SRDR database will be made accessible to the general public (with capacity to read, download, and comment on data). The basic elements and design of the extraction form are the similar to those used for other AHRQ comparative effectiveness reviews and include elements that address population characteristics, including method of diagnosis; descriptions of the interventions, exposures, and comparators analyzed; outcome definitions; effect modifiers; enrolled and analyzed sample sizes; study design features; funding source; results; and risk of bias questions. If information was stratified by carcinoma subtype for BCC (e.g. superficial or nodular) and SCC (e.g. SCC in situ, well-differentiated, or poorly differentiated), we recorded that information as well.

## Assessment of Methodological Risk of Bias of Individual Studies

We assessed the methodological quality of each study based on predefined criteria. For RCTs, we used the Cochrane risk of bias tool,^40^ which asks about risk of selection bias, performance bias, detection bias, attrition bias, reporting bias, and other potential biases. For observational studies, we used relevant questions from the Newcastle Ottawa Scale.^41^ For RCTs, the review team discussed each article, based on methodological (design and analysis) items that are related to the aforementioned biases for each outcome of each trial. To obtain information on (a lower bound of) the number of yet unpublished trials, we searched clinicaltrials.gov for completed trials, and examined the publication status of thus identified studies.

## Data Synthesis

All included studies were summarized in narrative form and in summary tables that include the important features of the study populations, design, intervention, outcomes, and results. Lesions were divided by subtype (superficial, nodular, or high-risk BCC, SCC, or mixed populations) for analysis to ensure that the treatments would be most comparable. Where possible, lesions were also evaluated by size and location. Trial arms with fewer than 5 lesions were not included in the analysis, because they contribute minimal information, and in some instances, necessitated adding model parameters that were difficult to estimate.

We conducted pairwise and network meta-analyses with mixed effects (random intercepts and fixed intervention slopes) or full-random effects (random intercepts and random slopes) multilevel models within the generalized linear and latent mixed models. We used the normal approximation to discrete likelihoods with a canonical (logit) link function. Treatment effect estimates from such models are odds ratios. We fit models by maximizing the restricted likelihood. We explored clinical and methodological heterogeneity in subgroup analyses. We did not conduct dose-response meta-analyses because there was substantial heterogeneity in the definitions of intervention intensity (dose) across studies; instead, we summarized dose-response results qualitatively. To aid the interpretation of these analyses we also present model-based estimates for the mean frequency of an outcome in the examined interventions, as well as forecasts of the frequency of the outcome in a new setting (e.g., a new study, or in a population) that is similar to the studies in the meta-analysis. The forecasts’ point estimate about the frequency of the outcome is very close to the point estimate of the mean frequency of the outcome over the meta-analyzed studies. However, the 95% confidence interval (CI) for a forecast of the frequency of an outcome in a new setting accounts for between-study heterogeneity, and will, thus, be broader than the corresponding 95% CI for the mean frequency of the outcome across the analyzed studies. See the next paragraph about the presentation of results. Inconsistency was assessed by comparing the fit of models that do not assume consistent intervention effects versus typical network meta-analysis models, that assume consistent treatment effects. Analyses did not identify statistical evidence of inconsistency. Because such analyses are known to be underpowered, we also compared qualitatively the agreement of estimates based only on direct data versus of estimates based on both direct and indirect data. Such estimates were deemed to be congruent.

## Presentation of Results

We present results with plots and tables. We briefly describe three expository formats that are not commonly used in EPC reports, namely, evidence graphs, league tables, and relative effects tables.

### Evidence Graphs

We use evidence graphs such as the one in Figure 2 to describe which interventions have been compared with others. An evidence graph comprises nodes, which represent interventions, and edges (depicted by a line linking nodes). Edges connect a pair of nodes only if the corresponding interventions have been compared in at least one head-to-head study. In Figure 2, nodes for interventions from the same intervention category are in a shaded area. For example, nodes E1 (corresponding to PDT with MAL) and E2 (corresponding to PDT with ALA) are within the same shaded area which represents PDT as the type of intervention), and analogously for other nodes and interventions in the figure. The organization of interventions in intervention categories has been described in the Interventions paragraph. We use the term connected subgraph to describe a set of nodes that are connected through one or more edges. For example, Figure 2 has 2 connected subgraphs, which include the following nodes:

1. A|B, D1|D2, and
2. all remaining nodes in the evidence graph, namely A, B, A|B, B+F3, D1, F2, H, C3, C4, C1, C5+E1, E1, and E2.

Figure 2 Example evidence graph depicting comparisons between individual interventions

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL = methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 2. This is an example topology map of the network meta-analysis of different specific interventions for skin cancer. Thirty interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, curettage and diathermy, curettage and cryotherapy, laser), radiation (external or brachytherapy), PDT (MAL or ALA), drugs (5-FU, imiquimod, interferon, ingenol, other), curettage, and no treatment or placebo) Of the 378 possible pairwise comparisons among 28 treatments, 35 are covered by direct study comparisons as indicated by lines between the treatment circles.

If all the nodes in the graph were connected, then there would be a single connected subgraph—which would be the whole graph. Identifying connected subgraphs is important, because we do not statistically compare interventions that belong to different connected subgraphs.

Figure 3 is an analogous representation of the comparisons between intervention categories for the same network of interventions depicted in Figure 2. When one considers intervention categories, comparisons between interventions that belong to the same type are not pertinent. Such comparisons are represented by edges enclosed in the shaded areas in the evidence graph in Figure 2. Observe also that comparing between intervention categories happened to result in a single connected subgraph in Figure 3.

Figure 3 Evidence graph depicting comparisons between intervention categories

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; ALA = 5-aminolevulinic acid; MAL= methyl aminolevulinate; FU = fluorouracil; INF = interferon

Figure 3. This is an example topology map of the network meta-analysis of the different types of intervention (surgical, thermodynamic, radiation, PDT, medical/drugs, curettage, and no treatment or placebo). Of the 21 possible pairwise comparisons, 13 are covered by direct study comparisons as indicated by lines between the treatment circles.

### Relative Effects Tables

Relative effects tables describe odds ratio estimates and 95% CIs for all pairwise comparisons in a connected subgraph. Table 1 is an example; it is the analysis that corresponds to the evidence graph in Figure 3. Each cell has a (row, column) address, and reports the estimated odds ratio between the intervention in the row versus the intervention in the column. Consider the cell in the second row, fourth column: The odds ratio comparing interventions that destroy lesions with heat or cold (with code letter C; the intervention in the row) versus PDT (E; the intervention in the column) was 0.91 (95% CI, 0.43 to 1.95). The cell in the fourth row, second column is the odds ratio for a comparison between the same interventions but in the other direction: 1.10 (95% CI, 0.51, 2.34) is the odds ratio of PDT (E) versus interventions that destroy the lesion with heat or cold (C). The unshaded cells correspond to comparisons for which there is head-to-head information, i.e., there is an edge between these corresponding nodes in the evidence graph. The estimated treatment effects in these cells are informed by direct and indirect evidence. The shaded cells correspond to comparisons that have not been empirically observed (there is no edge between these corresponding nodes in the evidence graph), and are based only on indirect comparisons.

Table 1 Relative odds ratios for an outcome between intervention categories (Figure 3)

Surgery/MMS (A,B) | 0.13 (0.05, 0.35) | 0.77 (0.22, 2.73) | 0.12 (0.04, 0.32) | 1.09 (0.05, 24.23) | 0.14 (0.03, 0.77)
7.71 (2.83, 20.98) | Heat/cold (C) | 5.95 (2.03, 17.4) | 0.91 (0.43, 1.95) | 8.44 (0.41, 173.75) | 1.09 (0.23, 5.16)
1.3 (0.37, 4.59) | 0.17 (0.06, 0.49) | Radiation (D) | 0.15 (0.05, 0.45) | 1.42 (0.06, 32.2) | 0.18 (0.03, 1.04)
8.45 (3.08, 23.16) | 1.10 (0.51, 2.34) | 6.52 (2.21, 19.21) | PDT (E) | 9.25 (0.45, 190.91) | 1.19 (0.25, 5.68)
0.91 (0.04, 20.24) | 0.12 (0.01, 2.44) | 0.7 (0.03, 15.99) | 0.11 (0.01, 2.23) | Drugs (F) | 0.13 (<0.005, 3.56)
7.08 (1.3, 38.49) | 0.92 (0.19, 4.35) | 5.46 (0.96, 31.02) | 0.84 (0.18, 3.99) | 7.75 (0.28, 214.11) | Curettage (H)

Note: This example is for analyses of recurrence among patients with BCC lesions. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

MMS = Mohs micrographic surgery; PDT = photodynamic therapy

### League Tables

League tables such as Table 2, describe the mean fraction of lesions with the outcome of interest for each intervention (or intervention category) over the populations included in the meta-analysis, and the corresponding forecasted fraction in a new setting that is analogous to the settings of the analyzed studies. The results in the league table and the results in the relative effects table are from the same analysis. The league table explains what the relative effects imply about the probability of the outcome under each treatment. In the example, over the meta-analyzed studies the probability of the event with PDT (E) was 23.0 percent (95% CI 14.8 to 33.9) and with interventions that destroy the lesion with heat or cold (C) it was 21.4 percent (95% CI 13.8 to 31.6). The expected frequency of the event in a setting that is analogous to the settings in which the meta-analyzed studies where conducted is shown in the forecast column. Note that the confidence intervals for the forecast are always larger than the confidence intervals for the mean.

Table 2 Mean and forecasted event fractions by intervention category

Intervention Type | Mean Percent (95% CI) | Forecast Percent (95% CI)
Surgery/MMS (A,B) | 3.4 (1.5, 7.6) | 3.4 (1.0, 11.4)
Heat/cold (C) | 21.4 (13.8, 31.6) | 21.4 (8.3, 45.1)
Radiation (D) | 4.4 (1.8, 10.4) | 4.4 (1.2, 15.0)
PDT (E) | 23.0 (14.8, 33.9) | 23.0 (8.9, 47.5)
Drugs (F) | 3.1 (0.2, 38.8) | 3.1 (0.1, 42.5)
Curettage (H) | 20.0 (5.5, 51.9) | 20.0 (4.1, 59.1)

MMS = Mohs micrographic surgery; PDT = photodynamic therapy; CI = confidence interval

Imagine that you are hiking along a trail from east to west, through six camp sites. The camp sites serve as the analogue for the interventions. A table showing the signed distances^a^ between pairs of campsites would be the analogue of the relative effects table. A table showing how far each campsite is from the easternmost end of the trail would be the analogue of the league table.

## Grading the Strength of Evidence (SOE) for Major Comparisons and Outcomes

We graded the strength of the body of evidence as per the AHRQ Methods Guide on assessing the strength of evidence.^37^ We assed the strength of evidence for each outcome. Following the standard AHRQ approach, for each intervention and comparison of intervention, and for each outcome, we assessed the number of studies, their study designs, the study limitations (i.e., risk of bias and overall methodological quality), the directness of the evidence to the KQs, the consistency of study results, the precision of any estimates of effect, the likelihood of reporting bias, and the overall findings across studies. Based on these assessments, we have assigned a strength of evidence rating as being either high, moderate, or low, or there being insufficient evidence to estimate an effect. The data sources, basic study characteristics, and each strength-of-evidence dimensional rating are summarized in a “Summary of Evidence Reviewed” table detailing our reasoning for arriving at the overall strength of evidence rating.

We assessed the applicability within and across studies with reference to demographics of enrolled participants (e.g. age and sex distributions), the location and severity of the lesions, and the availability of treatments (e.g. with respect to radiation treatments).

## Peer Review

A draft version of this report was reviewed by invited and public reviewers. Revisions of the draft were made, where appropriate, based on their comments. The draft and final reports have also been reviewed by the Task Order Officer and an Associate Editor from another EPC. However, the findings and conclusions are those of the authors, who are responsible for the contents of the report.

a A signed distance encodes the direction of movement and the distance traveled.