# Introduction

## Background

Skin cancers, including basal cell carcinoma (BCC) and squamous cell carcinoma (SCC), are the most common malignancies in the United States.^1^ BCC and SCC, the 2 most common skin cancers, are collectively referred to as keratinocyte carcinomas. Over 5.4 million of these cancers are diagnosed in 3.3 million people in the United States annually,^2, 3^ and the global burden of disease from keratinocyte carcinomas is estimated at 12.9 disability-adjusted life years per 100,000 persons.^4^ Generally keratinocyte carcinomas are not aggressive and do not metastasize or kill as often as melanoma, which is the third most common skin cancer.^5^ However, SCC can metastasize and is estimated to kill between 3900 and 8800 people in the United States each year.^6^ Aggressive behavior is of particular concern in people who are immunosuppressed, including organ transplant recipients whose mortality is increased after being diagnosed with SCC.^7^ A more common problem is that basal and squamous cell carcinomas and their treatment may result in disfigurement or disability, which can adversely impact quality of life.^3^ The recent Surgeon General’s call to action to prevent skin cancer at the population level emphasizes the public health importance of dealing with keratinocyte carcinomas.^8^ Because of their frequency, BCC and SCC are the fifth most expensive cancer at the population level, and, being more common in older adults, their management is of great importance to Medicare.^2, 3, 9^ It is estimated that in 2012 over 2 million Medicare beneficiaries underwent intervention for BCC or SCC.^2^

There are many potential management strategies for keratinocyte carcinoma, and they can be broadly grouped into eight main categories: (1) surgical excision without intraoperative evaluation of the margins, (2) surgical excision with intraoperative evaluation of the margins, (3) destruction via temperature gradients, (4) ionizing radiation, (5) photodynamic interventions, (6) medical therapies, along with (7) combinations of these therapies, and (8) watchful waiting. Surgical management is used most commonly, followed by radiation.^10–12^ In individuals over 65, surgery is used to treat 61 percent of keratinocyte carcinomas (excision 42% and Mohs micrographic surgery 19%) followed by electrodessication and curettage (39%).^13^ Specific surgical techniques include simple surgical excision with prespecified margins, surgery with intra-operative margin control (e.g. Mohs micrographic surgery or excision with examination of frozen sections), and curettage, which is usually combined with secondary destruction using electrodessication.^14^ Cryotherapy with liquid nitrogen is another destructive method. Ionizing radiation modalities include traditional external beam radiation as well as brachytherapy, in which radioactive implants are placed directly in the tumor. Topical medical treatments include topical chemotherapy (such as 5-fluorouracil) and topical immunomodulatory medications (such as imiquimod). Photodynamic therapy involves application of a topical photosensitizer (such as 5-aminoleveulinic acid (ALA) and methyl-ALA) followed by exposure to specific wavelengths of light to destroy tumor cells. New targeted systemic agents, such as vismodegib, for BCC^15^ are also available, but are reserved for advanced or metastatic cases and are used much less commonly than the modalities listed above. Additionally, active nonintervention (watchful waiting) has recently been advanced as a therapeutic strategy, particularly for patients with decreased life expectancy.^16, 17^

The choice of management strategy for an individual patient with a specific keratinocyte carcinoma is complex. Factors that are important include patient factors (e.g. age, frailty, immunosuppression, and personal preference) and tumor factors (e.g. histologic subtype, size, and location). A lack of clarity regarding the comparative efficacy and safety of the available options overall and in specific circumstances further complicates the choice of treatment for both physicians and patients.

There is general agreement that surgical removal is the gold standard. However, despite several dozen randomized controlled trials (RCTs) and nonrandomized comparative studies (NRCS), it is not clear how various surgical techniques and other therapeutic options perform relative to each other (e.g., see references^18–23^). None of the over 30 systematic reviews and meta-analyses (e.g., see references^24–31^) on this topic to date includes all treatment modalities for both BCC and SCC. The Australian and Finnish clinical practice guidelines for keratinocyte carcinoma management allude to the difficulty in interpreting the existing evidence-base, which comprises comparisons among pairs of several available treatments.^32, 33^ Furthermore, existing guidance is not based on systematic assessments of the evidence. It is hoped that the information in this review will be useful in the development of future guidelines, such as the guidelines on keratinocyte carcinomas from the American Academy of Dermatology, anticipated later in 2016.

Interventions for treating skin cancers differ substantially in cost and have a huge economic impact.^3, 9, 34, 35^ Payers are faced with increased utilization of costly therapies, such as brachytherapy, without clear evidence for relative benefits to justify increased costs.^36^

Estimates of keratinocyte carcinoma treatments’ comparative effectiveness and safety with respect to patient-relevant outcomes are needed to inform clinical decisionmaking and payer coverage decisions. The objective of this systematic review is to comprehensively collect and synthesize information on the comparative effectiveness and safety of each of the above-mentioned therapeutic strategies for both BCC and SCC.

## Key Questions

The review addresses two Key Questions for adult patients with basal cell or squamous cell carcinoma of the skin. Each Key Question will be answered separately for SCC and BCC:

Key Question 1 What is the comparative effectiveness of various interventions, overall and in subgroups of interest?
Key Question 2 How do the adverse events associated with the various interventions compare overall and in subgroups of interest?

## Analytic Framework

The analytic framework in Figure 1 depicts the chain of logic that evidence must support to link the studied interventions.

Figure 1 Analytic framework for treatments for basal cell and squamous cell carcinoma of the skin

Figure 1. The analytic framework, summarizes the key questions within the context of the PICO. It articulates the effectiveness of different types of treatments (1) Interventions that remove the lesion surgically, (2) Interventions that destroy the lesion thermally, (3) Interventions that destroy the lesion with ionizing radiation, (4) Photodynamic interventions, (5) Medical interventions, (6) Combination therapies, and (7) Monitoring or watchful waiting) for adults with non-melanoma skin cancers, specifically basal cell carcinoma or squamous cell carcinoma, on short and long term adverse events and patient-centered health outcomes, including cure rates, recurrence, morbidity, disfigurement, pain, quality of life, mortality, or hospitalizations.