# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Mary-Margaret Chren, M.D.
  Department of Dermatology
  University of California at San Francisco
  San Francisco VA Medical Center
  San Francisco, CA
- Graham Colditz, M.D.
  Department of Surgery
  Washington University School of Medicine
  St. Louis, MO
- Robert P. Dellavalle, M.D., Ph.D., M.S.P.H.
  Professor of Dermatology and Public Health
  University of Colorado School of Medicine
- Colorado School of Public Health
  Chief, Dermatology Service
  U.S. Department of Veterans Affairs
  Eastern Colorado Health Care System
  Denver, CO
- Naveed Nosrati, M.D.
  Division of Plastic Surgery
  Department of Surgery
  Indiana University
  Indianapolis, IN