# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows.

- Sarah Arron, M.D.^*^
  Dermatologist/Associate Professor
  University of California
  San Francisco, CA
- Elizabeth Toni Barnes, M.D.^*^
  Department of Radiation Oncology
  University of Toronto
  Toronto, ON, Canada
- An-Wen Chan, M.D.
  Associate Professor
  University of Toronto
  Toronto, ON, Canada
- Melody Eide, M.D., M.P.H.^*^
  Dermatologist/Assistant Professor of Medicine
  University of South Dakota Sanford School of Medicine
  Rapid City Medical Center
  Rapid City, SD
- Charles Hayley
  Medical Director/Medicaid, Noridian
  Lawrence, KS
- William Higgins, M.D., M.Be.
  Assistant Professor of Dermatology
  Brown University
  Providence, RI
- Eleni Linos, M.D.
  Dermatologist/Health Services Researcher
  University of California
  San Francisco, CA

* Provided input on Draft Report.