# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Sarah Arron, M.D.
  Dermatologist/Associate Professor
  University of California
  San Francisco, CA
- Melody J. Eide, M.D. M.P.H.
  Dermatologist/Assistant Professor of Medicine
  University of South Dakota Sanford School of Medicine
  Rapid City Medical Center
  Rapid City, SD
- Charles Hayley
  Medical Director/Medicaid, Noridian
  Lawrence, KS
- William Higgins, M.D., M.Be.
  Assistant Professor of Dermatology
  Brown University
  Providence, RI
- Eleni Linos, M.D.
  Dermatologist/Health Services Researcher
  University of California
  San Francisco, CA
- Dr. Yakub Puthawala, M.D.
  Radiation Oncologist
  Chief of Brachytherapy Services
  Rhode Island Hospital
  Providence, RI
- Patients (2)
  Rhode Island
  Names withheld for privacy protection