# Discussion

## Evidence Summary

Tables 82 and 83 summarize our conclusions on comparisons between types of intervention for treating basal cell carcinomas (BCCs) and squamous cell carcinoma in situ (SCCIS).

Table 82 Summary conclusions for BCC lesions and strength of the relevant evidence

Conclusion statement | RoB (evidence-base) | Consistency | Precision | Directness | Overall Rating | Comments
Recurrence, all BCC
1. Surgical interventions (A,B) and radiation (D) were associated with lower recurrence rates than interventions that destroy lesions with heat or cold (C), and PDT (E) (moderate to high strength of evidence); 2. Curettage (H) may have higher recurrence rates than surgical interventions (A,B) or radiation (D); 3. Imiquimod (F) was associated with recurrence rates that were not significantly different than that of surgical interventions (A,B); 4. [Imprecise data on the comparison on curettage and interventions that destroy lesions with heat or cold (C) or PDT (E)] | Moderate | Possibly consistent (No robust indications of inconsistency) | Varies by comparison from precise to imprecise. | Mix of direct and indirect data | 1. Moderate to High; 2. Low; 3. Low; 4. [Insufficient] | - Surgery/MMS (A,B) had significantly fewer recurrences than heat/cold, PDT, and curettage; not significantly fewer than radiation; and not significantly more than drugs (7 RCTs; 2 NRCSs); - Heat/cold (C) interventions had significantly more recurrences than surgery and radiation; not significantly more than drugs and curettage, and not significantly fewer than PDT (7 RCTs); - Radiation (D) had significantly fewer recurrences than thermal interventions and PDT, not significantly fewer than curettage, and not significantly more than surgery and drugs (3 RCTs); - PDT (E) had significantly more recurrences than radiation and surgery, and not significantly more than heat/cold, drugs, and curettage (6 RCTs, 1 NRCS); - Imiquimod (F) had more recurrences than surgery, but not significantly so (1 RCT); - Curettage (H) had significantly more recurrences than surgery, not significantly more recurrences than drugs and radiation, and not significantly fewer recurrences than PDT and heat/cold (2 RCTs)
Histologic clearance, all BCC
1. Surgical interventions (A,B) were associated with better histological clearance outcomes and were statistically significantly better than interventions that destroy lesions with heat or cold (C), PDT (E), drugs (F), and placebo (I,J).; 2. Interventions that destroy lesions with heat or cold (C), PDT (E), and drugs (F) have better histological outcomes than placebo (I,J); 3. [imprecise data on the relative comparisons of nonsurgical active interventions] | Moderate | Possibly consistent (No robust indications of inconsistency) | Varies by comparison from precise to imprecise. | Mix of direct and indirect data | 1. High; 2. Moderate to high; 3. [Insufficient] | - Surgery (A,B) performed significantly better than heat/cold, drugs, and placebo, and nonsignificantly better than PDT (2 RCTs); - Thermal interventions (C) performed significantly better than placebo, nonsignificantly better than drugs, nonsignificantly worse than PDT, and significantly worse than surgery (2 RCTs); - PDT (E) performed significantly better than placebo, nonsignificantly better than drugs and heat/cold, and nonsignificantly worse than surgery (7 RCTs, 1 NRCS); - Drugs (F) performed significantly better than placebo, nonsignificantly worse than PDT and heat/cold, and significantly worse than surgery (8 RCTs, 2 (NRCSs)
Clinical clearance, all BCC
1. Surgical interventions (A,B) were associated with better clinical clearance outcomes than PDT (E), drugs (F) and placebo (I,J); 2. All active treatments were associated with better clinical clearance outcomes than placebo; 3. [Imprecise data on relative comparisons between nonsurgical active treatments] | Moderate | Possibly consistent (No robust indications of inconsistency) | Varies by comparison from precise to imprecise. | Mix of direct and indirect data | 1. High; 2. Moderate to high; 3. [Insufficient] | - Surgery (A,B) performed statistically significantly better than drugs and placebo, and nonsignificantly better than heat/cold and PDT (4 RCTs); this comparison is less relevant as surgery ought to achieve 100% clinical clearance; - Thermal interventions (C)performed statistically significantly better than plecebo, nonsignificantly better than drugs and PDT, and nonsignificantly worse than surgery (3 RCTs); - PDT (E) performed statistically significantly better than placebo, nonsignificantly better than drugs, and nonsignificantly worse than surgery and heat/cold (7 RCTs); - Drugs (F) performed statistically significantly better than placebo, nonsignificantly worse than PDT and heat/cold, and significantly worse than surgery (5 RCTs)
Patient-reported cosmetic outcomes, all BCC
1. PDT is associated with better cosmetic outcomes than other intervention categories; 2. [Imprecise data on relative comparisons between nonsurgical active intervention categories] | Moderate | Possibly consistent (No robust indications of inconsistency) | Varies by comparison from precise to imprecise. Imprecise for most comparisons | Mix of direct and indirect data (most comparisons based on indirect data) | 1. Low; 2. Insufficient | - Surgery(A,B) had significantly better outcomes than heat/cold and radiation, significantly worse outcomes than PDT, and nonsignificantly worse outcomes than drugs (4 RCTs); - Thermal interventions (C)had significantly worse outcomes than surgery and PDT and nonsignificantly worse than radiation and drugs (2 RCTs); - Radiation (D) had nonsignificantly better outcomes than heat/cold, nonsignificantly worse outcomes than drugs, and significantly worse outcomes than PDT and surgery (2 RCTs); - PDT (E) had significantly better outcomes than surgery, heat/cold, and radiation and nonsignificantly better outcomes than drugs (4 RCTs); - Drugs (F) had better outcomes than surgery, heat/cold, and radiation, and nonsignificantly worse outcomes than PDT, but not statistically significantly so (1 RCT)
Observer-reported cosmetic outcomes, all BCC
1. PDT is associated with significantly better cosmetic outcomes than surgery (A,B); 2. [PDT may be associated with better cosmetic outcomes compared to nonsurgical active intervention categories]; 3. [Imprecise data on relative comparisons between heat/cold (C), radiation, and drugs (D)] | Moderate | Possibly consistent (No robust indications of inconsistency) | Varies by comparison from precise to imprecise. Imprecise for most comparisons | Mix of direct and indirect data (most comparisons based on indirect data) | 1. Moderate; 2. [Insufficient]; 3. [Insufficient] | - Surgery(A,B) had nonsignificantly better outcomes than radiation, significantly worse outcomes than PDT, and nonsignificantly worse outcomes than drugs, heat/cold, and placebo (4 RCTs, 1 NRCS); - Heat/cold interventions (C) had significantly better outcomes than radiation, nonsignificantly better outcomes than surgery, and nonsignificantly worse outcomes than PDT, drugs, and placebo (1 RCT); - Radiation (D) had significantly worse outcomes than heat/cold, PDT, drugs, and placebo, and nonsignificantly worse outcomes than surgery (1 RCT, 2 NRCS); - PDT (E) had significantly better outcomes than surgery and radiation, nonsignificantly better outcomes than drugs and heat/cold, and nonsignificantly worse outcomes than placebo (7 RCTs, 1 NRCS); - Drugs (F) had significantly better outcomes than radiation, nonsignificantly better outcomes than surgery and heat/cold, and nonsignificantly worse outcomes than PDT and placebo (1 RCT)
Adverse effects, all BCC
1. Serious adverse events, adverse events leading to discontinuation and infections of the treated site are uncommon with surgical interventions (A,B), heat or cold (C), PDT (E) and drugs (F); 2. For the interventions above, on average, 1 in 10 to 1 in 5 patients report experiencing pain after treatment | High (selective reporting bias) | Unclear (Consistency cannot be assessed) | Imprecise We do not report relative effects. Forecasted percentages of patients with adverse events have wide 95% CIs | Mix of direct and indirect data (most comparisons based on indirect data) | 1. Moderate; 2. Low | - For active interventions, point estimates for percentage of discontinuation of treatment, serious adverse events, and infection of the treatment site range from 0/not defined to 5.5%. Forecast CIs are wide (as high as 29%); - For active interventions, point estimates for the percentage of pain after treatment range between 9.9 and 21.6%. Forecast CIs are wide (as high as 88%)
Other outcomes, all BCC
[Evidence on quality of life, mental health, patient satisfaction, mortality, cost and resource use is reported in a minority of studies and its strength not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated]
Other analyses
[Subgroup analyses and analyses focusing on individual interventions are generally sparse and are not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated]

Note: When a summary conclusion cannot be made, the description is given in square brackets.

RoB = risk of bias; BCC = basal cell carcinoma; SCC = squamous cell carcinoma; MMS = Mohs micrographic surgery; PDT = photodynamic therapy; RCT = randomized controlled trial; NRCS = nonrandomized comparative study; CI = confidence interval

Table 83 Summary conclusions for SCCIS lesions and strength of the relevant evidence

Conclusion statement | RoB (evidence-base) | Consistency | Precision | Directness | Overall Rating | Comments
Recurrence, SCCIS
1. Interventions that destroy the lesions with heat or cold (C) and PDT (E) were associated with lower recurrence rates than 5 FU (F); 2. [Imprecise data on the relative effect of thermal interventions versus PDT] | Moderate | Possibly consistent (No robust indications of inconsistency) | Moderately precise. Varies by comparison from precise to imprecise. | Mix of direct and indirect data | 1. Low; 2. [Insufficient] | - Thermal interventions (C) had statistically significantly fewer recurrences than drugs, and not significantly fewer than PDT or placebo (2 RCTs); - PDT (E) had statistically significantly fewer recurrences than drugs, but not statistically significantly fewer than placebo or more than heat/cold (4 RCTs); - Drugs (F) had statistically significantly more recurrences than heat/cold and PDT, and not significantly more than placebo (1 RCT)
Histologic clearance, SCCIS
1. [Laser (C5) + PDT with ALA (E2) results in better histologic clearance over laser alone]; 2. 5-FU (F) results in better histologic clearance than placebo (I,J) | 1. Low; 2. High | [Not rated] | 1. Imprecise; 2. Precise | 1. Direct; 2. Direct | 1. [Insufficient]; 2. Low | [2 RCTs, 50 patients.]
Clinical clearance, all SCCIS
1. Examined types of active interventions (heat/cold [C], PDT (E), and drugs [5-FU, imiquimod; F]) were associated with better clinical outcomes than placebo; 2. [Imprecise data on relative comparisons between types of active interventions] | Moderate | Possibly consistent (No robust indications of inconsistency) | Varies by comparison from precise to imprecise. | Mix of direct and indirect data | 1. High; 2. [Insufficient] | - Thermal interventions (C) performed significantly better than placebo, and nonsignificantly better than drugs and PDT (4 RCTs); - PDT (E) performed significantly better than placebo, nonsignificantly better than drugs, and nonsignificantly worse than heat/cold (5 RCT); - Drugs (F) (5-FU, imiquimod) performed significantly better than placebo, and nonsignificantly worse than PDT and heat/cold (2 RCT)
Observer-reported cosmetic outcomes, SCCIS
1. Cryotherapy plus 5-FU (C1+F1) is associated with better outcomes than PDT (MAL) (E1); 2. [No difference between laser pretreatment of the lesion before PDT versus PDT alone] | Low | Unclear (Consistency cannot be rated) | 1. Precise; 2. Imprecise | Mix of direct and indirect data | 1. Moderate; 2. [Insufficient] | [2 RCTs, 204 patients.]
Adverse effects, SSCIS
1. [Serious adverse events, adverse events leading to discontinuation and infections of the treated site are uncommon with heat or cold (C), PDT (E) and drugs (F)]; 2. [On average, 1 in 4 and 1 in 3 patients report experiencing pain after treatment with PDT (E) and heat or cold (C), respectively] | High (selective reporting bias) | Unclear (Consistency cannot be assessed) | Imprecise We do not report relative effects. Forecasted percentages of patients with adverse events have wide 95% CIs | Mix of direct and indirect data (most comparisons based on indirect data) | 1. [Insufficient]; 2. [Insufficient] | [3 RCTs 292 patients.]
Other outcomes, SCCIS
[Evidence on patient-reported cosmetic outcomes, quality of life, mental health, patient satisfaction, mortality, cost and resource use id reported in a minority of studies and its strength not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated]
Other analyses
[Subgroup analyses and analyses focusing on individual interventions are generally sparse and are not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated] | [Not rated]

Note: When a summary conclusion cannot be made, the description is given in square brackets.

RoB = risk of bias; BCC = basal cell carcinoma; SCC = squamous cell carcinoma; MMS = Mohs micrographic surgery; PDT = photodynamic therapy; RCT = randomized controlled trial; NRCS = nonrandomized comparative study; CI = confidence interval

The conclusions in the Tables are general and do not cover all the analyses we explored. We estimated effects for 213 comparisons between intervention categories and 565 comparisons between individual interventions for the outcomes of interest, not counting information from dose-response analyses (e.g., Table 58) and from nonrandomized studies. Providing conclusions and rating the “strength of the evidence” for each of these hundreds of comparisons is not productive. Consumers of our report who have specific interests should consult the pertinent results.

Within the existing evidence, with respect to BCC recurrence, surgical treatments and radiation therapy appear to be (statistically significantly) better than interventions that destroy lesions with heat or cold, photodynamic therapy (PDT), or curettage. However, PDT was associated with improved cosmetic outcomes. With regards to drugs for the treatment of BCC, recurrence rates with imiquimod were not significantly different than with surgical excision in a single large randomized controlled trial (RCT) (Table 8).

Given that lack of recurrence is, essentially, cure from disease, these results support the use of surgical and radiation treatment for low-risk BCC. For SCCIS, the use of cryotherapy and PDT is supported over topical 5-fluorouracil with regards to recurrence. However, how these treatments perform for SCCIS compared with surgical treatments, which are commonly used in clinical practice, is not ascertainable based on the currently available evidence.

For patients and clinicians, though, cure is not the only important endpoint. Surgery, radiation and each of the other treatments under study are associated with benefits and drawbacks that patients and clinicians consider routinely. For example, while external beam radiation therapy is effective, its remote sequelae, such as skin atrophy and the development of secondary tumors, make it less advisable for younger patients. For patients for whom cosmesis is a primary concern, treatment with PDT may be preferable despite its higher recurrence rates. Despite sparse evidence on their ability to cure BCC and SCCIS, some patients may prefer the convenience provided by topical medical treatments such as 5-fluorouracil and imiquimod which can be applied by the patient at home; this contrasts with the multiple visits to hospitals or specialty clinics required for radiation therapy which are not be practical for some patients. Access to treatments will also impact clinical decisionmaking. Specialty care is not available in all communities; while primary care physicians can perform basic surgical procedures and prescribe topical medications, they do not have access to specialized treatments such as Mohs micrographic surgery (MMS), radiotherapy, and PDT.

We acknowledge that the clinical applicability of some of these results is limited. The analyses cannot adequately account for heterogeneity of the populations in included studies, particularly for low-risk BCCs, because, although the RCTs had comparable populations (see Tables 3–6), many did not stratify their results by histologic subtype (superficial or nodular) or location. Thus, we were unable to incorporate these important factors into the analyses. For example, radiation (because of its expense and poor cosmetic outcomes) is rarely used in routine clinical practice to treat low-risk BCC; its use is generally limited to patients with high risk or recurrent disease or for patients with contraindications to surgery. However, the four RCTs that included radiation arms did not differ significantly in population from the other studies included in the low-risk BCC network, with the exception that they included a larger percentage of lesions in high-risk (face, eyelids) areas. Conversely, use of topical drugs is generally limited to primary, superficial tumors. Therefore, comparisons of the efficacy of radiation and drugs for the low-risk BCCs included in our study may not be relevant in the clinical decision making for most patients and clinicians. That said, the analysis contains an RCT that looks at the direct comparison of radiation and imiquimod in a high-risk location (eyelids), so it might be that they are more relevant for low-risk lesions in high-risk locations.^67^

Perhaps the most striking observation is the dearth of information that is available comparing interventions for these very common cancers. For example, consider comparisons between interventions for BCC lesion recurrence (Figure 7), a most important outcome from a clinical, public health and cost perspective.

Within the existing evidence, with respect to BCC recurrence, surgical treatments and radiation therapy appear to be (statistically significantly) better than interventions that destroy lesions with heat or cold, PDT, or curettage. A comparison of surgery and imiquimod showed that surgery was not significantly better in terms of recurrence. Only 13 RCTs (n=1664 lesions) examining BCC recurrence were included, of which only 20 were treated with curettage. Further, the amount of evidence in the 10 comparisons with head to head data was limited: the number of RCTs per comparison ranged between 1 and 3, and the cumulative number of lesions ranged between 27 and 355.

For SCCs, data on recurrence are even sparser. First, only one RCT examined invasive SCCs, the subgroup of lesions that are most likely to recur or metastasize, and thus most important to evaluate. In clinical practice, these lesions are routinely treated with surgical excision with or without intraoperative margin evaluation, and in most cases are considered appropriate for Mohs surgery in the American Academy of Dermatology appropriate use criteria.^159^ Radiation is also commonly used for invasive SCC. The lack of evidence comparing efficacy among these commonly used treatments is striking.

For SCCISs, only 4 RCTs (348 lesions) compared 4 types of interventions, namely a drug (imiquimod), interventions that destroy lesions with heat or cold, PDT, and sham treatments (Figure 16 (B) and Table 61). Note that surgical interventions, radiation therapy and curettage, therapies commonly used in clinical practice, were not examined.

## Evidence Limitations

With few exceptions and for most outcomes, individual studies were deemed to have at most moderate risk of confounding, selection, or measurement biases. The risk of bias of individual studies was not a major determinant for the conclusions in Tables 82 and 83 Assessing impact of the risk of bias of individual studies on the conclusions of a network meta-analysis is not straightforward.^160^ The comparison effects estimated from a network meta-analysis are a combination of the estimated effects from head-to-head studies and from studies contributing through indirect comparisons. For example, assume that there is a highly-biased study in a network meta-analysis: it would be a concern primarily for the comparison it directly informs on, it may be a smaller (or even negligible) concern for comparisons that it informs indirectly, and it will be no concern for comparisons to which it contributes zero information.^161^ In this analysis we deemed qualitatively that risk of bias concerns would not change our conclusions. While qualitative-only assessments are precarious, we opted for high-level conclusions that may be robust.

By far the major concern, however, is that the evidence is sparse when one considers the richness of the clinical questions that can be posed. Comparisons between intervention categories are not as informative as comparisons between individual interventions. We have provided analyses at the individual intervention level, but opt not to draw conclusions based on them, because most are based on indirect data and small numbers. In addition, sample sizes were small leading to concerns about generalization.

A second consequence of the paucity of the evidence base is that one cannot directly address questions that may have important health and cost implications for insurers and patients. For example, there are no studies on the effectiveness of external radiation therapy delivered with portable machines in the office setting versus radiation therapy delivered in specialized facilities or versus other interventions. Empirical data on this radiation therapy modality would be useful because there are only limited data on radiation therapy to extrapolate from. Adjuvant treatment in the case of positive margins post excision or in the case of high-risk features, such as adjuvant radiotherapy and new drugs (including epidermal growth factor receptor inhibitors, such as cetuximab and erlotinib) were not within the scope of this review but also have utility in treating BCC and SCC lesions.

Other large gaps remain in the knowledge base: There is no information on subgroups of patients who have limited life expectancy, are frail, or who are immunocompromised (e.g., have chronic lymphocytic leukemiaand other malignancies, immunodeficiency disorders, or who receive immunomodulating or immunosuppressive treatments). There is limited or no information on high risk BCC lesions, and on invasive SCCs. There is limited data on patient- and lesion-specific modifiers of intervention effects.

The inconsistent reporting of adverse events was a challenge in this report. The specific adverse events reported and their definitions varied greatly among studies and treatment modalities. Because of the large number of individual adverse events reported, we grouped them for analysis. However, this can lead to misclassification, especially given that different treatments have different associated harms.

Finally, outcomes such as histological clearance and clinical clearance are surrogates for lesion recurrence. In particular, clinical clearance may be informative when comparing among PDT, medical, and radiation-based therapies, but is not an informative outcome for surgical interventions: any surgical treatment, regardless of margin control, removes all clinically visible tumor. Therefore, our conclusion in Table 82 that surgical interventions are better than all other interventions with respect to clinical clearance, while very likely to be true, is almost meaningless.

## Future Research Recommendations

We have identified a number of important gaps in the medical literature on the topic of treating BCC and SCC. They are described briefly in the following paragraphs.

More trials are needed comparing commonly used treatment modalities such as simple excision, Mohs surgery, PDT and topical medical therapy. Further, in order to justify routine use of various forms of radiotherapy for these patients, more trials comparing radiotherapy with other modalities are needed. As it stands, the lack of evidence on radiotherapy has led the American Academy of Dermatology to discourage the use of superficial radiotherapy and electronic brachytherapy for keratinocyte carcinomas except in select patients.^162, 163^ As these tumors are very common and generally have low morbidity and mortality, recruitment for such trials may not prove to be prohibitively difficult.

All trials for BCC and SCC should, where possible, use recurrent disease as a primary or secondary outcome as it is the most clinically important outcome. Trials should also attempt to incorporate measures of health care resource utilization, which were lacking in our review of the existing evidence save for one RCT and one NRCS.^20, 155^ Future trials would also benefit from standardization and consistent definition of all outcomes, particularly adverse events and patient-reported outcomes such as cosmesis. To this end, we encourage the development of a core outcome set as is being done for other skin diseases such as psoriasis (The International Dermatology Outcome Measures)^164^ and atopic dermatitis (Harmonising Outcome Measures for Eczema).

While more evidence is needed overall, future research should also focus on specific subgroups that have minimal evidence to date. Aggressive histologic subtypes of BCC, including infiltrative and sclerosing patterns, account for very little of the evidence found in our review. While their increased likelihood of recurrence has led to their inclusion as appropriate indications for Mohs surgery (except for lesions ≤0.5 cm on the trunk and extremities, whose appropriateness is rated as “uncertain”), there is scant evidence to support this.^159^ With regards to SCC, only one included RCT in this report concerns invasive SCC with the rest concerning in situ disease. Given that invasive SCC is responsible for mortality in 3900–8800 people in the United States each year,^6^ in addition to morbidity and health care costs, there is a clear need for comparative effectiveness research for invasive SCC treatments. No comparative evidence was found on keratinocyte carcinoma in high-risk groups such as organ transplant recipients and patients with other altered immune states such as HIV and Chronic Lymphocytic Leukemia (CLL). Patients with limited life-expectancy are another subgroup of interest who warrant study.

Given how common these tumors are and their burden on the health care system, research funding directed to determine the most effective and cost-effective measures for these tumors is needed. It is incumbent on funding agencies and health care payers to fund research examining important questions in this field. Patients, clinicians, payers, and research funders would benefit from a decision analysis of the management of BCC and SCC lesions.

Finally, better monitoring of population trends in BCCs and SCCs can help focus research on most consequential subtypes. Such monitoring can be performed by SEER (which currently ignores these cancers), the CDC, or large health organizations taking advantage of advances in health information technology. While the volume of these tumors makes surveillance logistically difficult and costly, advances in health information technology and big data analytic techniques should make it more feasible.^165^

## Conclusions

Based on sparse evidence, surgical, radiation and some topical drug treatments have lower recurrence rates than other modalities for the treatment of low-risk BCC, and PDT appears to have superior cosmetic outcomes. Large gaps remain in the literature regarding the comparison of individual interventions, and very little or no information on immunocompromised patients, patients with limited life expectancy, and on patients with specific lesion categories, including high risk BCCs and invasive SCCs. In order for clinicians, patients and payers to make informed decisions regarding the treatment of these lesions, new RCT or high-quality NRCS evidence is needed.