# Treatments for Basal Cell and Squamous Cell Carcinoma of the Skin: BCC Addendum

An updated search, using the same search strategy from the original report but limited to basal cell carcinoma (BCC), was conducted in May 2018. The methods used for this addendum were the same as those used in the original report. The updates are for individual interventions only.

## Summary of Studies

The updated search yielded three new studies^1–3^ and a paper with 5-year results from a fourth.^4^ Study characteristics for the three new studies are summarized in Table 1. Two compared photodynamic therapy (PDT) with 5-aminolevulinic acid (ALA) compared to PDT with methyl aminolevulinate (MAL).^2,^ ^3^ The third compared surgery, cryotherapy, and laser diathermy.^1^

Table 1 Characteristics of eligible randomized trials

Table 1 gives the baseline data for the three new studies identified. The arms ranged in size from 80 to 133 people, the mean age ranged from 64 to 69, percent female from 37 to 56. All studies reported small numbers of lesions on the head or neck (0-17%), and the summary risk of bas was low.

Study | Arm | N people | Age, Mean | Female % | Lesion A[rea] (mm^2^), D[iameter] (mm), or T[hickness] (mm) | Head and neck location (%) | Max FU (mo) | 1^*^ | 2^*^ | 3^*^ | 4^*^ | 5^*^ | 6^*^ | 7^*^ | ROB summary (across all outcomes)
Study | Arm | N people | Age, Mean | Female % | Lesion A[rea] (mm^2^), D[iameter] (mm), or T[hickness] (mm) | Head and neck location (%) | Max FU (mo) | RNG | AC | Bal | Bl-Pt | Bl-Dr | Bl-AS | <20% attrition | ROB summary (across all outcomes)
Kessels 2018; 28886209^2^ | PDT (MAL), E1 | 80 | 64 | 56 | D=11 | 1 | 12 | Yes | No | Yes | No | Yes | No | Yes | Low
Kessels 2018; 28886209^2^ | PDT (ALA), E2 | 82 | 66 | 51 | D=11 | 8 | 12 | Yes | No | Yes | No | Yes | No | Yes | Low
Morton 2018; 294326443^3^ | PDT (MAL), E1 | 133 | 67 | 50 | T=0.46 | >=17^**^ | 12 | Yes | Unsure | No | Yes | Yes | Yes | No | Low
Morton 2018; 294326443^3^ | PDT (ALA), E2 | 129 | 67 | 37 | T=0.41 | >=17^**^ | 12 | Yes | Unsure | No | Yes | Yes | Yes | No | Low
Zane 2017; 28291062^1^ | Surgical excision, A | 80 | 68 | 45 | NR | 0 | 3 | Yes | Yes | Yes | No | No | No | Yes | Low
Zane 2017; 28291062^1^ | Cryotherapy, C1 | 80 | 69 | 41 | NR | 0 | 3 | Yes | Yes | Yes | No | No | No | Yes | Low
Zane 2017; 28291062^1^ | Laser diathermy, C5 | 80 | 68 | 40 | NR | 0 | 3 | Yes | Yes | Yes | No | No | No | Yes | Low

* Design items: 1: RNG = Adequate generation of a randomized sequence reported; 2: AC=Adequate allocation concealment reported; 3: Bal=Group similarity at baseline; 4: Bl Pt = Adequate blinding of patients reported; 5: Bl Dr = Adequate blinding of providers reported; 6: Bl As = Adequate blinding of outcome assessors reported; 7: Less than 20% of sample size missing for any eligible outcome in any arm.

** Neck lesions are counted with torso/extremities.

Abbreviations: PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, INF=interferon; NR=not reported.

### Recurrence

The updated evidence graph for recurrence with respect to individual treatments is shown in Figure 1. It replaces the graph shown in Figure 7 of the report.

Figure 1 Evidence graph of RCTs evaluating recurrence in BCCs across individual interventions

Abbreviations: MMS=Mohs micrographic surgery, PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, INF=interferon. Layout as in Figure 1. This evidence graph comprises three connected networks. The first is the largest group of nodes and is not labeled explicitly. The second and third connected networks are labeled explicitly.

This is the topology map of the network meta-analysis of the interventions for recurrence for all BCCs compared in RCTs. Sixteen interventions or combinations of interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, curettage and cryotherapy, curettage and diathermy, and laser), radiation (external or brachytherapy), PDT (MAL or ALA), drugs (imiquimod); or combinations of interventions (excision or Mohs, external radiation or brachytherapy, imiquimod and Mohs, MAL PDT and laser). Of the possible pairwise comparisons, 20 are covered by direct study comparisons as indicated by lines between the treatment circles. Most comparisons were covered by only a single RCT, and most treatment were compared with only one or two other treatments. Surgical excision was the most common comparator, being directly compared with MAL PDT, ALA PDT, curettage and diathermy, curettage and cryotherapy, and Mohs surgery.

Table 2 replaces Table 11 from the original report, giving the relative effects for the larger subgraph. The results from the smaller network, given in Table 12 of the original report, were unaffected by this update. The new data changed the direction of the comparison for MAL- versus ALA-PDT from an odds ratio of 0.65 (95% CI 0.25, 1.73) to an odds ratio of 1.07 (95% CI 0.34, 3.35). Nevertheless, the comparison remains nonsignificant, with wide confidence intervals. Similarly, surgery went from being better than Mohs surgery (MMS) (OR 1.04, 95% CI 0.21, 5.23) to worse (OR 0.86; 95% CI 0.13, 5.76), again with wide confidence intervals. MMS is no longer statistically significantly better than cryotherapy or PDT, with or without laser therapy. Other comparisons changed in magnitude, but not in direction or statistical significance.

Table 2 Relative odds ratios for recurrence in the larger network in Figure 1

Table 2 gives the relative odds ratios for all comparisons for recurrence. Only 17 of the 91 comparisons were direct and only 10 of the 91 comparisons was statistically significant. Surgery was significantly less likely to lead to recurrence than cryotherapy (OR 0.13, 95% CI 0.03, 0.48), curettage and cryotherapy (OR 0.16, 95% CI 0.03, 0.96), laser and ALA PDT (OR 0.10, 95% CI 0.01, 0.78), MAL PDT (OR 0.16, 95% CI 0.05, 0.5), ALA PDT (OR 0.17, 95% CI 0.05, 0.6), 5-fluorouracil (OR 0.10, 95% CI 0.02, 0.56), or imiquimod (OR 0.20, 95% CI 0.05, 0.76). Cryotherapy was significantly more likely to lead to recurrence than external radiotherapy (OR 8.04, 95% CI 1.28, 50.51). Finally, external radiotherapy was significantly less likely to lead to recurrence than 5-fluorouracil (OR0.10, 95% CI 0.01, 0.97).

Surgery | 0.86 (0.13, 5.76) | 0.70 (0.02, 21.26) | 0.13 (0.03, 0.48) | 0.53 (0.06, 4.83) | 0.16 (0.03, 0.96) | 0.25 (0.03, 2.18) | 0.10 (0.01, 0.78) | 1.02 (0.14, 7.39) | 0.16 (0.05, 0.5) | 0.17 (0.05, 0.6) | 0.10 (0.02, 0.56) | 0.20 (0.05, 0.76) | 0.19 (0.03, 1.36)
| MMS | 0.82 (0.02, 30.59) | 0.15 (0.02, 1.13) | 0.62 (0.04, 9.79) | 0.19 (0.02, 2.2) | 0.29 (0.02, 4.13) | 0.11 (0.01, 1.5) | 1.19 (0.1, 14.54) | 0.18 (0.03, 1.26) | 0.19 (0.03, 1.45) | 0.12 (0.01, 1.19) | 0.24 (0.03, 1.88) | 0.22 (0.02, 2.89)
| | MMS + INF | 0.18 (0.01, 5.58) | 0.76 (0.01, 38.1) | 0.23 (0.01, 9.48) | 0.35 (0.01, 16.35) | 0.14 (<0.005, 6.06) | 1.45 (0.03, 60.47) | 0.22 (0.01, 6.5) | 0.24 (0.01, 7.24) | 0.15 (<0.005, 5.33) | 0.29 (0.01, 9.21) | 0.26 (0.01, 11.82)
| | | Cryotherapy | 4.19 (0.4, 43.92) | 1.29 (0.18, 9.3) | 1.95 (0.22, 17.33) | 0.76 (0.09, 6.24) | 8.04 (1.28, 50.51) | 1.23 (0.39, 3.83) | 1.31 (0.38, 4.56) | 0.81 (0.14, 4.53) | 1.61 (0.39, 6.66) | 1.46 (0.17, 12.54)
| | | | Curettage and Diathermy | 0.31 (0.02, 4.58) | 0.47 (0.03, 8.55) | 0.18 (0.01, 3.12) | 1.92 (0.12, 30.51) | 0.29 (0.03, 2.82) | 0.31 (0.03, 3.21) | 0.19 (0.01, 2.55) | 0.38 (0.04, 4.12) | 0.35 (0.03, 3.94)
| | | | | Curettage and Cryotherapy | 1.51 (0.11, 20.74) | 0.59 (0.05, 7.51) | 6.24 (0.53, 72.8) | 0.95 (0.15, 6.21) | 1.01 (0.14, 7.16) | 0.63 (0.07, 5.91) | 1.25 (0.17, 9.21) | 1.13 (0.09, 14.22)
| | | | | | Laser + PDT (MAL) | 0.39 (0.03, 5.96) | 4.12 (0.29, 57.8) | 0.63 (0.08, 4.68) | 0.67 (0.08, 5.93) | 0.42 (0.04, 4.64) | 0.83 (0.09, 7.59) | 0.75 (0.05, 11.74)
| | | | | | | Laser + PDT (ALA) | 10.59 (0.81, 138.59) | 1.62 (0.21, 12.24) | 1.72 (0.23, 12.82) | 1.07 (0.1, 11.47) | 2.12 (0.24, 18.39) | 1.92 (0.13, 28.17)
| | | | | | | | External Radiotherapy | 0.15 (0.02, 1.01) | 0.16 (0.02, 1.17) | 0.10 (0.01, 0.97) | 0.20 (0.03, 1.52) | 0.18 (0.01, 244)
| | | | | | | | | PDT (MAL) | 1.07 (0.34, 3.35) | 0.66 (0.15, 2.89) | 1.31 (0.4, 4.28) | 1.19 (0.15, 9.32)
| | | | | | | | | | PDT (ALA) | 0.62 (0.11, 3.44) | 1.23 (0.3, 5.02) | 1.11 (0.13, 9.41)
| | | | | | | | | | | 5-FU | 1.99 (0.43, 9.21) | 1.8 (0.16, 19.87)
| | | | | | | | | | | | Imiquimod | 0.91 (0.1, 7.99)
| | | | | | | | | | | | | Curettage

MMS=Mohs micrographic surgery, PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, 5-FU= 5-fluorouracil, INF=interferon, BCC=basal cell carcinoma. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

Table 3 replaces tables 13 and 27 from the main report. There is no change in the overall findings for recurrence, though the mean percentages changed some in magnitude.

Table 3 Mean outcome rates for specific interventions for basal cell carcinoma

Table 3 gives the mean outcome rates for recurrence and lack of histological clearance. For recurrence, in the primary network, the interventions are, in order, Surgical excision (3.3%, 95% CI 1.3, 7.8), MMS (3.8%, 95% CI 0.7, 18.9), MMS+INF (4.6%, 95% CI 0.2, 56.2), Cryotherapy (21.0%, 95% CI 9.0, 41.4), Diathermy+curettage (5.9%, 95% CI 0.7, 34.9), %, 95% CI Cryotherapy+curettage (17.1%, 95% CI 3.6, 53.4), Laser+PDT (MAL) (12.0%, 95% CI 1.8, 49.6), Laser+PDT (ALA) (25.9%, 95% CI 5.1, 69.6), External radiation (3.2%, 95% CI 0.6, 16.1), PDT (MAL) (17.8%, 95% CI 9.1, 31.8), PDT (ALA) (16.9%, 95% CI 7.3, 34.4), 5-fluorouracil (24.7%, 95% CI 7.1, 58.4), Imiquimod (14.1%, 95% CI 5.4, 32.4), Curettage (15.4%, 95% CI 2.6, 55.3). In the second network, Surgical excision or Mohs (0.6%, 95% CI 0.1, 4.0) performed better than external radiation or brachytherapy (4.6%, 95% CI 2.3, 9.0). For Lack of histological clearance, in the primary network, the interventions are, in order, Surgical excision (1.7%, 95% CI 0.3, 9.9), Cryotherapy (11.7%, 95% CI 3.1, 35.3), Laser (33.7%, 95% CI 10.9, 67.9), Laser + PDT (MAL) (37.5%, 95% CI 4.7, 87.9), PDT (MAL) (14.5%, 95% CI 5.4, 33.6), PDT (ALA) (11.0%, 95% CI 2.1, 41.4), 5-FU (5.5%, 95% CI 0.5, 38.8), Imiquimod (28.6%, 95% CI 14.6, 48.6), Ingenol (77.1%, 95% CI 23.7, 97.3), Other medical (78.1%, 95% CI 23.9, 97.6), No treatment (81.8%, 95% CI 48.3, 95.6), Placebo (86.3%, 95% CI 72.1, 93.9). In the second network, Surgery + PDT (MAL) (36.4%, 95% CI 14.3, 66.1), Surgery + PDT (MAL) + curettage (20.0%, 95% CI 5.0, 54.1), Surgery + PDT (ALA) (36.4%, 95% CI 14.3, 66.1) Surgery + PDT (ALA) + curettage (18.2%, 95% CI 4.6, 50.7), and in the third network Imiquimod + curettage (10.0%, 95% CI 1.4, 46.7), Curettage (40.0%, 95% CI 15.8, 70.3)

Intervention | Recurrence Mean Percent (95% Cl) | Intervention | Lack of Histological Clearance Mean Percent (95% Cl)
First network in Figure 1 | | First network in Figure 2
Surgical excision (A) | 3.3 (1.3, 7.8) | Surgical excision (A) | 1.7 (0.3, 9.9)
MMS (B) | 3.8 (0.7, 18.9) | Cryotherapy (C1) | 11.7 (3.1, 35.3)
MMS+INF (B+F3) | 4.6 (0.2, 56.2) | Laser (C5) | 33.7 (10.9, 67.9)
Cryotherapy (C1) | 21.0 (9.0, 41.4) | Laser + PDT (MAL) (C5+E1) | 37.5 (4.7, 87.9)
Diathermy+curettage (C3) | 5.9 (0.7, 34.9) | PDT (MAL) (E1) | 14.5 (5.4, 33.6)
Cryotherapy+curettage (C4) | 17.1 (3.6, 53.4) | PDT (ALA) (E2) | 11.0 (2.1, 41.4)
Laser+PDT (MAL) (C5+E1) | 12.0 (1.8, 49.6) | 5-FU (F1) | 5.5 (0.5, 38.8)
Laser+PDT (ALA) | 25.9 (5.1, 69.6) | Imiquimod (F2) | 28.6 (14.6, 48.6)
External radiation (D1) | 3.2 (0.6, 16.1) | Ingenol (F4) | 77.1 (23.7, 97.3)
PDT (MAL) (E1) | 17.8 (9.1, 31.8) | Other medical (F5) | 78.1 (23.9, 97.6)
PDT (ALA) (E2) | 16.9 (7.3, 34.4) | No treatment (I) | 81.8 (48.3, 95.6)
5-fluorouracil (F1) | 24.7 (7.1, 58.4) | Placebo (J) | 86.3 (72.1, 93.9)
Imiquimod (F2) | 14.1 (5.4, 32.4) | Second network in Figure 2
Curettage (H) | 15.4 (2.6, 55.3) | Surgery + PDT (MAL) (A+E1) | 36.4 (14.3, 66.1)
Second network in Figure 1 | | Surgery + PDT (MAL) + curettage (A+E1+H) | 20.0 (5.0, 54.1)
Surgical excision or Mohs (A\|B) | 0.6 (0.1, 4.0) | Surgery + PDT (ALA) (A+E2) | 36.4 (14.3, 66.1)
External radiation or brachytherapy (D1\|D2) | 4.6 (2.3, 9.0) | Surgery + PDT (ALA) + curettage (A+E2+H) | 18.2 (4.6, 50.7)
| | Third network in Figure 2
| | Imiquimod + curettage (F2+H) | 10.0 (1.4, 46.7)
| | Curettage (H) | 40.0. (15.8, 70.3)

### Lack of Histologic Clearance

The evidence graph for lack of histologic clearance with respect to individual treatments in Figure 2 replaces the one in Figure 8 of the main report

Figure 2 Evidence graph for lack of BCC histological clearance

Abbreviations: MMS=Mohs micrographic surgery, PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, INF=interferon. Layout as in Figure 1. This evidence graph comprises three connected networks. The first is the largest group of nodes and is not labeled explicitly. The second and third connected networks are labeled explicitly.

This is the topology map of the network meta-analysis of the interventions for lack of histological clearance for all BCCs compared in RCTs. Seventeen interventions or combinations of interventions are displayed, grouped by type of intervention. The interventions are: surgical (excision or Mohs surgery), thermodynamic (cryotherapy, laser), PDT (MAL or ALA), drugs (imiquimod, 5-FU, ingenol, and other), and placebo or no treatment; or combinations of interventions (imiquimod and Mohs, imiquimod and curettage, MAL PDT and laser, and combinations of excision plus MAL or ALA PDT with or without curettage). Eleven of these interventions are connected in the primary graph, with only MAL PDT connected to more than three others; most were connected to only one or two. MAL PDT was connected to MAL PDT plus laser, excision, 5-FU, imiquimod, and placebo. There are also two subgraphs: One connects surgery, MAL PDT, and curettage; the other connects Imiquimod with and without curettage.

Table 4 replaces Table 24 of the main report. Tables 25 and 26 remain unchanged. Similar to what was seen in recurrence, MAL-PDT changed from performing non-significantly worse than ALA-PDT (OR 0.67; 95% CI 0.30, 15.3) to non-significantly better (OR 1.37; 95% CI 0.17, 10.74), with wide confidence intervals. Surgery’s superiority over MAL-PDT with or without Laser, and Ingenol went from nonsignificant to significant. Ingenol performed statistically significantly worse than PDT and 5-FU. Other comparisons changed in magnitude, but not in direction or statistical significance. Table 3 replaces Table 27 from the report, but as was the case with recurrence, there are no changes, except in magnitude and precision.

Table 4 Relative odds ratios for lack of histological clearance between individual interventions (large network in Figure 2)

Table 4 gives the relative odds ratios for all comparisons for lack of histological clearance. Only 17 of the 66 comparisons were direct and 25 of the 66 comparisons was statistically significant. Surgery was significantly better than laser (OR 0.03, 95% CI <0.005, 0.35), laser + MAL PDT (OR 0.03, 95% CI <0.005, 0.64), MAL PDT (OR 0.1, 95% CI 0.01, 0.87), Imiquimod (OR 0.04, 95% CI 0.01, 0.33), Ingenol (OR 0.01, 95% CI <0.005, 0.1), other medical (OR <0.005, 95% CI <0.005, 0.1), no treatment (OR <0.005, 95% CI <0.005, 0.04), placebo (OR <0.005, 95% CI <0.005, 0.02); cryotherapy, ALA PDT, and 5-FU were significantly better than Ingenol, other medical, no treatment, or placebo; laser and Imiquimod were better than no treatment or placebo.

Surgery | 0.13 (0.01, 1.33) | 0.03 (<0.005, 0.35) | 0.03 (<0.005, 0.64) | 0.1 (0.01, 0.87) | 0.14 (0.01, 1.77) | 0.3 (0.01, 6.11) | 0.04 (0.01, 0.33) | 0.01 (<0.005, 0.1) | <0.005 (<0.005, 0.1) | <0.005 (<0.005, 0.04) | <0.005 (<0.005, 0.02)
| Cryotherapy | 0.26 (0.03, 1.94) | 0.22 (0.01, 3.9) | 0.78 (0.13, 4.68) | 1.07 (0.11, 10.12) | 2.29 (0.14, 36.81) | 0.33 (0.06, 1.73) | 0.04 (<0.005, 0.63) | 0.04 (<0.005, 0.62) | 0.03 (<0.005, 0.24) | 0.02 (<0.005, 0.11)
| | Laser | 0.85 (0.05, 15.04) | 3 (0.5, 18.11) | 4.11 (0.43, 39.1) | 8.78 (0.54, 142.06) | 1.27 (0.24, 6.69) | 0.15 (0.01, 2.42) | 0.14 (0.01, 2.39) | 0.11 (0.01, 0.94) | 0.08 (0.02, 0.43)
| | | Laser + PDT (MAL) | 3.54 (0.23, 54.09) | 4.85 (0.23, 101.95) | 10.35 (0.33, 328.52) | 1.5 (0.11, 20.96) | 0.18 (0.01, 5.62) | 0.17 (0.01, 5.48) | 0.13 (0.01, 2.55) | 0.1 (0.01, 1.35)
| | | | PDT (MAL) | 1.37 (0.17, 10.74) | 2.92 (0.21, 40.58) | 0.42 (0.11, 1.7) | 0.05 (<0.005, 0.69) | 0.05 (<0.005, 0.68) | 0.04 (0.01, 0.26) | 0.03 (0.01, 0.11)
| | | | | PDT (ALA) | 2.13 (0.11, 41.16) | 0.31 (0.04, 2.15) | 0.04 (<0.005, 0.7) | 0.03 (<0.005, 0.69) | 0.03 (<0.005, 0.29) | 0.02 (<0.005, 0.14)
| | | | | | 5-FU | 0.14 (0.01, 1.83) | 0.02 (<0.005, 0.5) | 0.02 (<0.005, 0.49) | 0.01 (<0.005, 0.23) | 0.01 (<0.005, 0.12)
| | | | | | | Imiquimod | 0.12 (0.01, 1.5) | 0.11 (0.01, 1.48) | 0.09 (0.01, 0.53) | 0.06 (0.02, 0.22)
| | | | | | | | Ingenol | 0.94 (0.03, 28.3) | 0.75 (0.04, 12.94) | 0.53 (0.04, 6.78)
| | | | | | | | | Other medical | 0.79 (0.04, 14.35) | 0.57 (0.04, 7.56)
| | | | | | | | | | No treatment | 0.71 (0.12, 4.34)
| | | | | | | | | | | Placebo/sham

PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, BCC=basal cell carcinoma, MMS = Mohs micrographic surgery. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

### Patient- and Observer-Reported Cosmetic Outcomes

The report only gives results for intervention categories for these outcomes, so this data is additional. Figure 3 gives the evidence graph for patient-reported cosmetic outcomes, while Figure 4 gives the evidence graph for observer-reported cosmetic outcomes.

Figure 3 Evidence graph for patient-reported cosmetic outcomes of BCC treatment

Abbreviations: MMS=Mohs micrographic surgery, PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, INF=interferon. Layout and naming of connected networks as in Figure 1.

This is the topology map of the network meta-analysis of the interventions for patient-reported cosmetic outcomes compared in RCTs. The 5 interventions or combinations of interventions in the primary network include surgical excision, thermodynamic (cryotherapy or laser), PDT (ALA or MAL). There are three subgraph that include radiation compared to surgery. Three other subgraphs compare radiation (external or brachytherapy) to surgery (excision or Mohs), external radiation to imiquimod, and Mohs to Mohs with PDT (MAL).

Figure 4 Evidence graph for observer-reported cosmetic outcomes of BCC treatments

Abbreviations: MMS=Mohs micrographic surgery, PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, INF=interferon. Layout and naming of connected networks as in Figure 1.

This is the topology map of the network meta-analysis of the interventions for patient-reported cosmetic outcomes compared in RCTs. The 9 interventions or combinations of interventions in the primary network include surgical excision, thermodynamic (cryotherapy or laser), PDT (ALA or MAL), medical (imiquimod and 5-FU), and placebo. Of the possible pairwise comparisons, 10 are covered by direct study comparisons. There a second subgraph that includes radiation (external or brachytherapy) compared to surgery (excision or Mohs).

As shown in Figure 3, patient-reported cosmetic outcomes comparisons in RCTs were sparse and involved four treatment networks. Table 5 gives the analysis of the largest network of 7 trials comparing 5 treatments (739 total lesions, range 23 to 169). Each of the other three networks comprised a single RCT. In one, an RCT (n=27) did not find a difference between external radiation and imiquimod (OR 0.81, 95% CI 0.01, 43.6). Another RCT favored surgical excision or Mohs micrographic surgery over external radiation/brachytherapy (n=244; OR 2.15, 95% CI 1.2, 3.86). In the last RCT, 7/7 patients rated their outcome as good or better after methyl-aminolevulinic acid PDT followed by Mohs micrographic surgery and 10/10 after Mohs surgery alone.

Table 6 gives outcome rates for each intervention subgraph. In general, patients rated their cosmetic outcomes as good or better significantly more often with PDT using methyl-aminolevulinic acid (93.8%, 95% CI 79.2, 98.3) or aminolevulinic acid (95.8%, 95% CI 84.2, 99.0) compared with standard excision (77.8%, 95% CI 44.8, 93.8), cryotherapy (51.1%, 95% CI 15.8, 85.4) or PDT combined with laser preparation of the lesion (20%, 95% CI 1.9, 76.6). All other comparisons were statistically not significant and had wide confidence intervals.

Table 5 Relative odds ratios for patient-reported cosmetic outcome

Table 5 gives the relative odds ratios for all comparisons for patient reported good or better cosmetic outcome. Five of the 10 comparisons were direct and 4 were statistically significant. Surgery, cryotherapy, and Laser + PDT were better than MAL or ALA PDT alone.

Surgery | 3.35 (0.58, 19.5) | 14.01 (0.97, 201.93) | 0.23 (0.08, 0.65) | 0.16 (0.05, 0.49)
| Cryotherapy | 4.18 (0.23, 77.64) | 0.07 (0.01, 0.39) | 0.05 (0.01, 0.28)
| | Laser + PDT (MAL) | 0.02 (<0.005, 0.21) | 0.01 (<0.005, 0.15)
| | | PDT (MAL) | 0.67 (0.38, 1.15)
| | | | PDT (ALA)

PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

Table 6 Mean outcome rates by specific intervention (all BCC lesions)

Table 6 gives the mean outcome rates for patient and observer reported cosmetic outcomes. For patient reported, the interventions are, in order, First network: Surgical excision (77.8%, 95% CI 44.8, 93.8), Cryotherapy (51.1%, 95% CI 15.8, 85.4), Laser+PDT (MAL) (20.0%, 95% CI 1.9, 76.6), PDT (MAL) (93.8%, 95% CI 79.2, 98.3), PDT (ALA) (95.8%, 95% CI 84.2, 99.0).Second network: External radiation (96.2%, 95% CI 59.7, 99.8), Imiquimod (96.9%, 95% CI 65.0, 99.8). Third network: Surgical excision or Mohs (80.9%, 95% CI 73.3, 86.8), External radiation or brachytherapy (66.4%, 95% CI 57.2, 74.5). Fourth network: MMS (95.5%, 95% CI 5.2, 99.7), MMS +PDT (MAL) (93.8%, 95% CI 46.1, 99.6). For observer reported, the interventions are, in order, first network: Surgical excision (46.7%, 95% CI 19.4, 76.1), Cryotherapy (60.1%, 95% CI 23.1, 88.3), Laser+PDT (MAL) (93.5%, 95% CI 63.5, 99.2), Laser+PDT (ALA) (5.9%, 95% CI 0.5, 45.9), PDT (MAL) (87.9%, 95% CI 73.3, 95.1), PDT (ALA) (53.4%, 95% CI 15.9, 87.4), 5-fluorouracil (57.5%, 95% CI 13.0, 92.4), Imiquimod (61.0%, 95% CI 24.8, 88.1), Placebo/sham (93.3%, 95% CI 41.5, 99.6). Second network: Surgical excision or Mohs (78.6%, 95% CI 70.8, 84.8), External radiation or brachytherapy (39.8%, 95% CI 31.2, 49.1).

Intervention | Patient-reported good or better cosmetic outcome Mean Percent (95% CI) | Intervention | Observer-reported good or better cosmetic outcome Mean Percent (95% CI)
First network in Figure 3 | | First network in Figure 4
Surgical excision (A) | 77.8 (44.8, 93.8) | Surgical excision (A) | 46.7 (19.4, 76.1)
Cryotherapy (C1) | 51.1 (15.8, 85.4) | Cryotherapy (C1) | 60.1 (23.1, 88.3)
Laser+PDT (MAL) (C5+E1) | 20.0 (1.9, 76.6) | Laser+PDT (MAL) (C5+E1) | 93.5 (63.5, 99.2)
PDT (MAL) (E1) | 93.8 (79.2, 98.3) | Laser+PDT (ALA) (C5+E2) | 5.9 (0.5, 45.9)
PDT (ALA) (E2) | 95.8 (84.2, 99.0) | PDT (MAL) (E1) | 87.9 (73.3, 95.1)
Second network in Figure 3 | | PDT (ALA) (E2) | 53.4 (15.9, 87.4)
External radiation (D1) | 96.2 (59.7, 99.8) | 5-fluorouracil | 57.5 (13.0, 92.4)
Imiquimod (F2) | 96.9 (65.0, 99.8) | Imiquimod | 61.0 (24.8, 88.1)
Third network in Figure 3 | | Placebo/sham | 93.3 (41.5, 99.6)
Surgical excision or Mohs (A\|B) | 80.9 (73.3, 86.8) | Second network in Figure 4
External radiation or brachytherapy (D1\|D2) | 66.4 (57.2, 74.5) | Surgical excision or Mohs (A\|B) | 78.6 (70.8, 84.8)
Fourth network in Figure 3 | | External radiation or brachytherapy (D1\|D2) | 39.8 (31.2, 49.1)
MMS (B) | 95.5 (55.2, 99.7)
MMS+PDT (MAL) (B+E1) | 93.8 (46.1, 99.6)

MMS=Mohs micrographic surgery, PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, INF=interferon; BCC=basal cell carcinoma; CI=confidence interval

Observer-reported cosmetic outcomes were evaluated in 11 RCTs and 1 NRCS. The larger network in Figure 4 consists of 10 RCTs that compare 9 treatments (3,505 total lesions, samples ranging from 23 to 563). As can be seen on Tables 6 and 7, good or better cosmetic outcomes were estimated to be more common for MAL-PDT than for ALA-PDT, surgical excision, cryotherapy, topical 5-fluorouracil, and imiquimod. The smaller network in Figure 4 was a single RCT that favored surgical excision or Mohs micrographic surgery over external radiation/brachytherapy (n=244; odds ratio 5.56 (3.17, 9.76]).

Table 7 Relative odds ratios for observer-reported good or better cosmetic outcome

Table 7 gives the relative odds ratios for all comparisons for observer reported good or better cosmetic outcome. Ten of the 36 comparisons were direct and 6 of 36 were statistically significant. Surgery was better than MAL PDT with (OR 0.06, 95% CI 0.01, 0.73) or without (OR 0.12, 95% CI 0.02, 0.61) laser. Cryotherapy (OR 24.1, 95% CI 1.12, 517.07) and MAL PDT with laser (OR 228.74, 95% CI 7.99, 6544.69) were better than ALA PDT with laser. ALA PDT with laser was better than MAL PDT alone (OR 0.01, 95% CI <0.005, 0.14). MAL PDT with laser was also better than Imiquimod (OR 0.04, 95% CI <0.005, 0.83).

Surgery | 0.58 (0.07, 4.58) | 0.06 (0.01, 0.73) | 14.02 (0.76, 257.68) | 0.12 (0.02, 0.61) | 0.76 (0.08, 7) | 0.65 (0.05, 8.31) | 0.56 (0.07, 4.24) | 0.06 (<0.005, 1.61)
| Cryotherapy | 0.11 (0.01, 1.49) | 24.1 (1.12, 517.07) | 0.21 (0.03, 1.36) | 1.31 (0.12, 14.7) | 1.11 (0.07, 17.02) | 0.96 (0.1, 9.05) | 0.11 (<0.005, 3.18)
| | Laser + PDT (MAL) | 228.74 (7.99, 6544.69) | 1.96 (0.19, 20.04) | 12.48 (0.78, 199.23) | 10.56 (0.5, 222.5) | 9.14 (0.66, 125.66) | 1.02 (0.03, 39.29)
| | | Laser + PDT (ALA) | 0.01 (<0.005, 0.14) | 0.05 (<0.005, 1.31 | 0.05 (<0.005, 1.4) | 0.04 (<0.005, 0.83) | <0.005 (<0.005, 0.23)
| | | | PDT (MAL) | 6.35 (0.82, 49.22) | 5.38 (0.48, 59.82) | 4.65 (0.74, 29.3) | 0.52 (0.02, 11.97)
| | | | | PDT (ALA) | 0.85 (0.05, 14.54) | 0.73 (0.07, 7.92) | 0.08 (<0.005, 2.66)
| | | | | | 5-FU | 0.87 (0.06, 12.85) | 0.1 (<0.005, 3.93)
| | | | | | | Imiquimod | 0.11 (<0.005, 3.23)
| | | | | | | | Placebo/sham

PDT=photodynamic therapy; ALA= 5-aminolevulinic acid, MAL=methyl aminolevulinate, FU= fluorouracil, BCC=basal cell carcinoma, MMS = Mohs micrographic surgery. Cells shaded gray indicate that the estimate is based only on indirect comparisons; bold-italic numbers indicate statistical significance. Results are given as odds ratios (95% confidence intervals).

## References

1 Zane C, Facchinetti E, Arisi M, . Pulsed CO2 Laser Ablation of Superficial Basal Cell of Limbs and Trunk: A Comparative Randomized Clinical Trial With Cryotherapy and Surgical Ablation. Dermatol Surg. 2017 Jul;43(7):920–7. doi: 10.1097/dss.0000000000001106. PMID: 28291062.28291062
2 Kessels J, Kreukels H, Nelemans PJ, . Treatment of superficial basal cell carcinoma by topical photodynamic therapy with fractionated 5-aminolaevulinic acid 20% vs. two-stage topical methyl aminolaevulinate: results of a randomized controlled trial. Br J Dermatol. 2017 Sep 8. doi: 10.1111/bjd.15967. PMID: 28886209.28886209
3 Morton CA, Dominicus R, Radny P, . A randomized, multi-national, non-inferiority, phase III trial to evaluate the safety and efficacy of BF-200 ALA gel versus MAL cream in the treatment of non-aggressive basal cell carcinoma with photodynamic therapy (PDT). Br J Dermatol. 2018 Feb 12. doi: 10.1111/bjd.16441. PMID: 29432644.29432644
4 Jansen MHE, Mosterd K, Arits A, . Five-Year Results of a Randomized Controlled Trial Comparing Effectiveness of Photodynamic Therapy, Topical Imiquimod, and Topical 5-Fluorouracil in Patients with Superficial Basal Cell Carcinoma. J Invest Dermatol. 2018 Mar;138(3):527–33. doi: 10.1016/j.jid.2017.09.033. PMID: 29045820.29045820