# Appendix H Adverse Events Reported

Arm type | Outcome Description | # studies reporting outcome
cryotherapy | Blistering | 3
cryotherapy | wound infection | 3
cryotherapy | Necrosis | 4
cryotherapy | Ulceration | 4
cryotherapy | inflammation/swelling | 5
cryotherapy | scarring | 5
cryotherapy | pain | 24
excision | bleeding | 5
excision | cataract and lachrymal duct stenosis | 1
excision | crusting | 10
excision | dyspigmentations and telangiectasia | 2
excision | Ectropion | 1
excision | edema/oedema | 5
excision | erosion | 6
excision | Erythema | 14
excision | headache | 1
excision | inflammation/swelling | 5
excision | itching | 10
excision | malaise | 1
excision | necrosis | 4
excision | pain | 25
excision | photosensitivity reaction | 1
excision | Radiodystrophy | 1
excision | scabbing | 1
excision | scaling | 4
excision | soreness | 1
excision | spots or pimples | 1
excision | skin infection | 1
excision | skin irritation | 9
excision | swelling | 1
excision | weeping | 1
excision | wound dehiscence | 2
excision | wound infection | 3
laser | dyspigmentation | 2
laser | hypopigmentation | 2
laser | Purpura | 2
laser | blistering | 3
laser | bullae | 3
laser | scarring | 5
laser | crusting | 10
laser | Erythema | 13
medical | Alanine aminotransferase elevation | 1
medical | alkaline phosphatase elevation | 2
medical | application site reaction | 5
medical | arthralgia | 1
medical | back pain | 1
medical | bleeding | 5
medical | Blink discomfort and dry eye | 1
medical | Burning | 9
medical | crusting | 10
medical | Desquamation | 1
medical | diarrhea | 2
medical | discharge | 1
medical | drainage | 1
medical | Ectropion | 1
medical | edema/oedema | 5
medical | erosion | 6
medical | Erythema | 14
medical | excoriation/flaking | 2
medical | fatigue | 2
medical | fever | 1
medical | headache | 4
medical | hypopigmentation | 2
medical | induration | 1
medical | inflammation/swelling | 5
medical | Intense conjunctival irritation | 1
medical | itching | 10
medical | lesions at remote site | 1
medical | leukopenia | 1
medical | loss of eyelashes | 1
medical | malaise/cold or flu like symptoms | 3
medical | nausea | 3
medical | necrosis | 4
medical | pain | 25
medical | Paresthesia | 1
medical | Pruritus | 2
medical | pustules | 1
medical | rash | 3
medical | redness | 2
medical | scabbing | 4
medical | Scaling | 4
medical | sensitivity | 1
medical | sinusitis | 1
medical | skin irritation | 9
medical | soreness | 1
medical | spots or pimples | 1
medical | swelling | 1
medical | Telangiectasia | 1
medical | tenderness | 2
medical | thrombocytopenia | 1
medical | Ulceration | 4
medical | upper respiritory tract infection | 1
medical | Vesicles | 3
medical | weeping | 2
medical | Wound dehiscence | 2
medical | Wounds | 1
PDT | oozing | 1
PDT | photosensitivity reaction | 1
PDT | skin infection | 1
PDT | squamae | 1
PDT | tingling | 1
PDT | warmth | 1
PDT | hypopigmentation | 1
PDT | hyperpigmentation | 3
PDT | Infection | 2
PDT | redness | 2
PDT | wound dehiscence | 2
PDT | Blistering | 3
PDT | bullae | 3
PDT | stinging | 3
PDT | vesicles | 3
PDT | wound infection | 3
PDT | bleeding | 4
PDT | scaling | 4
PDT | Ulceration | 4
PDT | necrosis | 4
PDT | edema/oedema | 5
PDT | erosion | 6
PDT | scarring | 6
PDT | inflamation/swelling | 5
PDT | burning | 9
PDT | skin irritation | 10
PDT | itching | 9
PDT | crusting | 10
PDT | Erythema | 13
PDT | pain | 25
radiotherapy | Blink discomfort and dry eye | 1
radiotherapy | cataract and lachrymal duct stenosis | 1
radiotherapy | Intense conjunctival irritation | 1
radiotherapy | loss of eyelashes | 1
radiotherapy | Radiodystrophy | 1
radiotherapy | slight pain in lower eyelid | 1
radiotherapy | dyspigmentations and telangiectasia | 2
radiotherapy | Ectropion | 2
radiotherapy | Necrosis | 4
radiotherapy | scarring | 5