# Appendix G Summary Results From Unadjusted NRCS

Table G-1 Summary results from unadjusted NRCS