# Appendix F Risk of Bias

Table F-1 Risk of bias in RCTs

Table F-2 NRCS