# Appendix E Arm Details

Table E-1 Arm details