# Appendix D Baselines

Table D-1 Baselines