# Appendix C Design Details

Table C-1 Design details