# Appendix B Excluded Studies

Table B-1 Excluded studies