# Appendix A Search Strategy

## PubMed (3/8/17)

((“Bowen’s Disease”[Mesh] OR bowen’s Or “basal cell carcinoma” or “basal cell carcinomas” or “Carcinoma, Basal Cell”[Mesh] or BCC Or “squamous cell carcinoma” or “squamous cell carcinomas” OR “Carcinoma, Squamous Cell”[Mesh] or SCC OR ((keratinocyte* or “Keratinocytes”[Mesh]) and (carcinoma* or “Carcinoma”[Mesh])) OR “non-melanoma” OR “non melanoma” OR “nonmelanoma”) NOT (Oropharynx OR Oropharyngeal neoplasms or “Oropharyngeal Neoplasms”[Mesh] OR Pharynx OR Pharyngeal neoplasms OR “Pharyngeal Neoplasms”[Mesh] or “Lung Neoplasms”[Mesh] or “Urinary Bladder Neoplasms”[Mesh] or “Uterine Cervical Neoplasms”[Mesh] or “Esophageal Neoplasms”[Mesh] or “Laryngeal Neoplasms”[Mesh]))

AND

(((Surger* or surgic*) and (excision or removal)) Or “shave removal” Or “external beam radiation” Or “external-beam radiation” Or brachytherap* or “Brachytherapy”[Mesh] Or chemotherap* OR Sensus OR X-ray OR “X-Ray Therapy”[Mesh] OR radiotherapy OR “Radiotherapy”[Mesh] Or (topical and (medications or chemotherap*)) Or observation Or “watchful waiting” Or ((Mohs or micrographic*) and surgery) Or “Mohs Surgery”[Mesh] Or Curett* or “Curettage”[Mesh] Or diathermy or “Diathermy”[Mesh] Or cauterization or “Cautery”[Mesh] Or Cryotherapy or “Cryotherapy”[Mesh] Or electrodesiccation Or ((CO2 or “carbon dioxide”) and laser and therapy) Or “Laser Therapy”[Mesh] Or plesiotherapy Or “Methyl 5-aminolevulinate” or “methyl 5-aminolevulinate” [Supplementary Concept] OR MALA Or “5-aminolevulinic acid” or “Aminolevulinic Acid”[Mesh] Or ALA Or Photodynamic or “Photochemotherapy”[Mesh] or Photochemotherap* Or 5-fluorouracil Or 5-FU Or Methotrexate Or “Methotrexate”[Mesh] Or Bleomycin or “Bleomycin”[Mesh] Or imiquimod or “imiquimod” [Supplementary Concept] Or BEC-5 Or diclofenac or “Diclofenac”[Mesh] Or interferon or IFN Or “Ingenol mebutate” or “3-ingenyl angelate” [Supplementary Concept] or PEP005 or PEP-005 or “PEP 005” Or Vismodegib Or Erivedge or “HhAntag691” [Supplementary Concept] or NSC747691 or NSC-747691 or “NSC 747691” or R-3616 or R3616 or “R 3616” or RG-3616 or RG3616 or “RG 3616” or GDC-0449 or GDC0449 or “GDC 0449” Or Sonidegib or Odomzo or “LDE225” [Supplementary Concept] or NVP-LDE225 Or Itraconazole or “Itraconazole”[Mesh] or Sporanox or Orungal or R51211 or R-51211 or “R 51211”)

AND

(“Cohort Studies”[Mesh] OR cohort OR “Clinical Trial” [Publication Type] OR “Clinical Trials as Topic”[Mesh] OR (follow-up or followup) OR longitudinal OR “Placebos”[Mesh] OR placebo* OR “Research Design”[Mesh] OR “Evaluation Studies” [Publication Type] OR “Evaluation Studies as Topic”[Mesh] OR “Comparative Study” [Publication Type] OR ((comparative OR Intervention) AND study) OR pretest* OR pre test* OR posttest* OR post test* OR prepost* OR pre post* OR “before and after” OR interrupted time* OR time serie* OR intervention* OR ((quasi-experiment* OR quasiexperiment* OR quasi experiment*) and (method or study or trial or design*)) OR “Case-Control Studies”[Mesh] OR (case and control) OR Clinical Studies OR “Clinical Studies as Topic”[Mesh] OR random allocation [mh] OR double-blind method[mh] OR single-blind method[mh] OR random* OR “Clinical Trial” [Publication Type] OR “Clinical Trials as Topic”[Mesh] OR “Placebos”[Mesh] OR placebo OR ((clinical OR controlled) and trial*) OR ((singl* or doubl* or trebl* or tripl*) and (blind* or mask*)) OR rct OR “Randomized Controlled Trial” [Publication Type] OR “Controlled Clinical Trial” [Publication Type] OR randomized)

NOT

(“addresses”[pt] or “autobiography”[pt] or “bibliography”[pt] or “biography”[pt] or “case reports”[pt] or “comment”[pt] or “congresses”[pt] or “dictionary”[pt] or “directory”[pt] or “editorial”[pt] or “festschrift”[pt] or “government publications”[pt] or “historical article”[pt] or “interview”[pt] or “lectures”[pt] or “legal cases”[pt] or “legislation”[pt] or “letter”[pt] or “news”[pt] or “newspaper article”[pt] or “patient education handout”[pt] or “periodical index”[pt] or “comment on” or “review”[pt] or “systematic”[sb] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] or cow[tw] or cows[tw] or chicken*[tw] or horse[tw] or horses[tw] or mice[tw] or mouse[tw] or bovine[tw] or sheep or ovine or murinae)

## Cochrane (3/8/17)

((bowen’s Or bowens OR basal cell carcinoma or BCC Or squamous cell carcinoma or SCC OR keratinocyte* and carcinoma* OR “non-melanoma” OR “non melanoma” OR “nonmelanoma”) NOT (Oropharynx OR Oropharyngeal neoplasms OR Pharynx OR Pharyngeal neoplasms))

AND

(((Surger* or surgic*) and (excision or removal)) Or “shave removal” Or “external beam radiation” Or “external-beam radiation” Or brachytherap* Or chemotherap* OR Sensus

OR X-ray OR radiotherapy Or (topical and (medications or chemotherap*)) Or observation Or “watchful waiting” Or ((Mohs or micrographic*) and surgery) Or Curett* Or diathermy or cauterization Or Cryotherapy Or electrodesiccation Or ((CO2 or “carbon dioxide”) and laser and therapy) Or plesiotherapy Or “Methyl 5-aminolevulinate” or “methyl 5-aminolevulinate” or MALA Or “5-aminolevulinic acid” or ALA Or Photodynamic or Photochemotherap* Or 5-fluorouracil Or 5-FU Or Methotrexate Or Bleomycin Or imiquimod Or BEC-5 Or diclofenac Or interferon or IFN Or “Ingenol mebutate” or “3-ingenyl angelate” or PEP005 or PEP-005 or “PEP 005” Or Vismodegib Or Erivedge or NSC747691 or NSC-747691 or “NSC 747691” or R-3616 or R3616 or “R 3616” or RG-3616 or RG3616 or “RG 3616” or GDC-0449 or GDC0449 or “GDC 0449” Or Sonidegib or Odomzo or NVP-LDE225 Or Itraconazole or Sporanox or Orungal or R51211 or R-51211 or “R 51211”)

## EMBASE (3/8/17)

(bowen* OR basal cell carcinoma or BCC Or squamous cell carcinoma or SCC OR keratinocyte* and carcinoma* OR non-melanoma OR non melanoma OR nonmelanoma) NOT (Oropharynx OR Oropharyngeal neoplasms OR Pharynx OR Pharyngeal neoplasms)

AND

(((Surger* or surgic*) and (excision or removal)) Or “shave removal” Or “external beam radiation” Or “external-beam radiation” Or brachytherap* Or chemotherap* OR Sensus OR X-ray OR radiotherapy Or (topical and (medications or chemotherap*)) Or observation Or “watchful waiting” Or ((Mohs or micrographic*) and surgery) Or Curett* Or diathermy or cauterization Or Cryotherapy Or electrodesiccation Or ((CO2 or “carbon dioxide”) and laser and therapy) Or plesiotherapy Or “Methyl 5-aminolevulinate” or “methyl 5-aminolevulinate” or MALA Or “5-aminolevulinic acid” or ALA Or Photodynamic or Photochemotherap* Or 5-fluorouracil Or 5-FU Or Methotrexate Or Bleomycin Or imiquimod Or BEC-5 Or diclofenac Or interferon or IFN Or “Ingenol mebutate” or “3-ingenyl angelate” or PEP005 or PEP-005 or “PEP 005” Or Vismodegib Or Erivedge or NSC747691 or NSC-747691 or “NSC 747691” or R-3616 or R3616 or “R 3616” or RG-3616 or RG3616 or “RG 3616” or GDC-0449 or GDC0449 or “GDC 0449” Or Sonidegib or Odomzo or NVP-LDE225 Or Itraconazole or Sporanox or Orungal or R51211 or R-51211 or “R 51211”)

AND

(Clinical trial/OR Randomized controlled trial/OR Randomization/OR Single blind procedure/OR Double blind procedure/OR Crossover procedure/OR Placebo/OR Randomi?ed controlled trial$.tw. OR Rct.tw. OR Random allocation.tw. OR Randomly allocated.tw. OR Allocated randomly.tw. OR (allocated adj2 random).tw. OR Single blind$.tw. OR Double blind$.tw. OR ((treble or triple) adj blind$).tw. OR Placebo$.tw. OR Prospective study/OR Clinical study/OR Case control study OR Family study/OR Longitudinal study/OR Retrospective study/OR Prospective study/OR Randomized controlled trials/OR Cohort analysis/OR (Cohort adj (study or studies)).mp. OR (Case control adj (study or studies)).tw. OR (follow up adj (study or studies)).tw. OR (observational adj (study or studies)).tw. OR (epidemiologic$ adj (study or studies)).tw. OR (cross sectional adj (study or studies)).tw.)

Limits: (human and english language and (adult <18 to 64 years> or aged <65+ years>))

## ClinicalTrials.gov (8/25/16) 376 records

(bowen’s disease OR basal cell carcinoma OR BCC OR squamous cell carcinoma OR SCC OR keratinocyte carcinoma OR “non-melanoma”)

AND (skin OR dermatology OR dermatological OR derma)

## ICTRP (8/25/16) 601 records

bowen’s disease OR basal cell carcinoma OR BCC OR squamous cell carcinoma AND skin OR SCC AND skin OR keratinocyte carcinoma OR non-melanoma AND skin