# Results

## Results of Literature Searches

For Key Question 1 on the benefits and harms of pharmacological interventions for schizophrenia, we reviewed 698 titles and abstracts and included one systematic review^29^ of 138 trials (N=47,189) and 24 additional trials^43–66^ (N=6,672) for second-generation antipsychotics (SGAs) versus other SGAs, and one systematic review of 111 trials^27,28^ (N=118,503) and five additional trials^57,67–70^ (N=1,055) for first-generation antipsychotics (FGAs) versus SGAs. There was significant overlap of studies between the two sections.

For Key Question 2 on the benefits and harms of psychosocial and other nonpharmacological interventions for schizophrenia, we reviewed 2,766 titles and abstracts and included 13 systematic reviews of 271 trials (N=25,050) and 27 additional trials (n=6,404) across 13 main intervention areas: assertive community treatment (1 systematic review^71^ and 1 trial^72^), cognitive adaptive training (CAT; 3 trials^73–76^), cognitive-behavioral therapy (CBT; 3 systematic reviews^77–79^ and 5 trials^76,80–83^), cognitive remediation/training (2 systematic reviews^84,85^ and 4 trials),^86–90^ family interventions (1 systematic review^91^ and 6 trials^92–97^), intensive case management (ICM; 1 systematic review^98^ and 1 trial^99^), illness self-management and recovery (1 systematic review^100^ and 1 trial^101^), psychoeducation (1 systematic review^102^), social skills training (3 trials^97,103–105^), supported employment (1 systematic review^106^ and 2 trials^107–109^) supportive therapy (1 systematic review^110^, early interventions for first episode psychosis (4 trials^111–119^), and co-occurring substance use disorders (SUDs) and schizophrenia (1 systematic review^120^). For each intervention area, we reported on the available evidence for prioritized, patient centered, outcomes, as described in the Methods. Prioritized outcomes for which there was no evidence available are not included in the Results. Direct comparisons were to usual care, which may include pharmacologic as well as other nonpharmacologic treatments.

The literature flow diagrams are shown in Figures 2 and 3. Tables 1–4 show the main characteristics of the included studies for the systematic reviews and trials for Key Questions 1 and 2 by intervention area. Detailed evidence tables of included studies are available in Appendix E, and details on quality assessment are available in Appendix F.

Figure 2 Key Question 1 literature flow diagram

FGA = first-generation antipsychotic; SGA = second-generation antipsychotic

* Other sources include prior reports, references lists, referrals from experts, and grey literature.

† Some studies were included for both FGA vs. SGA and SGA vs. SGA sections.

Figure 2 is a literature flow diagram depicting the search and selection of articles for Key Question 1. The diagram shows that 698 abstracts of potentially relevant articles were identified through literature database searches. 179 full text articles were reviewed after excluding 519 abstracts that did not meet inclusion criteria. From the full text articles reviewed, 141 were excluded for the following reasons: 6 population ineligible for review, 8 intervention not included in review, 14 comparator not included in review, 17 outcome not included in review, 9 had inadequate duration, 2 setting not included in this review (i.e. inpatient), 44 study design not included in review, 1 sample size too small, 4 not a study, 16 covered by a systematic review, and 20 were systematic reviews not included due to inclusion of a more recent, more comprehensive, or had a more similar scope to this review. The remaining publications were included for Key Question 1. For FGA vs. SGA 1 systematic review containing 113 studies (in 2 publications) and 5 additional trials (in 7 publications) were included. For SGA vs. SGA 1 systematic review containing 169 studies and 24 additional trials (in 38 publications) were included. Some studies were included in both FGA vs. SGA and SGA vs. SGA.

Figure 2 Key Question 2 literature flow diagram

* Other sources include prior reports, reference lists, referrals from experts, and grey literature.

Figure 3 is a literature flow diagram depicting the search and selection of articles for Key Question 2. The diagram shows that 2,766 abstracts of potentially relevant articles were identified through literature database searches. 895 full text articles were reviewed after excluding 1,871 abstracts that did not meet inclusion criteria. From the full text articles reviewed, 842 were excluded for the following reasons: 17 had a population ineligible for review, 153 had an intervention ineligible for review, 74 had a comparator not included in review, 96 had an outcome not included in review, 18 had an inadequate duration (<12 weeks), 26 had a setting not included in the review (i.e. inpatient only), 28 were in an ineligible country, 102 had a study design not included in review, 78 were not a study, 8 were not English language, 17 had a sample size too small (<50), 42 used an intervention evaluated in a single study, 10 were systematic reviews or meta-analysis used as a source document only to identify individual studies, 136 were studies covered by a systematic review, and 37 were systematic reviews excluded due to inclusion of a review that was more recent, more comprehensive, or had a more similar scope to this review. The remaining publications were included for Key Question 2, including 1 systematic review (containing 14 studies) and 1 trial for assertive community treatment, 3 trials in 4 publications for cognitive adaptive training, 3 systematic reviews (containing 89 studies) and 5 trials (in 6 publications) for cognitive behavioral therapy, 2 systematic reviews (containing 57 studies) and 4 trials (in 5 publications) for cognitive remediation/training, 4 trials (in 9 publications) for early interventions for first episode psychosis, 1 systematic review (containing 27 studies) and 6 trials (in 8 publications) for family interventions, 1 systematic review (containing 13 studies) and 1 trial for illness self-management, 1 systematic review (containing 10 studies) and 1 trial for intensive case management (ICM), 1 systematic review (containing 10 studies) for psychoeducation, 1 systematic review (containing 32 studies) for co-occurring substance use-disorders, 3 trials (in 4 publications) for social skills training, 1 systematic review (containing 14 studies) and 2 trials (in 3 publications) for supportive employment, and 1 systematic review (containing 5 studies) for supportive therapy.

Table 1 Characteristics of included systematic reviews for Key Question 1

Study Characteristic | FGA Versus SGA | SGA Versus SGA
Study quality (number of SRs) | Good (1) | Good (1)
Number of included studies | 113 (111 RCTs and 2 observational studies) | 169 (138 RCTs and 31 observational studies)
Sample size | 118,503 | 138 RCTs (N=47,189) 31 observational studies (N=602,547)
Duration of Intervention (range) | <1 day–22 years (median 8 weeks) | 6–104 weeks

FGA = first-generation antipsychotic; RCT = randomized controlled trial; SGA = second-generation antipsychotic; SR = systematic review

Table 2 Characteristics of new included trials for Key Question 1

Study Characteristic | Category | FGA Versus SGA | SGA Versus SGA
Study quality | Good | 2 | 2
Study quality | Fair | 2 | 17
Study quality | Poor | 1 | 5
Sample size | Total | 1,055 | 6,672
Duration of intervention/followup | Range | 12 weeks–3 years | 6 weeks–3 years
Location | U.S. only | 1 | 3
Location | Other | 4 | 21

FGA = first-generation antipsychotic; SGA = second-generation antipsychotic

Table 3 Characteristics of included systematic reviews for Key Question 2

Study Characteristic | ACT | CBT | Cognitive Remediation/Training | Co-occurring Substance Use Disorder | Family | ICM | Illness Self-Management | Psycho-education | Supported Employment | Supportive Therapy
Study quality (number of SRs) | Good (1) | Good (3) | Good (2) | Good (1) | Fair (1) | Good (1) | Fair (1) | Good (1) | Good (1) | Good (1)
Number of included studies | 14 | 89 | 57 | 32 | 27 | 10 | 13 | 10 | 14 | 5
Sample size | 2,281 | 7,154 | 2,885 | 3,165 | 2,297 | 1,652 | 1,404 | 1,125 | 2,265 | 822
Duration of intervention | Not reported | 8 weeks–5 years | 2 weeks–2 years | 1 month–3 years | 6 weeks–3 years | Not reported | 7–49 sessions, 45–90 minutes each | 1–18 months | 12 – 24 months | 7 months–1 year
Duration of followup | 1 month–2 years | 8 weeks–5 years | 2 weeks–2 years | 1 month–3 years | 6 weeks–8 years | 1 month–4 years | Up to 24 months post-treatment | 2 months–5 years | 2 years | 7 months–2 years

ACT = assertive community treatment; CBT = cognitive behavioral therapy; ICM = intensive case management; SR = systematic review

Table 4 Characteristics of included trials for Key Question 2

Study Characteristic | Category | Overall | ACT | CBT | Cognitive Remediation/Training | Early Interventions for First Episode | Family | ICM | Illness Self-Management | Social Skills Training | Supported Employment
Study quality and number of trials | Good | 4 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0
Study quality and number of trials | Fair | 20 | 1 | 4 | 3 | 2 | 3 | 1 | 1 | 3 | 2
Study quality and number of trials | Poor | 3 | 0 | 0 | 0 | 1 | 2 | 0 | 0 | 0 | 0
Sample size | Total | 6,404 | 118 | 823 | 341 | 2,363 | 562 | 77 | 210 | 433 | 1477
Duration of intervention | Range | 8 weeks–2 years | 1 year | 8 weeks–9 months | 12 weeks–6 months | 1–2 years | 6–12 months | 18 months | 8 months | 6 months–2 years | 2 years
Duration of followup | Range | 6 months–3 years | 2 years | 24 weeks–2 years | 6 months–1 year | 1–10 years | 1–2 years | 3 years | 8 months | 6 months–3 years | 2 years
Location | U.S. | 8 | 0 | 2 | 1 | 1 | 2 | 0 | 0 | 1 | 2
Location | Other | 18 | 1 | 3 | 3 | 3 | 4 | 1 | 1 | 2 | 0

ACT = assertive community treatment; CBT = cognitive-behavioral therapy; ICM = intensive case management

As described in the methods, for Key Question 2 we excluded unique psychosocial and nonpharmacological interventions, as well as interventions that are not commonly used in the United States (see Appendix C).

## Key Question 1a Comparative Benefits and Harms of Pharmacological Treatments for Adults With Schizophrenia

### Second-Generation Antipsychotic Versus Second-Generation Antipsychotic

#### Key Points

- The comparative evidence on SGAs came from one good-quality systematic review that included 138 head-to-head randomized controlled trials (RCTs) (N=47,189), 31 observational studies (N=602,547), and 24 newer RCTs (N=6,672). The studies were mostly fair quality.
- SGAs did not differ in effects on social, occupational, or global functioning.
  ○ No difference in social functioning was found between paliperidone palmitate monthly long-acting injection (LAI) and risperidone bi-weekly LAI (Personal and Social Performance [PSP] scale mean change from baseline 16.8 and 18.6, respectively; least squares mean [LSM] difference 0.5, 95% confidence interval [CI] −2.14 to 3.12) based on one RCT (N=452) (strength of evidence [SOE]: low).
  ○ A single study (N=666) found risperidone LAI to result in greater improvements in social function over 24 months compared with quetiapine (change at endpoint 6.6 vs. 1.1; p<0.0001) (SOE: low).
  ○ Although both groups improved significantly from baseline, risperidone LAI resulted in greater improvements than quetiapine on the Social and Occupational Functioning Assessment Scale (SOFAS) at 6 months (6.1 vs. 2.7, p=0.02) and 12 months (9.5 vs. 6.1; p=0.009) (SOE: low).
  ○ Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) Phase 1 found no significant differences in rates of employment between risperidone, olanzapine, quetiapine, perphenazine, and ziprasidone at 18 months (SOE: low)
  ○ Global functioning was not different (based on the Global Assessment of Functioning [GAF] scale) between olanzapine and either risperidone (four cohort studies; weighted mean difference [WMD] 0.61, 95% CI −1.78 to 2.99) or quetiapine (two RCTs; WMD 1.14, 95% CI −4.75 to 7.02) (SOE: low).
- Older SGAs (clozapine, risperidone oral and LAI, olanzapine, quetiapine, and ziprasidone) were not found different from one another on a variety of quality of life measures, although small but significant improvements were seen from baseline.
  ○ Olanzapine was not found significantly different than risperidone (two RCTs; moderate SOE), ziprasidone (two RCTs; moderate SOE), or quetiapine (one RCT; low SOE) at 12 months using the Heinrich Carpenter Quality of Life Scale (QLS) (change in scores ranged from 0.09 to 0.26).
  ○ Risperidone was not found significantly different from quetiapine or ziprasidone at 12 months using the QLS scale (one RCT each; range of change in scores 0.19 to 0.26) (SOE: low). Risperidone LAI was not found different from quetiapine on the 12-Item Short Form Health Survey (SF-12) or Schizophrenia Quality of Life Scale –Revision 4 (SQLS-R4) at 24 months (SOE: low).
- Response was significantly more likely with olanzapine (odds ratio [OR] 1.71. 95% CI 1.11 to 2.68) and risperidone (OR 1.41, 95% CI 1.01 to 2.00) than quetiapine, based on a network meta-analysis of 46 head-to-head RCTs (SOE: low)
  ○ The rate of response in individual study arms ranged from 20 to 80 percent.
  ○ Meta-regression examining the influence of study duration, dose-level, population (either treatment-resistant or first-episode status), and category of response definition did not result in any significant findings.
  ○ Due to few studies, the findings for newer SGAs (e.g., the 3-month paliperidone palmitate LAI, lurasidone, iloperidone, brexpiprazole, and cariprazine) should be interpreted with caution.
- All-cause mortality was not different between the SGAs in incidental reports in RCTs or retrospective cohort studies, but evidence was not available for the newest SGAs.
  ○ With mortality rates of 0 to 1.17 percent, significant differences in mortality were not found in two RCTs (4 to 24 months duration) of asenapine with olanzapine (relative risk [RR] 2.49, 95% CI 0.54 to 11.5), quetiapine and risperidone (RR 3.24, 95% CI 0.72 to 14.6), and two RCTS (also 4 to 24 months duration) of paliperidone palmitate monthly LAI versus risperidone LAI (RR 1.26, 95% CI 0.21 to 7.49) (SOE: low).
  ○ Retrospective cohort studies found no significant difference in the risk of all-cause (one study, N=48,595) or cardiovascular mortality (two studies, N=55,582) between risperidone, olanzapine, and quetiapine (SOE: low).
- Clozapine was found superior to olanzapine in preventing significant suicide attempts or hospitalization to prevent suicide (hazard ratio [HR] 0.76, 95% CI 0.58 to 0.97) and Clinical Global Impression of Severity-Suicidality Scale (CGI-SS) ratings of “much worse” or “very much worse” (HR 0.78, 95% CI 0.61 to 0.99); number needed to treat [NNT] of 12) among patients at high risk (SOE: low). Observational studies confirm these findings in broader populations.
- There were no significant differences between the SGAs in the proportions of patients reporting overall adverse events, based on 72 RCTs and 31 drug comparisons.
- Clozapine was found to improve core illness symptoms significantly more than the other SGAs, except for olanzapine (network meta-analysis of 212 RCTs; standard mean differences [SMDs] on Positive and Negative Syndrome Scale [PANSS] or Brief Psychiatric Rating Scale [BPRS]. All of the SGAs were superior to placebo (SMDs −0·33 to −0·88) (SOE: low).
- Olanzapine and risperidone were found to result in similar core illness symptom improvements, which were greater in these drugs than in the other SGAs, except for paliperidone (SMDs −0.13 to −0.26) (SOE: low). Paliperidone was found to improve core illness symptoms more than lurasidone and iloperidone (SMDs −0.17) (SOE: low).
- In a separate network analysis of 40 RCTs of clozapine, risperidone, olanzapine, quetiapine, and ziprasidone in patients who were resistant to treatment, the only significant difference was that the mean change in the PANSS was greater with olanzapine than quetiapine (SMD −0.29, 95% CI −0.56 to −0.13) (SOE: low).
- Based on a network meta-analysis of 90 head-to-head RCTs withdrawal due to adverse events were significantly lower with four SGAs compared with the others (SOE: low).
  ○ Risperidone LAI had significantly lower risk than clozapine (OR 0.27, 95% CI 0.10 to 0.71); lurasidone (OR 0.39, 95% CI 0.18 to 0.84); quetiapine extended release (ER) (OR 0.43, 95% CI 0.22 to 0.81); risperidone (OR 0.50, 95% CI 0.25 to 0.99); and ziprasidone (OR 0.40, 95% CI 0.20 to 0.82)
  ○ Olanzapine had lower risk than clozapine (OR 0.39, 95% CI 0.19 to 0.79); lurasidone (OR 0.57, 95% CI 0.34 to 0.94); quetiapine (OR 0.62, 95% CI 0.44 to 0.87); risperidone (OR 0.72, 95% CI 0.55 to 0.96); and ziprasidone (OR 0.58, 95% CI 0.41 to 0.82)
  ○ Aripiprazole had lower risk than ziprasidone (OR 0.64, 95% CI 0.44 to 0.94) and clozapine (OR 0.43, 95% CI 0.21 to 0.88)
  ○ Cariprazine (OR 0.40, 95% CI 0.17 to 0.95) and iloperidone (OR 0.34, 95% CI 0.13 to 0.91) had lower risk than clozapine
  ○ Meta-regression examining the influence of study duration, dose level, and either treatment-resistant or first-episode status did not result in any significant findings.
- There are fewer data available for the newer drugs; results for these drugs should be interpreted with caution.

#### Detailed Synthesis

##### Description of Included Studies

A recent large, good-quality systematic review compared the benefits and harms of SGAs, including oral and LAI drugs (Appendix Tables E-1 and F-1).^29^ The review included 138 RCTs of at least 6 weeks duration, including 47,189 patients with schizophrenia or related psychosis (includes 3 trials of adolescents with 315 patients). Of these, 17.5 percent were rated as poor quality, and 9 percent as good quality. Reasons for trials being rated as poor quality were unclear methods of randomization and/or allocation concealment, lack of blinding of outcome assessors and incomplete reporting of outcome data or high attrition (missing data). Patients enrolled in the included trials of adults not experiencing a first episode of schizophrenia had a mean age of 39 years, and in trials of adults with a first episode the mean age was 26 years. These trials made comparisons of the older SGAs (clozapine, risperidone, olanzapine, quetiapine, ziprasidone and aripiprazole) with few studies or only placebo-controlled trials of newer SGAs (iloperidone, lurasidone, paliperidone, and the LAI products). The duration of followup among the included studies ranged widely from 6 weeks to 3 years, with most being 8 to 12 weeks. The review also included 31 observational studies (cohort and case-control) with at least 6 months of followup to evaluate harms and selected effectiveness outcomes (e.g., functioning, employment). These studies included 602,547 patients, mostly diagnosed with schizophrenia or related psychosis. Twenty-one percent of these studies were rated poor quality, and 5 percent were good quality. Reasons for observational studies being rated as poor quality were potentially biased selection of patients, unclear description of methods for ascertaining exposure or outcomes, and lack of blinding of, or inadequate, control for confounding. Mean doses reported for the observational studies tended to be lower than those used in the trials noted above. Mean doses of olanzapine in particular were 10 to 12 mg daily in the observational studies, whereas across 54 trials reporting a mean olanzapine dose, the mean was 17 mg daily. For risperidone, the observational studies reported doses of 3 to 4 mg daily, whereas the mean across 55 trials was 5.7 mg daily.^29^ Evidence on dosing of other SGAs was limited. The reasons for this apparent difference in dosing between the observational studies and trials were not clear, primarily because data on patient characteristics were poorly reported in the observational studies. A number of these studies were poor quality for a variety of reasons, but primarily unclear population selection criteria and methods (potential for biased selection), lack of blinding outcome assessors, short durations of followup, small sample sizes, and little or no statistical analysis of potential confounding factors.^29^

Since the inclusion dates of the systematic review above, we have included 24 newer RCTs directly comparing SGAs^43–66^ (Appendix Tables E-2 and F-2). The comparisons in these newer trials included seven studies of a LAI drug; four of oral versus LAI of the same drugs (aripiprazole and risperidone, two studies each), and three comparing different LAI formulations or drugs (aripiprazole and paliperidone monthly injections, risperidone 2-week and paliperidone monthly, and paliperidone monthly and 3-month injections). Additionally, there were eight new trials comparing aripiprazole to other SGAs, including brexpiprazole, olanzapine, paliperidone, quetiapine, risperidone and ziprasidone; three new trials comparing either immediate or extended-release quetiapine to risperidone; one trial of olanzapine and ziprasidone, and two of cariprazine and risperidone. The duration of treatment in these studies was six to 52 weeks, median 28 weeks with six being 52 weeks long. Mean age of patients in these trials was 36 years. Five trials (21%) were deemed to be poor quality, based on unclear reporting on randomization and concealment of allocation procedures, lack of blinding of outcome assessors, some differences in prognostic factors at baseline, and high attrition combined with unclear handling of missing data.^44,53,58,60,64^ Two trials were good quality^56,61^ and the rest were fair quality.

In comparing SGAs with each other (and to one FGA), the CATIE trial, a large, federally funded effectiveness trial with three phases, is a major contribution to the evidence base, and deserves introduction.^121–125^ In Phase 1 patients were randomized to olanzapine, quetiapine, risperidone, ziprasidone, or perphenazine (however, patients with tardive dyskinesia at baseline were not randomized to perphenazine; this group=Phase 1A). Ziprasidone was added to the trial partway through enrollment, after it received FDA approval. As a result, the numbers of patients randomized to ziprasidone were fewer (183 vs. 329 to 333 in other SGA groups), limiting statistical power. The mean modal dose of each SGA was within the typical dosing range for each drug.^29^ The study was planned to enroll patients from a broad range of settings, excluding patients with treatment resistance. However, the large number of study sites at major academic centers drew criticism that the results may not be generalizable to other setting. The study was funded by the National Institute of Mental Health and is a good-quality study.

In Phase 1B those patients who were randomized to perphenazine in Phase 1 but discontinued the drug prior to 18 months were then randomized to one of the four SGAs. In Phase 2E patients who discontinued the originally assigned drug in Phase 1 due to inadequate efficacy were randomized to open-label clozapine or to a blinded trial of olanzapine, risperidone, or quetiapine. In Phase 2T patients who discontinued the originally assigned drug in Phase 1 due to poor tolerability were randomized to ziprasidone or one of olanzapine, risperidone, or quetiapine with no one receiving the same drug assigned in Phase 1 during Phase 2. It has been noted, however, that some patients who discontinued drug during Phase 1 due to lack of efficacy opted to be enrolled in Phase 2T. Fifty-eight percent (184 of 318) of those enrolling had discontinued treatment in Phase 1 due to lack of efficacy, most likely due to patients wanting to avoid randomization to clozapine. The authors noted “patients who were assigned to olanzapine during Phase 2 had the lowest rates of Phase 1 discontinuation because of intolerable side effects and the lowest rates of discontinuation due to weight gain or metabolic side effects.” In Phase 3, 270 patients who discontinued the Phase 2 drug (or discontinued Phase 1 drug and did not wish to be rerandomized to another treatment) were offered enrollment in an open-label treatment chosen by the patient, clinician, and research staff from among nine treatments: aripiprazole, clozapine, fluphenazine decanoate, olanzapine, perphenazine, quetiapine, risperidone, ziprasidone, or two of these combined.^125^ In addition to the results from the main analyses of each of these phases, numerous subgroup analyses and modeling studies have been published using data from this study.

The primary outcome measure in CATIE, all-cause treatment discontinuation, was selected for two reasons: first, because it was a discrete, common outcome that is easily understood; and second, because it encompassed lack of efficacy and/or intolerable side effects. Although this was an important outcome measure, it was an indirect measure of effectiveness and there appeared to be lack of agreement about its value to patients.^126–128^ Direct measures of effectiveness would include ability to work and to maintain successful social relationships. Hence, this outcome was not prioritized in the current review.

##### Findings

###### Function

###### Social Function

Across five RCTs (four included in the systematic review) and one observational study, assessments of social function resulted in mixed findings and insufficient evidence for the comparison of the older SGAs (clozapine, olanzapine, risperidone and quetiapine; Appendix Tables E-1 and E-2).^29,50^ Two fair-quality, open-label randomized trials with 12 months of followup came to different conclusions comparing olanzapine and risperidone, using different scales. In the first trial (N=108) no significant differences were seen between olanzapine and risperidone based on the Role Functioning Scale (RFS) or the Social Adjustment Scale (SAS) – Severely Mentally Ill version.^129^ In contrast, in the second trial (N=235), improvement on the Social Function Scale (SFS) was greater with olanzapine (+7.75) than risperidone (−0.92; p=0.0028) after controlling for baseline scores.^130^ These changes from baseline are very small, given the range of the scale (0 to 226). Data were not presented in a way that would allow pooling these findings, and the difference may be attributable to differences in patient characteristics. In the study finding a significant difference, patients had predominantly negative symptoms and SFS scores correlated with improvements in negative symptoms. In the study not finding a significant difference, patients had two or more psychiatric hospitalizations in the past 12 months and were known to be nonadherent to treatments. A large (N=10,972) prospective cohort study reported 84.6 percent of patients taking olanzapine to be socially active (self-report) at 6 months.^131^ This was significantly more than with risperidone (82.4%, OR 1.27, 95% CI 1.05 to 1.54) or quetiapine (78.9%, OR 1.67, 95% CI 1.29 to 2.16). Clozapine was not found significantly different from olanzapine (81.6%; OR 1.25, 95% CI 0.87 to 1.80). Evidence on comparisons of older SGAs on social functioning is insufficient to draw conclusions. Three short-term (8- and 10-week) trials found no differences in various social function scales (Social Skills Performance Assessment [SSPA], the Penn Emotional Acuity Test [PEAT], and the SFS) between risperidone and either quetiapine or clozapine.^132–134^

For newer SGAs, the review found that evidence from a pooled analysis of patient-level data from three, 6-week placebo-controlled trials of paliperidone and a small group assigned to olanzapine was insufficient to draw conclusions.^135^ Although the publication states that there were no significant differences on the PSP scale, statistical results were not reported and reporting of baseline characteristic of the olanzapine group were inadequately reported.

For the comparison of paliperidone palmitate monthly LAI and risperidone biweekly LAI, the review found low strength evidence that there is no difference in improvements in social functioning. This finding is based on a single fair-quality trial conducted in China (N=452) that found no difference at 13 weeks on the clinician rated PSP scale (mean change from baseline 16.8 with paliperidone and 18.6 with risperidone; LSM difference 0.5 [95% CI −2.14 to 3.12]).^136^ Since the review, another very small (N=30) fair-quality 6-month trial of paliperidone palmitate LAI and risperidone LAI, conducted in Japan, found paliperidone palmitate to result in a significant improvement if SFS scores compared with risperidone (14.60 vs. −1.64; p=0.038).^50,137^ The study also assessed functional capacity using the San Diego Performance Based Skills Assessment- Brief (UPSA-B) tool, but found no difference between groups on this measure. This study should be interpreted cautiously due to the very small sample size.

A secondary publication from a trial of risperidone LAI and quetiapine that was originally included in the systematic review reported on social function using the SOFAS scale.^138^ Although both groups improved significantly from baseline, risperidone LAI resulted in greater improvements in SOFA at 6 months (6.1 vs. 2.7; p=0.02), 12 months (9.5 vs. 6.1; p=0.009), and endpoint (6.6 vs. 1.1; p<0.0001). This evidence was low strength.

A single fair-quality trial of cariprazine and risperidone (N=456) that enrolled patients with stable schizophrenia and predominantly negative symptoms found no difference between the drugs on the SAS after 26 weeks of treatment.^56^

###### Employment and Residential Status

The systematic review included two RCTs and three observational studies that reported employment outcomes with the older SGAs (olanzapine, risperidone, quetiapine and ziprasidone) and found low strength evidence of no differences between the drugs (Appendix Table E-1).^29^ Results from Phase 1 of the CATIE study (N=1,121) did not indicate differences in employment at 18 months followup among olanzapine, quetiapine, risperidone, or ziprasidone.^139^ The threshold for “employment” was low—1 day in the last 30 days or an average of 1 hour a week over the last 30 days, with a mean of 18 percent reporting employment. The other smaller 12-month, open-label trial (N=235) only reported on the subscale occupation/employment item of the SFS, and found olanzapine to result in an improvement while risperidone resulted in a decrease in score (p=0.0024).^130^ Three observational studies did not show significant differences in employment outcomes between older SGAs.^140–142^

One fair-quality trial, comparing quetiapine with risperidone (N=771), assessed combined occupational and residential status using a “modified vocational status index” and a “modified location code index”.^55^ They defined “real functional improvement” as better status in both at 12 months than at baseline, and stable status if the status for both was unchanged from baseline. Using these definitions, they found that 3.8 and 3.1 percent, respectively, had real improved status, and that 75.5 and 75.3 percent had stable status, with no significant differences between groups. This evidence is insufficient to draw conclusions due to imprecision, unknown consistency, and study limitations.

###### Global Assessment of Functioning

The systematic review found that several studies have reported on the comparative effects of older SGAs using the GAF scale (score 0 to 100), but that very small differences (<4 points) were found favoring olanzapine compared with risperidone, quetiapine, and ziprasidone in three trials, otherwise differences were not found among drugs in nine studies (Appendix Table E-1).^29^ Such small differences are unlikely to have clinical importance as the minimal clinically important difference has been suggested to be 10 points.^143^

In the review, four observational studies reported on GAF scores in patients taking olanzapine and risperidone with followup of 6 months to 2 years. The pooled estimate of change from baseline in these studies was not significant (pooled WMD 0.61, 95% CI −1.78 to 2.99; I^2^=43%). The range in change of score from baseline was 6.0 to 18.34 with olanzapine and 6.0 to 16.13 with risperidone. In comparing olanzapine and quetiapine, the pooled estimate for difference in change in GAF score was not significant (2 RCTs, N=363; pooled WMD 1.14, 95% CI −4.75 to 7.02; Q=3.99, df=1; p=0.045). One of these studies found a small but significant difference, favoring olanzapine in patients with predominantly negative symptoms. This difference was correlated with improvements in negative symptoms (difference of 3.8 points; p=0.007).^144^ The evidence for indicating no difference in global function between olanzapine and risperidone or quetiapine was low strength. Evidence on comparisons of quetiapine and risperidone (one RCT), olanzapine and ziprasidone (one RCT), and clozapine and multiple other antipsychotics (one retrospective cohort study, one RCT) was insufficient to draw conclusions due to study limitations, unknown consistency and imprecision.

###### Quality of Life

Quality of life is a major consideration for choice of antipsychotic medication and is affected by both effectiveness and adverse events. There are multiple methods of measuring quality of life, many of which are intended for use in any population, such as the EuroQol five dimensions questionnaire (EQ-5D) or 36-Item Short Form Health Survey (SF-36), whereas a few are specifically designed for people with schizophrenia, such as the QLS. These methods measure different aspects of quality of life, and the data have been reported with too much variation to allow statistical pooling (e.g., not reporting standard deviations or standard errors, not reporting total scale scores, reporting endpoint only). The systematic review included five RCTs (N=3,443), including the CATIE trial, and five prospective cohort studies (N=5,728). Since then three additional trials of SGAs have reported quality of life.^49,54,55,138^ Using specific and nonspecific tools, 14 studies evaluated quality of life with seven oral and two injectable SGAs, with the majority finding no statistical or clinically meaningful differences (Appendix Tables E-1 and E-2).

Comparisons of olanzapine with risperidone and ziprasidone resulted in moderate-strength evidence of no significant difference in quality of life at 6 and 12 months. Low-strength evidence (due to smaller sample sizes) of no difference was found for comparisons of olanzapine with quetiapine, risperidone compared with quetiapine, and oral aripiprazole and aripiprazole monthly LAI. Evidence for the comparisons of olanzapine and asenapine, quetiapine ER and risperidone, and monthly LAIs of aripiprazole and paliperidone palmitate was insufficient to draw conclusions due to methodological limitations, unknown consistency (single trials), and imprecision in estimates (inadequate sample sizes). A secondary publication from a trial of risperidone LAI and quetiapine that was originally included in the systematic review reported on quality of life using the SF-12 physical and mental components and the SQLF-R4.^138^ Although both groups improved significantly from baseline, there was not a significant difference between groups at end point (24 months). This evidence was low strength.

The observational studies included in the systematic review support these findings for olanzapine, risperidone, and quetiapine with two exceptions. First, in the European Schizophrenia Outpatient Health Outcome (SOHO) study (N=919) whereas there were no differences in quality of life based on the EQ-5D at 6 or 36 months in the overall group, in the subgroup who were treatment-naïve at entry, patients taking olanzapine had significantly higher scores at 6 months than risperidone (adjusted mean difference 3.73, 95% CI −1.48 to 5.97).^145^ In another prospective cohort study (N=903; 612 with schizophrenia), olanzapine oral dissolving tablet (ODT) was found to have greater improvement on the Psychological General Well-being Index (scale scores 0 to 110) at 12 months than standard oral olanzapine (22.3 vs. 12.2, p<0.001).^146^ Because these are single observational studies, this evidence is insufficient to draw conclusions but may be useful in planning future RCTs.

###### Response and Remission

Response rates varied somewhat across trials due to differences in patient populations, timing of measurement, and definition of response (Appendix Tables E-1 and E-2). The most common definition of response was ≥20 percent improvement on the PANSS. Other definitions included the Kane criteria (improvement of ≥20% on BPRS and either Clinical Global Impression – Severity scale (CGI-S) ≤3 or BPRS ≤35);^147^ 30, 40, and 50 percent improvements in PANSS or BPRS; and ≤3 on all PANSS items and ≤3 on the CGI-S. Across the trials, significant differences in response rates were very rare, and generally were not confirmed in other trials, if available. Remission was rarely reported in these RCTs.

We conducted a network meta-analysis of response rates, controlling for duration of study, category of dose (low, mid-level, high), treatment status (first-episode and treatment-resistant) and definition of response (Figure 4). We grouped the response definition into three categories: >20 percent improvement on PANSS or BPRS scale, definition based on a scale with any threshold (20%, 30% 40%, etc.) and composite definitions and subjective definitions (e.g., Kane criteria plus one other element like hospitalization). Forty-six trials (40 two-arm studies and six three-arm studies; N=12,536),^43,46,47,51,55,59,130,132–135,148–182^ including 10 oral drugs (aripiprazole, asenapine, brexpiprazole, cariprazine, clozapine, olanzapine, paliperidone, quetiapine, risperidone, and ziprasidone) and aripiprazole monthly LAI were eligible for the analysis. Trials of the LAIs of paliperidone palmitate (monthly or 3-month formulations) and risperidone did not have a comparator drug in common with anything else in the network, and could not be included. Aripiprazole 4 to 6 week LAI, iloperidone, and lurasidone had no response data in head-to-head trials and could also not be included. The network analysis found only two significant differences between the drugs; both olanzapine (OR 1.71. 95% CI 1.11 to 2.68) and risperidone (OR 1.41, 95% CI 1.01 to 2.00) were significantly more likely to result in response than quetiapine. The rate of response in individual study arms ranged from 20 to 80 percent (data not shown, available upon request). The matrix of results for response can be found in Appendix G-1. Multiple methods were used to assess the model for inconsistency. Although the data available to test for inconsistency was limited, inconsistency in the model was not found. Taking this lack of inconsistency into account, and considering the indirectness of comparisons in the network, and the limited evidence for some comparisons, we found the results of the network meta-analysis to be low-strength evidence. Meta-regression examining the influence of study duration, dose-level, population (either treatment-resistant or first-episode status), and category of response definition did not result in any significant findings. There are fewer data available for the newer drugs; particularly all of the LAI drugs (e.g., the 3-month paliperidone palmitate injection), lurasidone, iloperidone, brexpiprazole, and cariprazine. Results for these drugs should be interpreted with caution.

Figure 3 Network meta-analysis of response rates in trials of SGAs

ER = extended-release; IR = immediate-release; LAI = long-acting injection; SGAs = second-generation antipsychotic

Legend: Circles represent relative numbers of studies including each drug. Line thickness represents number of studies making specific comparison for this outcome.

Figure 4 represents the network of comparisons comprising the meta-analysis of Key Question 1, response rates. The circles represent comparators (Asenapine, Aripriprazole monthly long-acting injection, Aripriprazole, Ziprasidone, Risperidone, Quetiapine immediate release, Paliperidone, Olanzapine, Clozapine, Cariprazine, and Brexipiprazole), with the size of the circle proportional to the number of trials using this comparator. The width of the lines connecting the comparators is proportional to the number of trials reporting those comparator pairs.

A fair-quality published network analysis of patients with treatment-resistant symptoms assessed response.^183^ Significant differences were not found in comparisons of clozapine, risperidone, olanzapine quetiapine, and ziprasidone.

###### Mortality

In April 2005, the United States Food and Drug Administration (FDA) issued a public health advisory regarding increased risk of all-cause mortality associated with the use of all SGAs in elderly patients with dementia-related psychosis (www.fda.gov/cder/drug/advisory/antipsychotics.htm). Evidence on the risk of death associated with the SGAs specifically in patients with schizophrenia is limited by the lack of RCTs with adequate duration, sample sizes, and broadness of eligibility criteria as well as the lack of specific methodology for identifying and categorizing cases. Evaluating the incidental reports of mortality in RCTs included in the systematic review indicates that over 4 months to 2 years of treatment the rate of all-cause deaths was 0 to 1.17 percent in trials of quetiapine compared with quetiapine ER (one RCT), quetiapine immediate-release or ER versus risperidone (three RCTs), asenapine versus olanzapine (two RCTs), paliperidone versus risperidone LAI (one RCT), paliperidone monthly LAI versus risperidone LAI (one RCT), paliperidone 3-month versus monthly LAIs (one RCT), and brexpiprazole versus aripiprazole (one RCT) (Appendix Tables E-1 and E-2).^43,55,136,154,175,184–188^ None of the comparisons were significant. For comparisons of asenapine with olanzapine (RR 2.49, 95% CI 0.54 to 11.5), quetiapine and risperidone (RR 3.24, 95% CI 0.72 to 14.6), and paliperidone palmitate monthly LAI versus risperidone LAI (RR 1.26, 95% CI 0.21 to 7.49), there was low-strength evidence of no difference in mortality over 4 to 24 months, but the evidence for the other comparisons is insufficient to draw conclusions.

The systematic review included three observational studies to address the risk of mortality with SGAs in patients with schizophrenia (Table 5). Only older SGAs were included in these studies. There was low-strength evidence of no significant difference in the risk of all-cause or cardiovascular mortality between risperidone and olanzapine or quetiapine (Appendix H). Evidence on the association of clozapine, risperidone, olanzapine and quetiapine and all-cause mortality versus no treatment is insufficient to draw conclusions due to the risk of bias of the study designs, and the lack of confirmatory studies (i.e., unknown consistency). Similarly, the evidence on cardiovascular mortality with risperidone compared with clozapine is insufficient. This study reported no differences in an analysis of older (starting drug at age 55 or older) versus younger patients, and found no association, however the mortality rates were very similar between drugs in the younger group (e.g., 2.7% and 2.8%) but the absolute difference was larger in the older group (e.g., 16.0% clozapine and 5.7% risperidone); the very small sample size in the older group may have prevented finding a significant difference.

Table 5 Mortality in retrospective cohort studies of SGAs

Study, Year | Study Population N, Mean Age (Quality) | Drugs and Comparison | All-Cause Mortality (95% CI) | Cardiovascular Mortality
Pasternak, 2014^189^ | Starting SGA N=48,595 39 years (Good) | Risperidone versus olanzapine, or quetiapine 1 year followup | Risperidone versus: Olanzapine HR 1.09, (0.79 – 1.49) Quetiapine HR 0.75, (0.53–1.07) | Risperidone versus: Olanzapine HR 0.99 (0.37 – 2.67) Quetiapine HR 0.76 (0.25 – 2.28)
Kiviniemi, 2013^190^ | First episode N=6,987 39 years (Good) | Clozapine, risperidone, olanzapine and quetiapine versus no treatment a 5 years followup | Clozapine OR 0.35 (0.21 – 0.58) Quetiapine OR 0.46 (0.30 – 0.72) Risperidone OR 1.0 (0.75 – 1.43) Olanzapine OR 0.73 (0.54 – 1.00) | Risperidone OR 0.82 (0.41–1.66) Clozapine OR 0.23 (0.05–.02) Olanzapine OR 0.89 (0.46–1.72) Quetiapine OR 0.72 (0.30–1.73)
Kelly, 2010^191^ | Starting SGA N=1686 40 years (Fair) | Clozapine versus risperidone 10 years followup | NR | 4.8% and 2.5%; RR 1.39 (0.61 to 2.53)

CI = confidence interval; HR = hazard ratio; OR = odds ratio; RR = risk ratio; SGA = second-generation antipsychotic

###### Reduction in Self-Harm

The best evidence on comparative effectiveness of SGAs in preventing suicide and suicide-related behaviors comes from the good-quality InterSePT trial^192^ of clozapine and olanzapine, that was included in the systematic review (Appendix Table E-1).^29^ This pragmatic, open-label RCT (N=980) of patients with schizophrenia or schizoaffective disorder who were at high risk of suicide behaviors was conducted in 11 countries and had the specific aim of assessing suicidal behaviors over 2 years. Clozapine was found superior to olanzapine in preventing significant suicide attempts or hospitalization to prevent suicide (HR 0.76, 95% CI 0.58 to 0.97) and CGI-SS ratings of “much worse” or “very much worse” (HR 0.78, 95% CI 0.61 to 0.99). Additional analyses that controlled for drug treatment, prior suicide attempts, active substance or alcohol misuse, country, sex, and age also found clozapine superior (HR 0.74, 95% CI 0.57 to 0.96), and indicated that the olanzapine group had significantly higher rates of using antidepressants, anxiolytics and rescue interventions to prevent suicide. The Kaplan-Meier life-table estimates indicated a significant reduction in the 2-year event rate in the clozapine group (p=0.02) with a NNT of 12. There was not a significant difference in suicide deaths (5 for clozapine and 3 for olanzapine). The strength of this evidence is moderate for serious attempts/hospitalizations and deaths, moderate for worsening of CGI-SS.

There were no other trials of SGAs that reported suicidal attempts, suicide deaths or other self-harm as a primary outcome measure, using explicit methods for ascertaining the outcome. Six fair-quality trials reported suicide-related outcomes as adverse events, all with very low event rates and no clear differences between treatments. Studies that did not prespecify or report methods were used for ascertaining and verifying the outcomes are open to misclassification and missing events. Patients were not selected for the trial based on risk for suicidal behavior, and there were no apparent differences between study groups in baseline severity of illness. A 52-week fair-quality efficacy trial of asenapine compared with olanzapine (N=1,225) reported 1.8 and 2.3 percent suicides attempts, respectively.^187^ A 13-week trial of risperidone LAI compared with paliperidone palmitate monthly LAI (N=452) reported that there were three suicidal behavior-related adverse events in the risperidone group (1.4%) and none in the paliperidone palmitate injection group (0%), with one suicide death in a patient with no prior history of suicidal behavior (0.5%).^136^ A 24-month trial of risperidone and quetiapine (N=1,098) initially designed to assess risk of ocular adverse events, reported two suicide deaths in the quetiapine group (0.34%) and one in the risperidone group (0.2%).^184^ Similarly, a 12-month trial of quetiapine ER and risperidone (N=798) reported a single death in the risperidone group (0.25%). ^55^ In a RCT of asenapine and olanzapine, conducted at sites around the world, results were reported according to the hemisphere of study site. In the Eastern hemisphere results, there was one suicide death in each group (0.41% and 0.42%),^154^ and none in the Western hemisphere analysis. This evidence is insufficient to draw conclusions due to lack of confirmatory studies, study limitations (i.e., ascertainment techniques), and small numbers of events (imprecision).

The systematic review also included four observational studies that used adequate ascertainment methods to assess the risk of suicide or suicide attempts in patients taking SGAs (not limited to those at high risk). Low-strength evidence from two retrospective cohort studies (combined N=16,584) found clozapine to be associated with lower risk of death by suicide. At 6 months, compared with no treatment, the risk with clozapine was OR 0.29, 95% CI 0.14 to 0.63. Risperidone, olanzapine, and quetiapine were not different from no treatment.^190^ In the other study, patients with schizophrenia newly starting on clozapine had a lower rate of suicide at 1 -year (1.1%) than the other drugs studied or than the 6 months prior to treatment (2.2%).^193^ Rates for the other drugs studied were risperidone 51 (2.1%), aripiprazole 13 (2.2%), risperidone LAI 26 (2.4%), quetiapine 49 (3.1%), olanzapine 57 (3.5%), and ziprasidone 17 (3.7%).

The other two studies, one assessing risk of suicide attempts in the fair-quality European SOHO prospective cohort study (N=10,204) of olanzapine, risperidone, quetiapine, and clozapine and the other assessing the risk of suicide attempts or death by suicide with aripiprazole compared with older SGAs provide only insufficient evidence due to methodological limitations of the study designs and lack of confirmatory studies for the specific outcomes and comparisons.

###### Improvement in Core Illness Symptoms

Three good-quality network meta-analyses compared several of the SGAs with each other on improvements in core illness symptoms.^183,194^ A network analysis published in 2013 included 212 head-to-head and placebo-controlled trials of 15 oral antipsychotics (both FGAs and SGAs).^194^ Cariprazine was not included, and the analysis includes drugs not available in the United States. This analysis pooled changes in the PANSS or BPRS, using SMDs. Clozapine was found significantly superior to all the other drugs in the network, except olanzapine, on this measure with SMDs ranging from −0.32 to −0.55 (small to medium differences). Olanzapine and risperidone were superior to the other drugs, except for each other and paliperidone, with effect sizes ranging from −0.13 to −0.26 (generally small differences). Using only indirect comparisons in the network, paliperidone was found superior to lurasidone and iloperidone, with SMDs of −0.17 (a small difference). All other comparisons were not significant, but all of the drugs in the network were found superior to placebo (SMDs −0.33 to −0.88). The network did not include injectable drugs, and it is possible that some of these findings would change, particularly for newer drugs, with new head-to-head studies. This evidence was low strength.

An analysis of six oral SGAs (clozapine, risperidone, olanzapine, quetiapine, and ziprasidone) in 40 RCTs of patients with treatment-resistant schizophrenia found that the mean change in the PANSS was greater with olanzapine than quetiapine (SMD −0.29, 95% CI −0.56 to −0.13).^183^ The authors noted that this corresponds to a difference in points on the PANSS of −6.08 (scale scores range from 30 to 210; 180 possible points). There is some evidence that in patients with more severe disease a minimal clinically important difference on the PANSS is 11.5 points, indicating that a difference of six points may not be clinically important, although statistically significant.^195^ The newer oral drugs (aripiprazole, iloperidone, lurasidone, asenapine, cariprazine, brexpiprazole) were not included. This was low-strength evidence.

A single fair-quality 6-week trial of brexpiprazole and aripiprazole (N=97) found that both drugs improved symptoms using the PANSS scale (−22.9 vs. −19.4 from baseline mean of 93.7; p<0.0001 for each drug vs. baseline).^43^ Comparisons across the drugs were not made, although the absolute difference was very small. This study was not included in published network meta-analyses, and alone this evidence is insufficient.

###### Overall Adverse Events

We identified 64 RCTs, making 34 comparisons of SGAs that reported the numbers of patients reporting an adverse event during the study by group.^45–47,49–51,54–56,61,123,125,133,136,148,150,151,154,155,161,163,167,169,171,172,174–178,184,186–188,196–227^ The majority of the trials did not find significant differences between the drugs compared. The rates of patients reporting adverse events varied widely across the studies, although the majority was above 60 percent for all SGAs, and the variability does not correlate with duration of study or mean or range of doses.

There was moderate-strength evidence of no significant difference in overall adverse event reporting between asenapine and olanzapine (five RCTs; N=2189)^154,176,187,223^, and quetiapine and risperidone (seven RCTs; N=3,254; Table 6).^123,133,169,171,172,184,186^

Table 6 Overall adverse events in trials of SGAs versus SGAs

SGA Comparison Number Studies/Number Patients | Percentage of Patients Reporting Adverse Events | Pooled Relative Risk
Asenapine vs. olanzapine 5 RCTs (4 publications); N=2189)^154,176,187,225^ | Asenapine 68% to 82% Olanzapine 69% to 82% | 1.00 (95% CI 0.96 to 1.05); I^2^ 9%
Quetiapine vs. risperidone 7 RCTs (N=3254)^123,133,169,171,172,184,186^ | Quetiapine 67% to 93% Risperidone 42% to 88% | 1.04 (95% CI 0.97 to 1.12); I^2^ 56%
Clozapine vs. olanzapine (N=182)^169,214^ | Clozapine 77% to 91% Olanzapine 73% to 77% | RR 1.15 (95% CI 1.00 to 1.33); I^2^ 0%
Risperidone vs. olanzapine 5 RCTs (N=873) ^123,149,163,169,171^ | Risperidone 42% to 71% Olanzapine 47% to 74% | RR 1.02 (95% CI 0.81 to 1.29); I^2^=77%
Olanzapine vs. ziprasidone 5 RCTs (N=1097; 6 weeks to 6 months durations)^161,167,178,197,226^ | Olanzapine 30% to 94% Ziprasidone 28% to 92% | RR 1.00 (95% CI 0.86 to 1.16); I^2^=80%
Olanzapine vs. quetiapine 3 RCTs (N=448)^123,169,171^ | Olanzapine 47% to 74% Quetiapine 60% to 68% | RR 0.90 (95% CI 0.74 to 1.11); I^2^=30%

CATIE = Clinical Antipsychotic Trials of Intervention Effectiveness; CI = confidence interval; RCT = randomized controlled trial; RR = risk ratio; SGA = second-generation antipsychotic

Similarly, the following comparisons had two to three RCTs each (6 weeks to 12 month; N=7810) that again found no significant differences in proportions of patients reporting adverse events: Quetiapine ER versus quetiapine and risperidone; risperidone versus clozapine and aripiprazole; olanzapine versus paliperidone; risperidone LAI versus paliperidone and paliperidone palmitate monthly LAI; and aripiprazole versus aripiprazole monthly LAI. This was low-strength evidence for these comparisons.

Single trials (3 weeks to 2 years; N=6700) of oral aripiprazole versus brexpiprazole, olanzapine, paliperidone, and risperidone LAI; ziprasidone versus clozapine, risperidone, iloperidone and lurasidone; risperidone versus asenapine, cariprazine and risperidone and risperidone LAI; clozapine versus quetiapine, quetiapine versus risperidone LAI; olanzapine versus olanzapine LAI and lurasidone; aripiprazole monthly LAI versus paliperidone; and paliperidone palmitate monthly LAI versus 3-monthly LAI found similar rates of overall adverse events with no significant differences. This evidence is insufficient to draw conclusions due to lack of confirmatory studies and imprecision for each comparison’s estimate of effect.

###### Withdrawals Due to Adverse Events

Adverse events that are intolerable lead to discontinuation from studies, although some may take longer to result in discontinuation. Such discontinuations take into account the patient’s evaluation of the degree to which the adverse event is tolerable. The CATIE trials included these discontinuations as a secondary outcome measure and found significant differences among the drugs. In CATIE Phase 1, discontinuations due to adverse events were highest among patients taking olanzapine (primarily due to weight gain or other metabolic effects, 18%) and lowest among those taking risperidone (10%; p=0.04 across groups). Time to discontinuation for adverse events did not differ among the groups. In Phases 1B, 2T, and 2E, differences were not seen between groups for rate of discontinuations or time to discontinuation due to adverse events (intolerability).

A network meta-analysis assessed discontinuation rates due to adverse events using data from 90 head-to-head trials of greater than 6-weeks duration (77 two arm studies, 8 three arm studies, 3 four arm studies and 2 five arm studies; N=29,678).^43,45–47,49–51,54–57,59,61,63,66,121–124,132–134,136,144,148,150–156,158,160,161,163–166,168–172,175–178,180,184,186–188,192,197,200,202,204–206,209,211,213,214,216,218–221,223,224,226–243^ (Figure 5). This analysis used direct and indirect comparisons based on the head-to-head trials and found that risperidone LAI had significantly lower risk of withdrawals due to adverse events than clozapine (OR 0.27, 95% CI 0.10 to 0.71); lurasidone (OR 0.39, 95% CI 0.18 to 0.84); quetiapine ER (OR 0.43, 95% CI 0.22 to 0.81); risperidone (OR 0.50, 95% CI 0.25 to 0.99); and ziprasidone (OR 0.40, 95% CI 0.20 to 0.82). Olanzapine had lower risk than clozapine (OR 0.39, 95% CI 0.19 to 0.79); lurasidone (OR 0.57, 95% CI 0.34 to 0.94); quetiapine (OR 0.62, 95% CI 0.44 to 0.87); risperidone (OR 0.72, 95% CI 0.55 to 0.96); and ziprasidone (OR 0.58, 95% CI 0.41 to 0.82). Aripiprazole had lower risk than clozapine (OR 0.43, 95% CI 0.21 to 0.88) and ziprasidone (OR 0.64, 95% CI 0.44 to 0.94). Cariprazine (OR 0.40, 95% CI 0.17 to 0.95) and iloperidone (OR 0.34, 95% CI 0.13 to 0.91) had lower risk than clozapine. The matrix of results for withdrawals can be found in Appendix G-2. Multiple methods were used to assess the model for inconsistency, and although the data available to test for inconsistency was limited, inconsistency was not found.

Figure 4 Network meta-analysis of withdrawals due to adverse events in trials of SGAs

ER = extended-release; IR = immediate-release; LAI = long-acting injection; SGAs = second-generation antipsychotic

Legend: Circles represent relative numbers of studies including each drug. Line thickness represents number of studies making specific comparison for this outcome.

Figure 5 represents the network of comparisons comprising the meta-analysis of Key Question 1, withdrawals due to adverse events. The circles represent comparators (Cariprazine, Brexipiprazole, Asenapine, Aripiprazole Monthly long-acting injection, Aripiprazole, Ziprasidone, Risperidone long-acting injection, Risperidone, Quetiapine immediate-release, Quetiapine extended-release, Paliperidone Monthly long-acting injection, Paliperidone, Paliperidone 3-month long-acting injection, Olanzapine long-acting injection, Olanzapine, Lurasidone, Iloperidone, and Clozapine), with the size of the circle proportional to the number of trials using this comparator. The width of the lines connecting the comparators is proportional to the number of trials reporting those comparator pairs.

Meta-regression examining the influence of study duration, dose-level, and either treatment-resistant or first-episode status did not result in any significant findings. There are fewer data available for the newer drugs; particularly all of the LAI drugs (e.g., the 3-month paliperidone palmitate injection), lurasidone, iloperidone, brexpiprazole, and cariprazine. Results for these drugs should be interpreted with caution.

###### Other Outcomes

There were several outcomes that were important to the evaluation of the evidence on SGAs, but that were lower priority and were not rated for their SOE. However, the Drug Effectiveness Review Project (DERP) systematic review^29^ included evidence synthesis on these outcomes, which is summarized below; complete details can be found in the review report.

###### Relapse

The systematic review found that the evidence on relapse suffers from methodological issues that could affect the findings, mainly lack of blinding, high dropout rates, and that no two studies used the same definition of relapse.^29^ Evidence on the comparison of olanzapine with risperidone and quetiapine was inconsistent, and conclusions of differences could not be drawn. Comparisons of risperidone and quetiapine to each other or to clozapine and lurasidone were based on very few studies but generally did not indicate significant differences. Single studies found risperidone LAI had lower relapse rates than oral risperidone (5% to 18% vs. 33% to 50% at 1 year; p<0.01) or quetiapine (16.5% vs. 31.3%; p<0.0001 at 1 year). No differences in relapse rates were found for comparisons of lurasidone and quetiapine ER or risperidone; aripiprazole LAI or risperidone LAI, or oral olanzapine and oral aripiprazole; or risperidone and quetiapine ER.

###### Drug Discontinuation and Time to Discontinuation

The rate of drug discontinuation and time to discontinuation were summary values representing the net effect of the two main causes of discontinuations: lack of efficacy and adverse events. Patients who withdraw from a study are also counted as having discontinued the study treatment drug. Based on a network analysis of 111 studies (95 two-arm studies, 11 three-arm studies, three four-arm studies, and two five-arm studies; N=32,096), there were several significant findings (the matrix of results for discontinuation can be found in Appendix G-3).^43,45–47,49–51,54–57,59,61,63,66,121–124,132–134,136,144,148,150–156,158,160,161,163–166,168–172,175–178,180,184,186–188,192,197,200,202,204–206,209,211,213,214,216,218–221,223,224,226–243^ Olanzapine and clozapine had significantly lower discontinuation rates than asenapine, cariprazine, iloperidone, lurasidone, olanzapine LAI, quetiapine, risperidone, and ziprasidone (ORs range from 0.42 for clozapine vs. iloperidone to 0.69 for clozapine vs. risperidone). Clozapine was found to also have lower risk than paliperidone palmitate monthly LAI (OR 0.56, 95% CI 0.33 to 0.96) and olanzapine had lower risk than paliperidone (OR 0.67, 95% CI 0.50 to 0.89). Quetiapine ER had lower risk of discontinuing study than iloperidone, olanzapine LAI, or quetiapine (ORs 0.26 to 0.35), and both risperidone and aripiprazole had lower risk than iloperidone or quetiapine (ORs 0.61 to 0.77). Both risperidone and aripiprazole monthly LAI had lower risk than iloperidone (ORs 0.52 and 0.62, respectively). Few studies of newer drugs exist, suggesting that these findings should be interpreted cautiously. Meta-regression examining the influence of study duration, dose level, and either treatment-resistant or first-episode status did not result in any significant findings.

Olanzapine was found to have longer time to discontinuation than quetiapine, risperidone, and ziprasidone (4 months longer based on trial data; 46 to 66 days longer based on observational data). Based on a single small trial, Phase 2E of the CATIE study, clozapine may have longer time to discontinuation (10.5 months) than olanzapine (2.7 months), risperidone (2.8 months) or quetiapine (3.3 months). Evidence did not differentiate aripiprazole, olanzapine, risperidone and quetiapine or ziprasidone and olanzapine or risperidone. A single fair-quality retrospective study found risperidone LAI to have significantly longer duration of treatment than aripiprazole, clozapine, olanzapine, quetiapine, or ziprasidone (79 to 120 days longer). These findings need confirmation.

###### Cardiac and Cardiovascular Risk

The DERP systematic review^29^ included evidence synthesis on these outcomes, although the evidence on cardiovascular risks is limited largely to observational studies of the older SGAs.

Coronary heart disease. A large, good-quality retrospective cohort study found no significant differences in the risk of cardiovascular death, acute coronary syndrome or ischemic stroke between risperidone and olanzapine or quetiapine in patients age 18 to 64 years within the first year of starting the drug. Based on data from CATIE, the estimated 10-year risk of coronary heart disease was increased with olanzapine compared with risperidone, and the highest risk increases occurred among those with higher baseline risk.

Myocarditis and cardiomyopathy. A large adverse event database study found that clozapine was significantly associated with myocarditis or cardiomyopathy, whereas olanzapine, quetiapine, and risperidone were not. Limited evidence suggested an increased risk of cardiac arrest and arrhythmia with risperidone compared with clozapine. Comparisons of second-generation to conventional antipsychotics showed lower odds of cardiomyopathy or coronary heart disease with aripiprazole, and increased odds of hypertension with ziprasidone.

Diabetes mellitus and ketoacidosis. The systematic review reported that evidence on diabetes mellitus and ketoacidosis was limited, and the studies did not control for several important potentially confounding factors such as weight or family history of diabetes.^29^ The absolute increase in risk was not clear based on this evidence. In children and adolescents, the risk of diabetes increased with antipsychotic exposure based on one good-quality systematic review of observational studies when compared with healthy controls (OR 2.58, 95% CI 1.56 to 4.24) or nonexposed psychiatric controls (OR 2.09, 95% CI 1.50 to 52.90). In children and adolescents, treatment with aripiprazole was associated with increased risk of diabetes when compared with risperidone based on one large observational study (OR 1.58, 95% CI 1.21 to 2.07). In adults, observational evidence indicated an increased risk of new-onset diabetes with olanzapine compared with risperidone (OR 1.16, 95% CI 1.03 to 1.31). Limited evidence did not consistently support a significant difference between clozapine and risperidone or between quetiapine and olanzapine, risperidone, or clozapine.

Diabetic ketoacidosis was significantly increased with olanzapine compared with risperidone (OR 3.5, 95% CI 1.7 to 7.9) in a single study; a second study found no difference in a composite outcome of diabetic ketoacidosis, hyperglycemia, or hyperglycemic hyperosmolar state between risperidone and olanzapine, regardless of age group, but a significantly lower risk with quetiapine compared with risperidone in older patients (adjusted HR 0.69, 95% CI 0.53 to 0.90).

Tardive dyskinesia. Comparative observational evidence suggested a significantly increased risk of new-onset tardive dyskinesia with risperidone compared with olanzapine (OR 1.70, 95% CI 1.35 to 2.14). Similar increases were not seen with clozapine or quetiapine. Rates of new-onset tardive dyskinesia were low overall: 3 percent with risperidone and 1 to 2 percent for others.

###### Extrapyramidal Symptoms

The systematic review reported that the best evidence suggested that the rates of patients experiencing extrapyramidal side effects (prevalent or incident), measures of severity of symptoms were mostly not different among the drugs, although use of anticholinergic medications did differ in some comparisons.^29^ Differences found, mainly in single studies, are summarized in Table 7.

Table 7 Extrapyramidal symptoms: significant differences in trials of SGAs

Primary SGA Comparison | Findings
Risperidone | Quetiapine and ziprasidone had lower use of anticholinergic medications to treat EPS and lower rates of withdrawal due to EPS than risperidone.
Risperidone | EPS adverse events were more frequent with risperidone LAI than with oral olanzapine or quetiapine
Risperidone | A single fair-quality trial suggested that aripiprazole may cause worse akathisia in early weeks of treatment but not with longer treatment.
Risperidone | Differences were not found between risperidone and cariprazine over 6 weeks on EPS outcomes in a fair-quality trial.
Ziprasidone | Ziprasidone was associated with lower risk of withdrawal due to EPS adverse events than quetiapine, but quetiapine had lower use of anticholinergic medications to treat EPS.
Ziprasidone | EPS adverse events were significantly more frequent with ziprasidone (9%) than with iloperidone (3%) in a fair-quality 3-week trial.
Olanzapine | Based on the CATIE trial, quetiapine had lower risk of patients using anticholinergic medications than olanzapine.
Olanzapine | Evidence suggested that paliperidone and asenapine cause more EPS adverse events and worse severity of symptoms than olanzapine, and that asenapine results in more patients using an anticholinergic medication (6% vs. 2%).
Long-Acting Injections | Aripiprazole monthly LAI resulted in greater incidence of EPS adverse events (RR 1.88, 95% CI 1.26 to 2.81) and worse akathisia symptoms (+0.06 vs. −0.05 on a 0 to 5 scale; p=0.0184) than oral aripiprazole in a short-term study, but differences were not found in a year-long study.
Long-Acting Injections | Differences in EPS adverse events were not found in a 28-week trial of aripiprazole and paliperidone palmitate monthly injections, or in a network meta-analysis comparing the monthly and 4- to 6-week injections of aripiprazole.

CATIE = Clinical Antipsychotic Trials of Intervention Effectiveness; CI = confidence interval; EPS = extrapyramidal symptoms; IR = immediate-release; LAI = long-acting injection; RR = risk ratio; SGA = second-generation antipsychotic

Source: McDonagh, 2013^29^

###### Weight Gain

The systematic review reported that the rate of clinically important weight gain (defined as a 7% or more increase from baseline) in clinical trials was greater with olanzapine than with aripiprazole (RR 2.31), asenapine (RR 2.59), clozapine (RR 1.71), quetiapine (RR 1.82), risperidone (RR 1.81), and particularly ziprasidone (RR 5.76) across 3.7 to 24 months.^29^ The analysis of risk of important weight gain for olanzapine compared with risperidone appeared to vary by duration of study, whereas the others did not. The RR of 1.81 represents studies of 6 to 7 months duration, whereas the CATIE Phase 1 results indicated much higher risk (RR 7.49, 95% CI 4.25 to 13.33) at 18 months.

The review reports that single studies of olanzapine compared with olanzapine ER, olanzapine ODT, and paliperidone palmitate injection did not find significant differences in risk of weight gain.^29^ Data for other SGAs compared with olanzapine were insufficient. Observational evidence generally agreed with trial evidence, but resulted in somewhat lower estimates of increased risk with olanzapine. Risperidone was found to have greater risk of weight gain (in single studies) compared with aripiprazole (12% vs. 3%; p=0.018), or cariprazine (calculated RR 1.98, 95% CI 1.03 to 3.80 for any dose cariprazine vs. risperidone). There was not a significant difference in the proportion of patients with weight gain between paliperidone and aripiprazole at 6 months in a single study. An open-label RCT of medication-naïve patients with first-episode schizophrenia (not included in the review) found aripiprazole to result in greater absolute weight gain and more patients with ≥7 percent gain than with ziprasidone or quetiapine.^244^

###### Metabolic Syndrome

The systematic review found that olanzapine had a significantly greater risk of metabolic syndrome than risperidone with followup of 6 weeks to 3 months (pooled OR 1.60, 95% CI 1.10 to 2.21, I^2^=0%).^29^ Olanzapine also had significantly greater risk of metabolic syndrome than aripiprazole (Evidence-based Practice Center [EPC] pooled OR 2.50, 95% CI 1.32 to 4.76; I^2^=0%) with followup of 3.5 to 12 months. Evidence for other comparisons was too limited to draw conclusions.

###### Sexual Function

Evidence on the comparative effect of SGAs on sexual function reported in the systematic review^29^ was inconsistent or limited by single-study bodies of evidence, inadequate sample sizes or lack of explicit methodology to measure symptoms. Based on four very small trials, evidence on risperidone compared with quetiapine was inconclusive. A single study comparing risperidone and quetiapine ER (N=798) found significantly more men had sexual adverse effects at 6 months (13% vs. 6%; p<0.05), but the difference was not significant at 12 months. Individual trials found no significant differences between olanzapine and paliperidone, risperidone, or ziprasidone or between risperidone and paliperidone or aripiprazole.

###### Agranulocytosis (Severe Neutropenia)

Although the incidence of agranulocytosis and neutropenia are known serious adverse events with clozapine that require regular monitoring, evidence on the risk with other SGAs is very limited and does not indicate a serious concern with the other drugs currently available.^29^

### First-Generation Antipsychotic Versus Second-Generation Antipsychotic

#### Key Points

- Evidence comparing FGA versus SGA is available from a good-quality systematic review (111 RCTs and two cohort studies; N=118,503) and five RCTs (N=1,055) not included in the systematic review.
- There was little evidence of a differential effect between FGAs and SGAs in quality of life outcomes using various measures based on a good-quality systematic review, with one trial comparing haloperidol with ziprasidone finding a positive effect favoring ziprasidone (effect estimate −12.12, 95% CI −22.06 to −2.17) and no difference between groups reported in another trial (SOE: low)
  ○ There were no differences between haloperidol and olanzapine (SOE: moderate), or perphenazine and olanzapine, quetiapine, risperidone, or ziprasidone (SOE: low).
- For response and remission, olanzapine was found superior to haloperidol.
  ○ Pooled results from 14 RCTs comparing haloperidol with olanzapine found a significant effect on response rate favoring olanzapine (N=4,099; RR 0.86, 95% CI 0.78 to 0.96) (SOE: low). Three trials comparing haloperidol with olanzapine found a significant difference in remission rates favoring olanzapine (RR 0.64, 95% CI 0.45 to 0.94) (SOE: low).
  ○ There was no difference in response rates between haloperidol and aripiprazole (five RCTs, N=2,185; RR 1.01; 95% CI 0.76 to 1.34), quetiapine (six RCTs, N=1,421; RR 0.99, 95% CI 0.76 to 1.30), risperidone (16 RCTs, N=3,452; RR 0.94, 95% CI 0.87 to 1.02), and ziprasidone (six RCTs, N=1,283; RR 0.98, 95% CI 0.74 to 1.30) (SOE: moderate for haloperidol versus risperidone; low for other comparisons).
  ○ There was no difference in remission rates between haloperidol and ziprasidone based on three trials (RR 0.89, 95% CI 0.71 to 1.12) (SOE: low).
- Reductions in core illness symptoms were greater with older SGAs than with haloperidol
  ○ There were significant difference in total PANSS between haloperidol and olanzapine (15 RCTs, N=4,209; mean difference [MD] 2.31, 95% CI 0.44 to 4.18) and risperidone (21 RCTs, N=4,020; MD 3.24, 95% CI 1.62 to 4.86), both favoring the SGA over haloperidol (SOE: moderate).
  ○ There were no differences in total PANSS, BPRS, CGI-S, and Clinical Global Impression - Improvement scale (CGI-I) scores for other FGA versus SGA comparisons (SOE: low).
- SGAs improved negative symptoms more than haloperidol
  ○ Olanzapine was more effective than haloperidol at improving negative symptoms based on Scale for Assessment of Negative Symptoms (SANS) scores (five RCTs, N=535; MD 2.56, 95% CI 0.94 to 4.18) (SOE: moderate).
  ○ Using the negative symptoms subscale of the PANSS scale, MDs (although small) between haloperidol and aripiprazole (three RCTs, N=1,701; MD 0.80, 95% CI 0.14 to 1.46), olanzapine (14 RCTs, N=3,742; MD 1.06, 95% CI 0.46 to 1.67), and risperidone (22 RCTs, N=4,142; MD 0.80, 95% CI 0.14 to 1.46) all favored the SGA (SOE: low).
  ○ There were no differences in negative PANSS or SANS scores for other FGA versus SGA comparisons (SOE: low).
- Overall adverse event rates were lower with SGAs when comparing haloperidol with aripiprazole (three RCTs, N=1,713; RR 1.11; 95 % CI 1.06 to 1.17), risperidone (eight RCTs, N=1,313; RR 1.20, 95% CI 1.01 to 1.42), and ziprasidone (six RCTs, N=1,448, RR 1.13, 95% CI 1.03 to 1.23) (SOE: moderate).
- Withdrawals due to adverse events were significantly higher with haloperidol than with SGAs: compared with aripiprazole (eight RCTs, N=3,232; RR 1.25, 95% CI 1.07 to 1.47), olanzapine (24 RCTs, N=5,708; RR 1.89; 95% CI 1.57 to 2.27), risperidone (25 RCTs, N=4,581; RR 1.32; 95% CI 1.09 to 1.60), and ziprasidone (seven RCTs, N=1,597; RR 1.68, 95% CI 1.26 to 2.23) (SOE: moderate).

#### Detailed Synthesis

##### Description of Included Studies

A recent large, good-quality systematic review compared the benefits and harms of FGAs versus SGAs (Appendix Table E-1).^27,28^ The review included 111 RCTs and 2 cohort studies conducted in people with schizophrenia or related psychosis (n=118,503). Patients enrolled in the included studies had a mean age of 37 years; half of the included studies were conducted in inpatient populations. The included studies compared: oral fluphenazine with olanzapine (two RCTs), quetiapine (one RCT) and risperidone (one RCT); haloperidol with aripiprazole (eight RCTs), asenapine (one RCT), clozapine (10 RCTs, one cohort study), olanzapine (34 RCTs, one cohort study), paliperidone (one RCT), quetiapine (10 RCTs, one cohort study), risperidone (37 RCTs, one nonrandomized trial, one cohort study) and ziprasidone (eight RCTs, one nonrandomized trial); and perphenazine with aripiprazole (one RCT), olanzapine (two RCTs), quetiapine (one RCT), risperidone (two RCTs) and ziprasidone (one RCT). No studies compared a FGA with brexpiprazole, cariprazine, iloperidone, or lurasidone. Doses of FGAs and SGAs varied widely among the studies included in the systematic review. For FGAs, doses of fluphenazine ranged from 6 to 21 milligrams per day (mg/day), haloperidol ranged from 1 to 30 mg/day and perphenazine ranged from 8 to 64 mg/day. SGA doses ranged from 1 to 45 mg/day for aripiprazole, 5 to 10 mg/day for asenapine, 200 to 800 mg/day for clozapine, 1 to 40 mg/day for olanzapine, 200 to 1200 mg/day for quetiapine1 to 6 mg/day for risperidone and 4 to 240 mg/day for ziprasidone. The duration of followup among the included studies ranged widely from less than 1 day to 22 years, although median followup was eight weeks. None of the included studies were rated as having low risk of bias. Reasons for unclear or high risk of bias among the studies were unclear methods of randomization and/or allocation concealment, unclear or lack of blinding of outcome assessors and incomplete reporting of outcome data (Appendix Table F-1).

We also included five additional trials not in the systematic review comparing FGAs with SGAs (N=1,055; Appendix Table E-2).^57,67–70^ These trials enrolled between 78 and 300 participants, mean age ranged from 26 to 45 years and the proportion of female participants ranged from 25 to 42 percent. Race was reported in one trial, enrolling predominantly black patients (57%); this was also the only trial conducted in the United States.^70^ Two trials limited enrollment to participants with first-episode psychosis.^67,69^ The FGA used in all of the trials was haloperidol, compared with olanzapine (three RCTs), quetiapine (two RCTs), aripiprazole, risperidone and ziprasidone (one RCT each). Two trials were rated good quality,^68,70^ one was rated poor quality,^69^ and the others were rated fair quality (Appendix Table F-2). The primary limitation in the fair-quality trials was lack of blinding of clinicians and patients.

##### Findings

###### Function

Outcomes related to function were rarely reported in the systematic review, with no significant differences between FGAs and SGAs for any measure of function (Appendix Table E-1).^28^ No significant differences were found in global function, based on GAF score, between haloperidol and olanzapine (one RCT, N=208; effect estimate −4.00; 95% CI −13.70 to 5.70), quetiapine (one RCT, N=207; effect estimate 0.20, 95% CI −9.60 to 9.80), or ziprasidone (two RCTs, one non-RCT, N=1,085; effect estimate 0.30, 95% CI −1.58 to 2.19; I^2^=0%), or in encounters with the legal system (one RCT, N=31; RR 3.20, 95% CI 0.76 to 13.46). There were also no differences in proportion of patients with paid employment for comparisons of perphenazine versus olanzapine (N=597; RR 1.29; 95% CI 0.70 to 2.38), quetiapine (N=598; RR 1.75; 95% CI 0.90 to 3.43), risperidone (N=602; RR 1.38; 95% CI 0.74 to 2.57) and ziprasidone (N=446; RR 1.22; 95% CI 0.60 to 2.51) based on one trial each. The number of patients with economic independence was also not different in one trial of haloperidol versus risperidone (N=100; RR 0.94; 95% CI 0.68 to 1.29). This SOE was insufficient due to limited evidence for each comparison.

###### Quality of Life

The systematic review found little evidence of a differential effect between FGAs and SGAs in quality of life outcomes (Appendix Table E-1).^28^ One trial comparing haloperidol with ziprasidone found a positive effect on QLS score favoring ziprasidone (N=599; effect estimate −12.12, 95% CI −22.06 to −2.17). There was no difference between haloperidol and ziprasidone in one other trial based on the Manchester Short Assessment of Quality of Life (MANSA) score (N=185; effect estimate −0.10, 95% CI −1.48 to 1.28). This was low SOE. There was no difference in quality of life outcomes in trials comparing haloperidol with olanzapine (five RCTs, N=816; effect sizes ranged from −3.62 to 0). This SOE was moderate. There was also no difference for haloperidol versus quetiapine (one RCT, N=207; effect estimate 0.00, 95% CI −1.38 to 1.38) and risperidone (two RCTs, N=352; effect estimates ranged from −0.10 to 0.10) using various quality of life measures; this evidence was of insufficient strength. Based on one trial each, no significant differences in quality of life measures were found when comparing perphenazine with aripiprazole (N=300; RR 4.74, 95% CI 2.58 to 8.69), olanzapine (N=597; effect estimate 0.00; 95 % CI −0.16 to 0.16), quetiapine (N=598; effect estimate 0.10, 95 % CI −0.07 to 0.27), risperidone (N=602; effect estimate −0.07, 95% CI −0.24 to 0.10), or ziprasidone (N=446; effect estimate −0.07, 95 % CI −0.27 to 0.13). Due to limited evidence and the heterogeneity of measures used to assess quality of life, this SOE was low to insufficient (for perphenazine versus aripiprazole).

###### Response and Remission

###### Response

Evidence on response rate was mixed in the systematic review and heterogeneity was moderate to high for most risk estimates (Appendix Table E-1).^28^ Pooled results from 14 RCTs comparing haloperidol with olanzapine found a significant effect favoring olanzapine (N=4,099; RR 0.86, 95% CI 0.78 to 0.96; I^2^=55%). However, the review found no difference in response rates between haloperidol and aripiprazole (five RCTs, N=2,185; RR 1.01, 95% CI 0.76 to 1.34; I^2^=83%), quetiapine (six RCTs, N=1,421; RR 0.99; 95% CI 0.76 to 1.30; I^2^=77%), risperidone (16 RCTs, N=3,452; RR 0.94, 95% CI 0.87 to 1.02; I^2^=29%) and ziprasidone (six RCTs, N=1,283; RR 0.98, 95% CI 0.74 to 1.30; I^2^=80%). This was low to moderate (for haloperidol versus risperidone) SOE. There was no difference between groups for other comparisons, including fluphenazine versus olanzapine, quetiapine and risperidone and for perphenazine versus aripiprazole based on one trial each. This evidence was insufficient for all comparisons.

###### Remission

Pooled evidence from three trials comparing haloperidol with olanzapine found a significant difference in remission rates favoring olanzapine (RR 0.64; 95% CI 0.45 to 0.94) with moderate heterogeneity (I^2^=54%).^28^ Evidence from a trial not included in the systematic review was consistent, though not significant, finding a greater number of patients taking olanzapine experienced remission compared with the haloperidol group 33% versus 25%; p=0.5).^67^ This was low SOE. There were no differences between haloperidol and clozapine (one RCT, N=71; RR 0.16, 95 % CI 0.02 to 1.20), quetiapine (one RCT, N=207; RR 0.72, 95% CI 0.41 to 1.25), risperidone (two RCTs, N=179; RR 0.84, 95% CI 0.56 to 1.24; I^2^=0%), or ziprasidone (three RCTs, N=1,085; RR 0.89, 95% CI 0.71 to 1.12; I^2^=12%). This was low (for ziprasidone) and insufficient (for clozapine, quetiapine and risperidone) SOE.

###### Mortality

The systematic review did not include any trials of outpatients reporting mortality rates.^28^ One retrospective cohort study was included, reporting higher risk of mortality in patients taking haloperidol versus clozapine or risperidone. These results are difficult to interpret, as patient characteristics such as age were not reported in patients taking antipsychotic medications, and the controls in the study were taking antipsychotic mediations for reasons other than schizophrenia or other psychotic disorders.^245^

###### Reduction in Self-Harm

Most RCTs excluded patients at risk for suicide. In trials of haloperidol versus olanzapine (N=182) and perphenazine versus olanzapine (N=597) there were no differences in incidence of attempted suicide (RR 3.13, 95% CI 0.13 to 76; and 0.64, 95% CI 0.06 to 7.06) or suicide deaths (RR 3.13, 95% CI 0.13 to 76; and 3.86, 95% CI 0.40 to 37).^28^ One trial not included in the systematic review reported no difference between LAI paliperidone and LAI haloperidol in incidence of suicidal or homicidal ideation (RR 1.10, 95% CI 0.63 to 1.89).^70^ This was insufficient SOE.

###### Improvement in Core Illness Symptoms

The systematic review assessed total and negative symptoms based on a number of scale measures, including total PANSS, BPRS, CGI-S and CGI-I for total symptoms and PANSS and SANS for negative symptoms (Appendix Table E-1).^27,28^ Comparative evidence was only available for haloperidol versus SGAs. The review did not combine results across different scales.

###### Total Symptoms

###### PANSS

Based on pooled analysis, there were significant difference in total PANSS between haloperidol and olanzapine (15 RCTs, N=4,209; MD 2.31, 95% 0.44 to 4.18) and risperidone (21 RCTs, N=4,020; MD 3.24, 95% CI 1.62 to 4.86), both favoring the SGA over haloperidol. This was moderate SOE, and the differences are small enough to possibly not meet a minimal clinically important difference threshold. There were no differences between haloperidol and clozapine (four RCTs, N=607; MD 2.69, 95% CI −1.28 to 6.65), quetiapine (five RCTs, N=1,013; MD 0.31, 95% CI −2.34 to 2.96) and ziprasidone (four RCTs, N=1,105; MD 1.22, 95% CI −0.62 to 3.07). This evidence was low strength.

###### BPRS

There were no differences in BPRS scores between haloperidol and aripiprazole (three RCTs, N=779; MD −0.01, 95% CI −2.82 to 2.81), clozapine (four RCTs, N=268; MD2.16, 95% CI −0.56 to 4.87), olanzapine (13 RCTs, N=4,014; MD 0.19, 95% CI −2.09 to 2.47), quetiapine (four RCTs, N=756; MD 1.23, 95% CI −0.50 to 2.96), risperidone (14 RCTs, N=2,659; MD 0.67, 95% CI −0.53 to 1.88) and ziprasidone (four RCTs, N=1,143; MD 0.24, 95% CI −0.57 to 1.06). This was low-strength evidence.

###### CGI-S

CGI-S scores, as a measure of illness severity, were marginally better with in olanzapine (MD 0.16, 95% CI 0.01 to 0.31) when compared with haloperidol, and better with haloperidol when compared with quetiapine (MD −0.23, 95% CI −0.42 to −0.04) based on analysis of eight (N=3,564) and four (N=1,253) trials each. Though these estimates were significant, they were considered not clinically meaningful.^27^ The SOE was moderate for both comparisons. MD in scores for haloperidol and aripiprazole (five RCTs, N=1,366; −0.03, 95% −0.20 to 0.14) risperidone (eight RCTs, N=2,348; 0.07, 95% CI −0.11 to 0.25) and ziprasidone (four RCTs, N=1,143; −0.00, 95% CI −0.26 to 0.26) was not significantly different between groups, with low SOE for all comparisons.

###### CGI-I

There was no difference in CGI-I scores, as a measure of improvement since beginning treatment, between haloperidol and olanzapine (two RCTs, N=281; MD 0.11, 95% −0.30 to 0.51), quetiapine (three RCTs, N=623; MD 0.02, 95 % CI −0.24 to 0.27) and risperidone (three RCTs, N=657; −0.02, 95 % CI −0.39 to 0.36) based on pooled analysis. This was low SOE.

###### Negative Symptoms

###### PANSS Negative

There was moderate-strength evidence that some SGAs were more effective than haloperidol at improving PANSS negative symptom scores. Analysis of MD in score between haloperidol and aripiprazole (three RCTs, N=1,701; 0.80, 95% CI 0.14 to 1.46), olanzapine (14 RCTs, N=3,742; 1.06, 95% CI 0.46 to 1.67), and risperidone (22 RCTs, N=4,142; 0.80, 95% CI 0.14 to 1.46) all favored the SGA. Evidence was not able to identify a difference in PANSS negative symptoms scores when comparing haloperidol and clozapine (three RCTs, N=184; MD 0.28, 95% CI −0.96 to 1.51), quetiapine (three RCTs, N=358; MD0.53, 95% CI −0.81 to 1.87) and ziprasidone (two RCTs, N=900; MD 0.56, 95% CI −0.30 to 1.42). This evidence is low strength, primarily due to the small sample sizes. Whether significant or not, the differences found were very small.

###### SANS

Olanzapine was found to be more effective than haloperidol at improving SANS scores based on analysis of five RCTs (N=535; MD 2.56, 95% CI 0.94 to 4.18). The SOE was moderate. Evidence was not able to identify a difference between haloperidol and clozapine (two RCTs, N=157; MD 0.94, 95% CI −2.60 to 4.48) or risperidone (4 RCTs, N=508; MD 0.30, 95% CI −2.79 to 3.38). This was low-strength evidence.

###### Overall Adverse Events

Overall adverse event rates were reported for each FGA and select SGAs (Appendix Table E-1).^28^ When compared with haloperidol, there were significant differences favoring aripiprazole (three RCTs, N=1,713; RR 1.11, 95% CI 1.06 to 1.17; I^2^=0%), risperidone (eight RCTs, N=1,313; RR 1.20, 95% CI 1.01 to 1.42; I^2^=84%), and ziprasidone (six RCTs, N=1,448; RR 1.13, 95 % CI 1.03 to 1.23; I^2^=31%). Due to limited evidence and heterogeneity for the risperidone and ziprasidone comparisons, SOE is low. No significant differences overall adverse event rates for other comparisons, primarily based on single studies, comparing: fluphenazine with olanzapine (one RCT, N=60; RR 9.00, 95% CI 0.51 to 160); haloperidol with asenapine (one RCT, N=335; RR 1.09, 95% CI 0.96 to 1.25), clozapine (one RCT, N=423; RR 0.81, 95% CI 0.49 to 1.34), olanzapine (one RCT, N=119; RR 10.47, 95% 0.59 to 185), or quetiapine (three RCTs, N=859; RR 1.08, 95% CI 0.93 to 1.25; I^2^=25%); perphenazine with olanzapine (one RCT, N=597; RR 0.93, 95% CI 0.83 to 1.04), quetiapine (one RCT, N=598; RR 1.00, 95% CI 0.89 to 1.12), risperidone (one RCT, N=602; RR 0.96, 95% CI 0.85 to 1.07), or ziprasidone (one RCT, N=446; RR 1.01; 95% CI 0.88 to 1.16). SOE for all of these comparisons was insufficient.

###### Withdrawal Due to Adverse Events

Evidence on withdrawals due to adverse events comes from the systematic review^28^ and four additional RCTs^57,67–69^ not included in the systematic review (Appendix Tables E-1 and E-2). When comparing haloperidol with specific SGAs, withdrawals due to adverse events were significantly higher with haloperidol use compared with aripiprazole (eight RCTs, N=3,232; RR 1.25, 1.07 to 1.47; I^2^=0%; Appendix G-4), olanzapine (24 RCTs, N=5,708; RR 1.89, 95% 1.57 to 2.27; I^2^=0%; Appendix G-5), risperidone (25 RCTs, N=4,581; RR 1.32, 95 % CI 1.09 to 1.60; I^2^=0%; Appendix G-6), and ziprasidone (seven RCTs, N=1,597; RR 1.68, 95% 1.26 to 2.23; I^2^=0 %; Appendix G-7). This was moderate SOE. There is low SOE of no difference in withdrawal due to adverse events when comparing haloperidol and clozapine (5 RCTs, N=719; RR 1.00, 95% CI 0.66 to 1.50; I^2^=0 %) or quetiapine (10 RCTs, N=1,759; RR 1.97, 95% CI 0.96 to 4.01; I^2^=62%; Appendix G-8). Based on single studies for each comparison, there was no significant differences when comparing: haloperidol to asenapine (N=335; RR 1.53, 95% 0.74 to 3.16); fluphenazine to olanzapine (N=60; RR 0.74, 95% CI 0.51 to 1.07) or quetiapine (N=25; RR 0.19, 95% CI 0.01 to 3.52); or perphenazine to aripiprazole (N=300; RR 0.53, 95% CI 0.27 to 1.05), olanzapine (N=597; RR 0.83, 95% CI 0.58 to 1.19), quetiapine (N=598; RR 1.05, 95% CI 0.72 to 1.55), risperidone (N=602; RR 1.54, 95% CI 1.00 to 2.36), or ziprasidone (N=446; RR 1.01, 95% CI 0.65 to 1.58). SOE for these comparisons was insufficient.

## Key Question 1b Variation of Benefits and Harms of Pharmacological Treatments for Adults With Schizophrenia by Patient Characteristics

### Second-Generation Antipsychotic Versus Second-Generation Antipsychotic

#### Key Points

- Evidence on SGAs versus each other in population subgroups was limited.
- In 17 trials in patients with first-episode psychosis evidence did not indicate significant differences between oral olanzapine, quetiapine, risperidone, ziprasidone, aripiprazole, or paliperidone in rates of response or remission.
  ○ Most studies also reported no difference in core illness symptom measures. These findings did not differ according to the duration of study, the specific drugs compared, in adolescents or women, or whether or not studies were blinded.
  ○ Evidence on study medication discontinuation was more limited, with conflicting findings from five trials. Olanzapine was not found to have fewer discontinuations and longer time to discontinuation consistently across the studies.
  ○ Single-trial evidence suggests that fewer patients taking aripiprazole discontinue medication than ziprasidone or quetiapine but patients receiving aripiprazole had more weight gain than those receiving ziprasidone.
- In treatment-resistant patients, network meta-analyses indicated a small benefit with olanzapine over other older SGAs in core illness symptom improvement, negative symptoms, whereas response rates and all-cause treatment discontinuations were not different. Clozapine had fewer discontinuations due to lack of efficacy.
- In subgroups based on age and sex:
  ○ Subgroup analyses did not find differences based on age between olanzapine and risperidone in symptom measures, quality of life, or persistence (>60 years or 50 to 65 years vs. younger populations).
  ○ Subgroup analyses indicated that women improved more than men on the CGI scale with clozapine and the EQ-5D visual analog scale score with olanzapine, compared with men.
  ○ Women and younger patients (<40 years) were at higher risk of new onset diabetes than older, male patients with olanzapine and risperidone compared with FGAs.
- Asian patients: Comparisons of aripiprazole and paliperidone with olanzapine, and quetiapine and risperidone in Asian patients were similar to the overall conclusions for these comparisons.
- In subgroups based on comorbidities and concomitant drug use:
  ○ Users of illicit drugs did not have different findings on any outcome compared with the overall study population in CATIE Phase 1 (olanzapine, risperidone, quetiapine and ziprasidone).
  ○ Response rates were also similar for olanzapine and risperidone in patients with first-episode schizophrenia and a history of cannabis use disorders.

#### Detailed Synthesis

##### Description of Included Studies

Very limited direct comparative evidence addressed SGAs used for the treatment of schizophrenia in subgroups of the population. Five studies assessed the impact of age,^163,240,246–248^ two assessed the impact of race,^249,250^ and three evaluated the impact of SGAs in patients with comorbid substance use or alcohol use disorders.^251–253^ Most trials did not report ethnicity of enrolled patients and although three trials reported that a substantial number of patients were of African ancestry, none stratified results to examine differences in response or adverse events.^152,192,254^ Three trials assessed the effects of these drugs on depressive symptoms, but the patients were not selected for the trial based on depressive symptoms.^255–257^ The results of these trials were discussed above.

In a subgroup analysis, 100 patients who had been randomly assigned to aripiprazole or risperidone were tested for the rs2514218 genotype. The authors then correlated symptom response and adverse events with genotype status. They found that “homozygotes for the risk (C) allele at rs2514218 had significantly greater reduction in positive symptoms during 12 weeks of treatment compared to the T allele carriers. In the aripiprazole group, C/C homozygotes also reported more akathisia than the T allele carriers, whereas in the risperidone group, male T allele carriers demonstrated greater prolactin elevations compared to male C/C homozygotes.”^258^ These findings suggest further development of genotyping may help with selection of SGA medications, but is preliminary at this point.

##### Findings

###### Clinical Subgroups

###### First-Episode Schizophrenia

The systematic review identified 17 trials (in 22 publications) of oral SGAs in patients experiencing their first episode of symptoms of schizophrenia.^29^ The studies were mainly fair quality (12 of 17), with nine open label trials (Table 8). Six trials had at least 12 months of followup and sample sizes ranged from 50 to 498. One trial included only women. And the mean age of patients was early 20s to late 30s.

Table 8 Studies of SGAs in patients treated for first episode of schizophrenia

Study | N Duration Blinding | Comparison | Results
Crespo-Facorro, 2011^67^ | N=174 1 year with 3 year followup Open | Olanzapine vs. Risperidone | NSD relapse, time to relapse or remission at 1 year NSD Symptoms or global functioning (1 and 3 years) NSD in discontinuation for any reason (1 and 3 years). NSD % reporting weight gain, change in EPS or new parkinsonism (3 years) NSD % akathisia, but increase in severity greater with risperidone vs. olanzapine (p=0.042). Daytime drowsiness greater with olanzapine Sexual dysfunction in men and amenorrhea in women greater with risperidone.
Crespo-Facorro, 2006^159^ | N=182 6 weeks Open | Olanzapine vs. Risperidone | NSD symptoms
Robinson, 2006^173^ | N=112 16 weeks Open | Olanzapine vs. Risperidone | NSD response, negative symptoms
McEvoy, 2007^169^ (CAFÉ study) | N=400 1 year DB | Olanzapine vs. Quetiapine vs. Risperidone | NSD in all-cause treatment discontinuations and core illness symptoms
Li, 2012^167^ | N=80 6 weeks Open | Olanzapine vs. Ziprasidone | NSD symptoms
Kahn, 2008^231,259^ (EUFEST study) | N=498 12 months Open | Olanzapine vs. Quetiapine vs. Ziprasidone | NSD response or remission. NSD all-cause treatment discontinuations for ziprasidone vs. quetiapine and olanzapine Quetiapine results in significantly higher risk of discontinuation than olanzapine. (OR 2.41, 95% CI 1.31 to 4.45)
San, 2012^68^ | N=114 12 months Open | Olanzapine vs. Quetiapine vs. Risperidone vs. Ziprasidone | All-cause treatment discontinuation lower with olanzapine (40%) than quetiapine (56.5%), risperidone (64%), or ziprasidone (80%). Mean time to discontinuation significantly longer with olanzapine (260 days) than the other drugs (range 142 days ziprasidone to 206 days risperidone; p=0.005).
Liu, 2014^52^ | N=80 12 months Open Women | Quetiapine vs. Risperidone | NSD Core illness symptoms at 9 and 12 months (lower with risperidone at 3 and 6 months).
Gafoor, 2010^260^ | N=72 12 weeks SB | Quetiapine vs. Risperidone | NSD all-cause treatment discontinuation, time to discontinuation, symptoms
Robinson, 2015^59^ | N=209 12 weeks DB | Aripiprazole vs. Risperidone | NSD in response, core illness symptoms
Crespo-Facorro, 2013^261^ | N=249 12 months Open | Aripiprazole vs. Ziprasidone vs. Quetiapine | NSD relapse or remission, core illness symptoms, adverse events, EPS, akathisia Treatment discontinuation: Quetiapine 82.3%, ziprasidone 66.1%, aripiprazole 43.6% (p<0.001) Time to D/C (mean days): Quetiapine 77.24, ziprasidone 129.88, aripiprazole 106.71 (p<0.001) D/C due to adverse events: Quetiapine 11.3%, ziprasidone 29%, aripiprazole 10.3% (p=0.005) ≥ 7% weight gain: Aripiprazole vs. ziprasidone: 45.6% vs.23.5% (p=0.02)
Zhang, 2012^242^ | N=254 52 weeks Open | Paliperidone vs. Ziprasidone vs. Aripiprazole | Core illness symptoms significantly lower with paliperidone than ziprasidone or aripiprazole at 13, 26 and 52 weeks NSD response rate

CGI = Clinical Global Impressions scale; CGI-S = Clinical Global Impressions-Severity scale; CI = confidence interval; N = sample size; NSD = no significant difference; OR = odds ratio; PANSS = Positive and Negative Syndrome Scale; SGA = second-generation antipsychotic; SS = statistically significant

Differences among the SGAs on at least one outcome were found in five of 12 fair-quality trials. Olanzapine was found to have lower risk and longer time to all-cause treatment discontinuation than risperidone (one of three RCTs), quetiapine (two of two RCTs), and ziprasidone (one of three RCTs), but differences in other benefit outcomes were not found. One trial that did not find differences in benefit outcomes at 1 year also found no differences at 3 years of followup. This trial also reported that patients taking risperidone had higher incidence of increasing severity of akathisia, sexual dysfunction (in men) and amenorrhea, whereas more patients reported daytime drowsiness with olanzapine. In a single study, aripiprazole was found to have lower risk of all-cause treatment discontinuation than quetiapine or ziprasidone, lower risk of discontinuing due to adverse events than ziprasidone, longer time to discontinuing than quetiapine, and greater risk of important weight gain than ziprasidone, but differences in other benefit outcomes were not found. A single trial found that core illness symptoms (based on the PANSS) were better with paliperidone than ziprasidone or aripiprazole, but that response rates did not differ significantly.

###### Treatment-Resistant Patients

Treatment resistance, defined as at least two adequate trials of an antipsychotic medication with failure to respond, is a challenge in approximately 20 to 30 percent of patients with schizophrenia.^262^ Although clozapine has been considered the treatment of choice, comparisons to other SGAs are needed since clozapine has a serious adverse event profile, the need for regular laboratory monitoring, and not all patients respond.

An analysis of six oral SGAs (clozapine, risperidone, olanzapine, quetiapine, and ziprasidone) in 40 RCTS of patients with treatment-resistant schizophrenia found that the mean change in the PANSS was greater with olanzapine than quetiapine (SMD −0.29, 95% CI −0.56 to −0.13).^183^ The authors note that this corresponds to a difference in points on the PANSS of −6.08 (scale scores range from 30 to 210; 180 possible points). There is some evidence that in patients with more severe disease a minimal clinically important difference on the PANSS is 11.5 points, indicating that a difference of six points may not be clinically important, although statistically significant.^195^ The newer oral drugs (aripiprazole, iloperidone, lurasidone, asenapine, cariprazine, brexpiprazole) were not included. This was low-strength evidence.

There are three systematic reviews published since 2013 that address the comparative benefits and harms of SGAs for treatment-resistant patients.^183,263,264^ The most recent and comprehensive of these uses network meta-analysis of 40 RCTS to analyze clozapine, risperidone, olanzapine, quetiapine, and ziprasidone (as well as three FGAs and an SGA not available in the United States).^183^ The newer oral drugs (aripiprazole, iloperidone, lurasidone, asenapine, cariprazine, brexpiprazole) and injectable SGAs were not included. The mean change in the PANSS was greater with olanzapine than quetiapine (SMD −0.29, 95% CI −0.56 to −0.13).^183^ The authors note that this corresponds to a difference in points on the PANSS of −6.08 (scale scores range from 30 to 210; 180 possible points). There is some evidence that in patients with more severe disease a minimal clinically important difference on the PANSS is 11.5 points, indicating that a difference of six points may not be clinically important, although statistically significant.^195^ Network analysis of negative symptoms found olanzapine significantly better than the other SGAs (and two FGAs), whereas response rates and all-cause treatment discontinuations indicated no significant differences among the SGAs (although SGAs were better than haloperidol). Analysis of discontinuations due to lack of efficacy showed clozapine to be better than risperidone and quetiapine (and two FGAs). One of the other two reviews compared only olanzapine and clozapine, and had consistent findings (no differences on discontinuation rates or improvement in PANSS total scores; clozapine superior on positive and negative symptoms).^263^ The third review evaluated strategies when clozapine fails, but was not able to come to a conclusion on adjunctive drug therapy including adding a second SGA.^264^

###### Special Populations

Age. Two fair-quality studies were specifically designed to compare the effects of olanzapine with risperidone in older patients (≥60 years) with schizophrenia or schizoaffective disorder.^163,240,265^ In an 8-week trial, no between-group differences were found in response rates (20% improvement on PANSS) or change in PANSS, CGI, or Hamilton Depression Scale (HAM-D) scores. In a smaller study (N=66), during the initial 6 months of followup there were no significant differences in efficacy outcomes (BPRS, SANS, Montgomery-Asberg Depression Scale [MADRS]) between the drugs. However, patients taking olanzapine were seen to have better quality of life at 6 months as assessed using the World Health Organization Quality of Life tool (p=0.040 for overall quality of life, p=0.031 for satisfaction with health), with better physical health and social relationships. Differences were not seen on the psychological or environmental domains. These outcomes are similar to outcomes found in younger populations, reported above.

Post hoc subgroup analyses of the Tran trial, which compared olanzapine with risperidone, reported outcomes for the subgroup of patients 50 to 65 years old.^181,247,266^ Out of a total study population of 339 patients, 39 were between 50 and 65 years old. The split between sexes was not evenly distributed across the two drug groups. The risperidone group was 42 percent male, whereas the olanzapine group was 70 percent male. Another difference at baseline was the duration of the current episode, a mean of 61 days in the olanzapine group and 120 days in the risperidone group (although not significant). The mean modal dose in the olanzapine group was 18 mg (within midrange) and in the risperidone group 8 mg (above midrange). In general, because the size of the subgroup was small and the age range covered only up to 65 years, the implications of the findings of this subanalysis for older patients with schizophrenia were difficult to interpret. However, the analysis did indicate that results were probably not different in this older population.

A retrospective study from the US Department of Veterans Affairs database, conducted to evaluate the risk of new onset diabetes among new users of SGAs, found a differential effect with analysis by age.^246^ Higher risk was found with olanzapine (p=0.05) and risperidone (p=0.03) for patients less than 45 years old, whereas the risk with quetiapine in this group was not significant.

Race. A retrospective study of Texas Medicaid claims data analyzing the mean number of days patients continued to take their prescribed SGA drug found that patients who were Mexican American or African American had significantly fewer days on drug than white patients, although the difference in days was small (18 and 19, respectively).^250^ The analysis did not indicate a difference among these groups when stratified by which SGA they were taking (olanzapine or risperidone).

Subgroup analyses of a 26-week trial of aripiprazole and olanzapine (N=314) evaluated the risk of metabolic syndrome in white patients and black or Hispanic patients. In comparing the drugs, the results across the subgroups were similar to the overall findings (that aripiprazole resulted in lower risk), although the point estimate was lower for white patients than for black and Hispanic patients and the comparison for the smaller black/Hispanic group did not reach significance.^267^ The ORs were 0.33 (95% CI 0.19 to 0.55) for all patients, 0.20 (95% CI 0.10 to 0.41) for white patients, and 0.53 (95% CI 0.25 to 1.12) for black and Hispanic patients. Analyses of effects of ethnicity within each drug group found that white patients had lower risk than black and Hispanic patients taking aripiprazole, but that there was no difference between these groups among patients taking olanzapine.

Aripiprazole’s effect in Japanese patients, compared with other drugs, was evaluated in meta-analyses using both published and unpublished information in a good-quality systematic review.^268^ Although the overall analysis combined results from multiple different comparator drugs in a simple way (i.e., not an indirect comparison or network meta-analysis), the publication also reported pair-wise comparisons for aripiprazole compared with risperidone, olanzapine and quetiapine, based on a single study that included all four drugs.^230^ This study found no differences between the drugs on the PANSS total scores or subscale scores, but did find aripiprazole to result in a higher risk of discontinuation due to lack of efficacy compared with olanzapine (OR 6.25, 95% CI 1.14 to 34.12) and risperidone (OR 4.52, 95% CI 1.30 to 15.73), but no difference compared with quetiapine (OR 0.68, 95% CI 0.20 to 2.30). The confidence intervals are wide, as these results are based on a single, small (N=80), 8-week study and the results should be interpreted with caution. Future studies could overturn these findings. These results are consistent with the findings of all trials comparing these drugs. Another trial, reported above in Key Questions 1 and 2, included 455 Japanese, Taiwanese, Malaysian and Filipino patients randomized to oral or aripiprazole LAI, finding the injectable drug to be noninferior to the oral drug in “non-exacerbation of psychotic symptoms/non-relapse” as the primary outcome measure.^49^ There were no significant differences on secondary outcomes as well, including extrapyramidal adverse events.

Two trials compared aripiprazole and risperidone in Asian patients; one in Taiwan^155^ and one in mainland China.^51,193^ Both studies found no significant differences in efficacy outcomes at 4 and 6 weeks, consistent with the findings of the overall analysis in Key Question 1 above. These studies come to different conclusions on extrapyramidal symptoms (EPS)-related adverse events, with the small 4-week study conducted in Taiwan (N=83) reporting more EPS adverse events, particularly akathisia with aripiprazole,^155^ and the larger 6-week study conducted in China (N=279) reporting no differences between the drugs on EPS outcomes. A third study, conducted in North America in patients with first-episode schizophrenia, found aripiprazole to be significantly associated with higher akathisia scores on the Barnes Akathisia Scale in the early months of the trial, but not at 12 months.^59^ Other measures, Parkinsonism and EPS severity, were not found different when akathisia was not considered part of EPS. Based on these studies, it is not clear that there is a difference in effects, benefits or harms, of aripiprazole and risperidone in Asian patients.

A fair-quality systematic review evaluated paliperidone and paliperidone palmitate monthly LAI in Chinese patients with schizophrenia.^269^ The review included 53 studies of the oral paliperidone and 9 of the injection that were conducted in China, including pharmacokinetic studies, single-arm studies, and studies with olanzapine, quetiapine, risperidone or aripiprazole. The review concludes that few differences were found between the drugs and that the findings are consistent with study results in non-Asian patients.

Sex. Analysis of differences in effect by sex in the European SOHO study found that compared with women, men had lower odds of response (based on the CGI scale; OR 0.56, 95% CI 0.34 to 0.93) with clozapine and smaller improvement in quality of life (based on EQ-5D visual analog score; OR −1.52, 95% CI −2.53 to −0.50).^248^ Risperidone did not result in any differences between men and women.

###### Substance Use

In a post-hoc analysis of the CATIE Phase 1 trial data, outcomes were compared between users and nonusers of illicit substances.^252^ Based on the primary outcome measure of overall discontinuation (rate and time to), the results were consistent with the overall trial results for those who were nonusers (olanzapine superior to quetiapine and risperidone, ziprasidone not significantly different). However, significant differences were not found for any of the comparisons among users of illicit drugs. Further analyses compared olanzapine to the combined group of antipsychotic drugs in the trial and were not useful for the purposes of this report.

A subgroup analysis from a fair-quality trial of 49 patients with first-episode schizophrenia and a lifetime history of cannabis use disorders found no significant difference between olanzapine and risperidone in rate of response at 16 weeks, defined as (1) mild or better on all the Schedule for Affective Disorders and Schizophrenia – Change Version with Psychosis and Disorganization (SADS-C + PD) items severity of delusions, severity of hallucinations, impaired understandability, derailment, illogical thinking, and bizarre behavior; and (2) a concurrent rating of very much improved or much improved on the CGI (45% vs. 54%; p=0.68).^270^ These results were consistent with results for the trial population as a whole (N=112).^173^

Three additional studies addressed substance misuse subgroups, but we rated them poor-quality and they did not contribute to our overall conclusions.^251,253^ A small study of 29 patients with comorbid schizophrenia and cocaine or marijuana abuse or dependence that compared olanzapine with risperidone was rated poor-quality based on unclear randomization and allocation concealment procedures with resulting imbalances in baseline characteristics among the groups, unclear analyses, and differential discontinuation.^253^ A small cohort study (N=67) of patients with comorbid alcohol use disorder that compared rehospitalization rates with risperidone or clozapine was rated poor-quality due to unclear methods of patient selection. Nine percent of patients were removed from analysis because they discontinued drug due to adverse events and potentially important differences at baseline were not controlled for in analyses.^251^ We also gave a poor-quality rating to a randomized trial of 139 patients with schizophrenia and nicotine dependence because of unclear methods of randomization, allocation concealment, and blinding and unclear reporting about attrition and completeness of the analysis dataset.^271^

###### Obesity

An exploratory analysis of treatment effect across baseline body mass index categories (normal: <25 kg/m^2^; overweight: ≥25 to <30 kg/m^2^; obese: ≥30 kg/m^2^) from a 53-week, fair-quality RCT of 749 patients found that the difference in mean change in PANSS total score indicated noninferiority for paliperidone palmitate injection 63.5 mg (mean dose) compared with risperidone long-acting injectable 32.4 mg (mean dose) for the normal and overweight subgroup (difference in least-squared means −0.5, 95% CI −4.01 to +3.08), but not for the obese subgroup (−7.5, 95% CI −12.1 to −2.82).^188^ The findings of this study may be affected by the rate of dose initiation and location of injections used for paliperidone palmitate injection, which was lower than currently recommended.

### First-Generation Antipsychotic Versus Second-Generation Antipsychotic

#### Key Points

- In patients with a first episode of schizophrenia, the evidence comparing FGAs to SGAs is less robust than SGAs versus SGAs, but did not find significant differences between the drugs.
- In treatment-resistant patients, response was significantly better with ziprasidone than haloperidol (N=120; RR 1.54, 95% CI 1.19 to 2.00), whereas there was no significant effect in nontreatment-resistant patients. Negative symptoms were significantly reduced with olanzapine versus haloperidol (N=2,207; MD 1.28, 95% CI 0.11 to 2.44, whereas in mixed populations the difference was not significant.
- There was not a clear impact of dose on response or core illness symptom improvement based on subgroup analyses of aripiprazole, olanzapine, quetiapine, and risperidone versus haloperidol.
- Asian patients: Although response rates were similar between Asian and non-Asian subgroups, core illness symptoms were significantly improved in Asian patients with olanzapine versus haloperidol (one RCT; MD 4.40; 95% CI 0.33 to 8.47), and not in other races.
- In patients with co-occurring SUD, core illness symptoms improved significantly more with olanzapine than haloperidol, whereas the subgroup of studies excluding these patients showed no difference. With risperidone, the results were opposite: there was no significant difference in studies that included patients with SUD, whereas risperidone was better than haloperidol in studies that excluded such patients.

#### Detailed Synthesis

##### Description of Included Studies

The 2012 systematic review reported a number of subgroup analyses according to demographic and clinical patient characteristics. Analyses for which there was a difference between patient groups are reported below.^28^

##### Findings

###### Clinical Subgroups

###### First-Episode Schizophrenia

There was no difference between groups in total PANSS score in studies of haloperidol versus risperidone in patients with first-episode psychosis (one RCT, N=183; MD 1.60, 95% CI −5.61 to 8.81) and those with multiple psychotic episodes (seven RCTs, N=1,984; MD −0.56, 95% CI −3.98 to 2.86; I^2^=65%).^28^ For other comparisons, outcomes were significantly better for the SGA only for the subgroup that included multiple episodes (Appendix Table E-1).

###### Treatment-Resistant Schizophrenia

Analysis of studies of haloperidol versus olanzapine stratifying results according to treatment resistance found mixed and unclear effects on total symptom scores (Appendix Table E-1).^28^ Using BPRS as a measure, a mixed population treatment and nontreatment-resistant patients fared better with olanzapine than haloperidol (nine RCTs, N=1,809; MD 1.10, 95 % CI 0.62 to 1.58; I^2^=0%), whereas in the treatment-resistant only populations there was no difference between the drugs, (four RCTs, N=2,205; MD −5.50, 95% CI −14.1 to 3.07) although heterogeneity was so high as to render this estimate unreliable (I^2^=95%). Using CGI-S as a measure, in treatment-resistant patients olanzapine resulted in a significant benefit (two RCTs, N=2,059; MD 0.24, 95 % CI 0.01 to 0.47; I^2^=32%), although the difference is so small (0.24 on a 0 to 7 scale) that clinical relevance is unlikely. The analysis of mixed populations showed no significant benefit (five RCTs, N=1,297; MD 0.07, 95% CI −0.10 to 0.24; I^2^=71%).

Negative symptoms were reduced with olanzapine use in treatment-resistant patients based on five trials (N=2,207; MD 1.28, 95 % CI 0.11 to 2.44; I^2^=40 %) with no significant effect in patients with no treatment resistance based on one small trial (N=44; MD 1.02, 95% CI −2.39 to 4.43; Appendix Table E-1).

Treatment-resistant patients taking ziprasidone were twice as likely to respond to treatment versus haloperidol based on one trial (N=120; RR 1.54, 95% CI 1.19 to 2.00) whereas no such effect was found in three trials of patients without treatment resistance (N=1,053; RR 0.79, 95% CI 0.56 to 1.13; Appendix Table E-1).

###### Impact of Dose

Analyses according to FGA dose were limited to studies comparing haloperidol with aripiprazole, olanzapine, quetiapine and ziprasidone with response being the only outcome available for all comparisons (Appendix Table E-1).^28^ The subgroup analyses divided the haloperidol dosing into <20 mg/day and >20 mg/day. The findings are not consistent across the SGAs, and not consistent with the theory that lower doses of FGAs would have better results. The findings of the overall and lower-haloperidol dose subgroup analyses were consistent; olanzapine was significantly better. The higher-haloperidol dose subgroup analysis was not significantly different, but there were only two studies, limiting the statistical power to find a difference, and the relative risk was similar to the other analyses. For aripiprazole and quetiapine, again the overall and lower-haloperidol dose analyses were similar (no difference in these cases), but the higher-haloperidol dose subgroup analyses showed the FGA to be better. With ziprasidone, finally, the lower-dose haloperidol subgroup analysis showed ziprasidone superior, whereas the other analyses found no difference. This evidence is difficult to interpret in due to high heterogeneity and the small numbers of studies using higher doses of haloperidol (1–2 studies of the higher doses for each comparison).

###### Special Populations

###### Race

When comparing haloperidol and olanzapine, total BPRS scores were significantly better in the olanzapine group when stratified according to Asian race (one RCT; MD 4.40; 95% CI 0.33 to 8.47) but not significant in a subgroup of studies in other races (12 RCTs; MD 0.28; 95% CI −1.48 to 2.04). For the same comparison, response rates were similar for Asian (one RCT; RR 0.87; 95% CI 0.76 to 1.00) versus other races (13 RCTs; RR 0.86; 95% CI 0.76 to 0.97) favoring olanzapine, although the estimate was significant for other races but not Asians (Appendix Table E-1).^28^

###### Substance Use

Evidence on the comparative effectiveness of haloperidol versus SGAs on core illness total symptom scores in patients with co-occurring SUD were mixed (Appendix Table E-1).^28^ Although the systematic review did not have data to evaluate only a subgroup of patients with SUD, in studies of mixed populations olanzapine had significantly better total PANSS (12 RCTs, N=3,726; MD 2.71, 95% CI 0.75 to 4.67; I^2^=40%), BRPS (seven RCTs, N=2,890; MD 2.05; 95% CI 0.55 to 3.55; I^2^=90 %) and CGI-S (three RCTs, N=2,467; MD 0.28, 95% CI 0.19 to 0.38; I^2^=0%) scores than haloperidol. In studies that excluded people with SUD the difference was not significant, possibly due to smaller sample sizes (PANSS: three RCTs, N=483; MD −0.73, 95% CI −5.83 to 4.38; I^2^=0 %; BPRS: six RCTs, N=1,124; MD −2.37, 95% CI −6.19 to 1.44; I^2^=36%; and CGI-S: five RCTs, N=1,097; MD 0.30, 95% CI −0.13 to 0.20). Conversely, risperidone use resulted in better symptom scores in the studies that excluded those with SUD based on total PANSS (14 RCTs, N=3,188; MD 2.56, 95% CI 0.65 to 4.47; I^2^=18%) and BPRS (seven RCTs, N=1,875; MD 0.84, 95% CI 0.36 to 1.32; I^2^=0%), whereas there was no significant effect in studies of mixed populations (six RCTs, N=833; MD 1.95, 95% CI −3.14 to 7.04; I^2^=82%; and six RCTs, N=717; MD 0.23, 95% CI −1.44 to 1.90; I^2^=29 %).

Haloperidol use resulted in significantly better negative symptom scores in patients with co-occurring SUD based on one small (N=31) RCT versus olanzapine (MD −3.20, 95% CI −6.03 to −0.37), whereas in nine trials (N=3,184) enrolling a mixed population, olanzapine use resulted in better negative symptom scores compared with haloperidol (MD 1.27, 95% CI 0.82 to 1.72; I^2^=2%).

## Key Question 2a Benefits and Harms of Psychosocial and Other Nonpharmacological Treatments for Adults With Schizophrenia Compared With Usual Care

### Assertive Community Treatment Versus Usual Care

#### Key Points

- Evidence on assertive community treatment comes from one good-quality systematic review (14 RCTs; N=2,281) and one other RCT (N=118) not included in the review. The primary outcome target of this intervention is reduction in rehospitalization (not a prioritized outcome for this review).
- Assertive community treatment did not improve social function more than usual care, based on pooled analysis of three studies (MD 0.03; 95% CI −0.28 to 0.34); an additional trial also found no difference (SOE: low).
- Compared with usual care, there were no significant differences in arrests (two trials, total N=604; OR 1.17, 95% CI 0.60 to 2.29), imprisonment (four trials, total N=471; OR 1.19, 95% CI 0.70 to 2.01), or police contacts (two trials, total N=149; OR 0.76, 95% CI 0.32 to 1.79) with assertive community treatment (SOE: low).
- Assertive community treatment resulted in a lower likelihood of not living independently (four trials; OR 0.52, 95% CI 0.35 to 0.79), being homeless (four trials, OR 0.20, 95% CI 0.09 to 0.47) and being unemployed (three trials; OR 0.46, 95% CI 0.21 to 0.99) compared with usual care (SOE: moderate).
- Core illness symptoms improved to a similar degree in both assertive community treatment and usual care groups (three trials, MD −0.14; 95% CI −0.36 to 0.08). (SOE: moderate).
- Assertive community treatment reduced the likelihood of patients being admitted to a hospital, compared with usual care (N=six RCTs; OR 0.59, 95% CI 0.41 to 0.85, I^2^=73%).

#### Detailed Synthesis

##### Description of Included Studies

A good-quality systematic review of 14 RCTs (N=2,281) assessed assertive community treatment compared with usual care (Appendix Tables E-3 and F-3).^71^ The review defines assertive community treatment as a multi-disciplinary team-based approach to caring for patients with severe mental illness who are described as reluctant and uncooperative. The care is provided through “assertive outreach,” offering services at home or work, with team members sharing responsibility for patients. Key goals of assertive community treatment are to maintain the patient’s contact with services, reduce the incidence and duration of hospitalizations, and improve social functioning and quality of life.^71^ A more recent review that combined evidence for assertive community treatment and intensive case management was not used, as we considered these to be distinct interventions.^272^ However, all of the trials of assertive community treatment included in the newer review are included here. The earlier systematic review included trials of interventions explicitly described as assertive community treatment, assertive case management, or PACT (Program of Assertive Community Treatment), or as being based on acknowledged models of assertive community treatment. Participants in the included trials had been diagnosed with schizophrenia or schizophrenia-like disorders, bipolar disorder, or depression with psychotic features. Most studies used eligibility criteria aimed at enrolling patients with frequent hospitalizations over the past 2 to 5 years, or recently hospitalized patients, but not all. Mean age ranged from 29 to 48 years. Among trials reporting other patient demographics, the proportion of female participants ranged from 0 to 56 percent and blacks were 18 to 72 percent of included populations. Quality of included studies ranged from fair to good; poor-quality studies were excluded, and the review notes that one of the flaws in the evidence based is the lack of measurements of program fidelity. Study duration ranged from 6 months to 2 years.

We identified one additional fair-quality RCT (N=118) of assertive community treatment, conducted in the Netherlands and published since the systematic review described above that enrolled participants with severe mental illness, including schizophrenia-spectrum or psychotic disorders (75%), bipolar disorder (4%), major depressive disorder (14%), and other mental illness (7%).^72^ (Appendix Table E-4). The mean age was 42 years, 31 percent were females; duration of illness was about 8 years; ethnicity was not reported and patients were followed for 15 to 24 months. This study measured fidelity to the assertive community treatment program using the Dartmouth Assertive Community Treatment Scale (DACT), and found that the study treatment achieved scores ranging from 3.8 to 4.1 on a scale of 1 to 5.

##### Findings

###### Function

###### Social Function

Based on a systematic review of three RCTs and one additional trial not included in the RCT, there was low-strength evidence that assertive community treatment does not improve social function more than usual care after 1 to 2 years. The systematic review of assertive community treatment found no significant effect on social function, based on pooled analysis of three trials (N=206) using different measures of social function (MD 0.03; 95% CI −0.28 to 0.34; I^2^=7%; Appendix Table E-3).^71^ Using the SFS scale, the additional RCT (N=118) found no impact of assertive community treatment compared with usual care at 12 months followup.^72^ (Appendix Table E-4). The SOE for function was low due to study limitations and imprecision.

###### Legal System Encounters

The systematic review reported no significant differences in arrests (two trials, total N=604; OR 1.17, 95% CI 0.60 to 2.29; I^2^=0%), imprisonment (four trials, total N=471; OR 1.19, 95% CI 0.70 to 2.01; I^2^=27%), or police contacts (two trials, total N=149; OR 0.76, 95% CI 0.32 to 1.79; I^2^=84%; Appendix Table E-3). This was low-strength evidence due to study limitations and imprecision.

###### Living Situation

The systematic review reported that assertive community treatment patients were less likely to not be living independently (i.e., more likely to be living independently) at the end of the trials compared with those receiving usual care (three trials, total N=362; OR 0.46, 95% CI 0.29 to 0.74; I^2^=0%) (Appendix Table E-3). The additional trial reported that the change in the number of days in “sheltered homes” was not different between assertive community treatment and usual care.^72^ In our analysis, assertive community treatment resulted in a lower likelihood of not living independently (four trials; OR 0.52, 95% CI 0.35 to 0.79; Appendix G-9) compared with usual care. This SOE is moderate.

The review also found that patients assigned to assertive community treatment were less likely to be homeless during or at the end of study compared to patients assigned to usual care (three trials, total N=374; OR 0.24, 95% CI 0.11 to 0.51; I^2^=52%). The additional study (N=118) also found a reduction in homelessness in the assertive community treatment group. Combining this evidence, the pooled odds ratio is 0.20 (95% CI 0.09 to 0.47; Appendix G-10). This was low-strength evidence due to the small numbers of events, leading to imprecise estimates.

###### Employment

The systematic review reported significantly less unemployment in the assertive community treatment group compared to the usual care group based on two trials (total N=604; OR 0.31, 95% CI 0.19 to 0.50; I^2^=34%). In our analysis, assertive community treatment resulted in a lower likelihood of being unemployed (three trials; OR 0.46, 95% CI 0.21 to 0.99; Appendix G-11) compared with usual care. The strength of this evidence is moderate.

###### Health-Related Quality of Life

Only one trial included in the systematic review reported quality of life, finding assertive community treatment associated with a significant but very small difference in quality of life score relative to usual care (MD −0.52, 95% CI −0.99 to −0.05; Appendix Table E-3). The additional trial also reported quality of life, using the MANSA scale, but found no impact with assertive community treatment relative to usual care. This evidence is insufficient due to study limitations, inconsistency between the trials, and imprecision.

###### Improvement in Core Illness Symptoms

The systematic review combined a wide range of symptom measures, including the BPRS, Brief Symptom Inventory, and Colorado Symptom Index and reported no significant differences between groups in symptoms based on three trials (N=255; MD −0.14; 95% CI −0.36 to 0.08) (Appendix Table E-3).^71^

The other RCT (N=118) not included in the systematic review reported total symptom scores using the BPRS symptom scale and found that, whereas symptoms improved in both assertive community treatment and usual care groups over time, there was no difference between interventions at 1 year (Appendix Table E-4).^72^ This was moderate SOE.

###### Treatment Discontinuation

The systematic review reported significantly less loss to followup with assertive community treatment compared to usual care based on 10 trials (total N=1,597; OR 0.51, 95% CI 0.40 to 0.65; I^2^=0%) (Appendix Table E-3). The RCT reported the number of patients who were “out-of-care” during the last 12 months of the study, and found assertive community treatment to result in significantly lower rates (OR 0.10, 95% CI 0.03 to 0.33).^72^ In our analysis, fewer patients receiving assertive community treatment were lost to followup (discontinued treatment) than those in usual care (12 trials; OR 0.51, 95% CI 0.41 to 0.63; Appendix G-12). This was moderate SOE.

###### Other Outcomes

Rehospitalization. The systematic review found that assertive community treatment reduced the likelihood of patients being admitted to a hospital, compared with usual care (OR 0.59, 95% CI 0.41 to 0.85, I^2^=73%).^71^ The statistical heterogeneity was high in this analysis, and examination of the forest plot reveals that inclusion criteria and country of study may have influenced these findings – specifically, those studies enrolling a broader population, not limited to those with a history of frequent hospitalizations, had a smaller and not significant effect. The review also found that the duration of hospitalizations was reduced for those receiving assertive community treatment compared with usual care, in seven of eight trials reporting this outcome but was statistically significant in five. The data were reported in varying ways, such that a mean or range of difference in duration was not clear, and the authors of the review note that not all the data were analyzed correctly.

The additional RCT that was not included in this review did not find that assertive community treatment significantly reduced inpatient days per month or the number of admissions per month.^72^ This difference in findings may be related to the setting, which was the Netherlands, whereas all of the studies finding a significant difference in the review were conducted in the United States. None of the studies of assertive community treatment that were excluded from this review (Appendix C) were excluded solely because they reported hospitalization as an outcome.

### Cognitive Adaptation Training Versus Usual Care

#### Key Points

- Evidence from three RCTs of cognitive adaptation training was insufficient due to the limited number of studies and participants.

#### Detailed Synthesis

We identified three RCTs (in four publications) comparing cognitive adaptive training with usual care (Appendix Table E-5).^73–76^ Due to the limited number of studies and participants, we were not able to reliably rate the SOE for this intervention. However, among the three trials, all found that cognitive adaptation training led to greater improvements in function (based on various scale measures) relative to usual care, and one trial found cognitive adaptation training reduced risk of relapse.

### Cognitive Behavioral Therapy Versus Usual Care

#### Key Points

- Three good-quality systematic reviews (9 to 50 trials each; N=895 to 3,947) and five RCTs (N=66 to 422) provided evidence for cognitive behavioral therapy (CBT). Most trials were designed to assess the effect of CBT on symptoms.
- CBT resulted in consistent improved short-term global function based on GAF and other measures, compared with usual care. Differences were not seen in long-term followup (>1 year; seven RCTs) (SOE: moderate and low, respectively).
- Social and occupational function was better with CBT than usual care in trials of ≤6 months duration (three trials; MD on SOFAS 9.11; 95% CI 6.31 to 11.91); evidence on longer-term effects was inconsistent (SOE: low).
- CBT improved quality of life more than usual care in the short term (12 to 24 weeks followup) based on two trials. Differences were not seen with longer followup (18 to 24 months; two trials) (SOE: low).
- CBT had a greater effect than usual care on overall core illness symptoms based on one good-quality systematic review of 34 trials (SMD −0.33, 95% CI −0.47 to −0.19) (SOE: moderate).
- Based on two systematic reviews, there is no meaningful difference in negative symptom improvement with CBT compared with usual care (SOE: low).

#### Detailed Synthesis

##### Description of Included Studies

We identified three good-quality systematic reviews^77–79^ comparing CBT with usual care (Appendix Tables E-6 and F-3). The systematic reviews included nine to 50 RCTs each (N=895 to 3,947) and followup among the included studies ranged widely from 8 weeks to 5 years. Studies of both individual and group CBT were included and combined in all three reviews, though one review conducted separate analyses for individual and group CBT.^79^ In all three reviews, the majority of included studies were focused on the use of CBT to control positive symptoms and were no necessarily designed to address other outcomes. Control groups among the trials included in the reviews varied. In addition to usual care, other controls included waitlists and nonactive interventions such as befriending and psychosocial interventions designed to control for the nonspecific effects of psychotherapy. Patient demographics were not well reported in the reviews. Participants in the included studies ranged from 18 to 65 years in one review^78^ and 22 to 40 years in another. Duration of illness also varied, from 6 months to 30 years across all studies. The proportion of female participants also varied widely, from 8 to 67 percent. Two reviews^77,78^ included studies conducted in people with schizophrenia, schizoaffective disorder and/or psychosis, while the third included studies conducted exclusively in people with schizophrenia.^79^ Though two of the reviews were recently published,^77,79^ the third, a Cochrane review, was last updated in 2010.^78^

The three systematic reviews were all rated good quality, however, they have some important limitations regarding applicability to our review. Presumably all three reviews included some inpatient studies, though this was only reported in one of the reviews, which included 11 (of 30) studies that enrolled exclusively inpatients or mixed inpatient and outpatient populations.^79^ The reviews all noted that there was considerable variability among the CBT interventions, and the specific methods and timing of treatment delivery were not always clearly described. Finally, studies included in these reviews utilized a wide range of outcome measures and scales, making meaningful synthesis and judgment regarding clinical applicability challenging.

Literature searches identified five additional RCTs not included in the systematic reviews (Appendix Table E-7).^76,80–83^ Searches identified one trial^95^ of family-based CBT, which is included in the Family Interventions section. The number of patients enrolled in these trials ranged from 66 to 422. Mean age ranged from 30 to 47 years, and the proportion of female patients ranged from 14 to 54 percent. In four trials reporting race, white patients predominated in two trials, while blacks were the majority in the one and Hispanics were the majority in the other.^76,80–82^ Baseline symptom severity varied among the trials based on study inclusion criteria and baseline measures. Three trials enrolled patients with persistent and ongoing symptoms and/or risk of relapse.^76,80,82^ Baseline symptom scores (total PANSS) were 76 and 82 in two trials,^80,81^ approximately corresponding to moderate illness.^273^ At baseline, patients ranged from minimal to serious functional impairment, based on three trials using various measures.^76,80,82^ The mean duration of illness, reported in three trials, ranged from 15 to 20 years in two trials,^81,83^ while a third study reported time elapsed since first contact with services of ≥10 years for about half of the participants.^80^

As with RCTs included in the above systematic reviews, the additional RCTs that met our inclusion criteria varied with regard to modality (group vs. individual), duration (brief vs. longer-term), and treatment target (e.g., role functioning, symptoms, and medication adherence). Studies were inconsistent in reporting therapist qualifications to provide CBT and few addressed fidelity. In four trials, CBT was delivered in individual sessions,^76,80,82,83^ and one trial^81^ used a combination of individual and group CBT as part of a manualized intervention targeting occupational functioning. Both brief and longer-term CBT interventions were included, with duration of CBT ranging from 8 weeks to 9 months. Four trials included post-treatment followup ranging from 4 to 19 months; total followup in these studies ranged from 6 to 24 months.^76,80,82^ One trial was rated good quality^80^ and the remaining four were rated fair quality (Appendix Table F-4).^76,81–83^ Methodological limitations in the fair-quality trials included unclear group allocation concealment and high attrition rates.

As the two more recent systematic reviews^77,79^ only assessed the effect of CBT on total and/or negative symptoms, we reviewed the included studies of both reviews for reporting of other outcomes of interest. Based on this review, we identified seven additional RCTs reporting function, relapse, and/or quality of life.^93,274–279^ We acknowledge that many of these studies were not specifically designed to assess these outcome measures, but we included evidence on these secondary outcomes when reported. Study characteristics, symptom outcomes and risk of bias assessments are presented in the existing good-quality systematic reviews, and we abstracted additional information only on relevant outcomes.

##### Findings

###### Global Function

###### Short Term

The effects of CBT on short-term (≤6 months since CBT initiation) function was reported in four RCTs^83,274,278,279^ and one systematic review^78^ that included two RCTs^280,281^ reporting functional outcomes (Table 9). Results from the single study that focused on global function found a higher proportion of CBT patients had normal functioning after 6 months treatment versus usual care patients (28% vs. 14%, RR 2.21, 95% CI 1.25 to 3.93).^279^

Table 9 Functional outcomes in randomized controlled trials of cognitive behavioral therapy versus usual care

Timing of Assessment | Outcome | Author, Year | Study Characteristics Intervention/Control CBT Focus/Primary Outcome Total N Duration of Treatment Duration of Followup | CBT Versus Usual Care Results | CBT Versus Usual Care Effect
Short Term (≤6 months) | Global Function | van der Gaag 2011^279^ | CBT vs. usual care Global function N=216 Treatment: 6 months Followup: 18 months | [underlined: 6-month outcomes] Participants with normal functioning; 28% (31/109) vs. 14% (14/97); RR 2.21 (95% CI 1.25 to 3.93) | Favors CBT
Short Term (≤6 months) | Global Function | Barrowclough 2006^274^ | Group CBT vs. usual care Positive symptoms N=113 Treatment: 6 months Followup: 12 months | [underlined: 6-month outcomes] GAF – Disability mean score (N=54 vs. 45): 38.11 vs. 39.98; mean difference −1.87 (95% CI −5.47 to 1.73) | No difference
Short Term (≤6 months) | Global Function | Lincoln 2012^278^ | CBT vs. waitlist Positive symptoms N=80 Treatment: 4 months Followup: 4 months | GAF mean score: 54.5 vs. 47.0; mean difference 7.50 (95% CI 1.80 to 13.20) | Favors CBT
Short Term (≤6 months) | Global and Social/Occupational Function | Zimmer 2007^83^ | Integrated psychological CBT vs. usual care Social function N=66 Treatment: 12 weeks Followup: 12 weeks | GAF mean score: 39.50 vs. 33.81; mean difference 5.69 (95% CI 2.05 to 10.97) SOFAS mean score: 43.25 vs. 34.14; mean difference 9.11 (95% CI 6.31 to 11.91) SAS mean score: 1.86 vs. 2.27; p=0.04 | All scales favor CBT
Medium Term (6–12 months) | Global Function | Barrowclough 2006^274^ | Group CBT vs. usual care Positive symptoms N=113 Treatment: 6 months Followup: 12 months | [underlined: 12-month outcomes] GAF – Disability mean score (N=52 vs. 46): 39.04 vs. 40.74; mean difference −1.70 (95% CI −6.00 to 2.60) | No difference
Medium Term (6–12 months) | Social/Occupational Function | Garety 2008^93^ | CBT vs. usual care Relapse N=273 Treatment: 12 months Followup: 24 months | [underlined: 12-month outcomes] SOFAS, treatment effect: 2.77 (95% CI −1.02 to 6.55) | No difference
Medium Term (6–12 months) | Occupational function | Lysaker 2009^81^ | Indianapolis Vocational Intervention Program (group and individual sessions) vs. social support Employment N=100 Treatment: 26 weeks Followup: 26 weeks | Mean total hours worked: 360.86 vs. 228.82; p<0.01 Mean number of weeks at least 1 hour worked: 18.64 vs. 14.46; p<0.05 Mean WBI: 113.34 vs. 105.43; p<0.05 | Favors CBT
Medium Term (6–12 months) | Basic Living Skills | Granholm 2005^275^ | CBT + social skills training vs. usual care Social function N=76 Treatment: 6 months Followup: 6 months | ILSS marginal mean score: 0.72 vs. 0.67; p<0.05 | ILSS: favors CBT
Long Term (>1 year) | Global Function | Grant 2012^276^ | CBT vs. usual care Global function N=60 Treatment: 18 months Followup: 18 months | GAS adjusted mean score 58.3 vs. 47.9; p=0.03 | Favors CBT
Long Term (>1 year) | Global Function | van der Gaag 2011^279^ | CBT vs. usual care Global function N=216 Treatment: 6 months Followup: 18 months | [underlined: 18-month outcomes] Participants with normal functioning (based on SFS score 95% of normal population); 38% (39/109) vs. 26% (25/97); RR 1.39 (95% CI 0.79 to 1.27) | No difference
Long Term (>1 year) | Global Function | Velligan 2015b^76^ | CBT vs. usual care Positive symptoms and global function N=85 Treatment: 9 months Followup: 15 months | Normatively reported a nonsignificant treatment effect on function with CBT | No difference
Long Term (>1 year) | Social/Occupational Function | Garety 2008^93^ | CBT vs. usual care Relapse and positive function N=273 Treatment: 12 months Followup: 24 months | [underlined: 24-month outcomes] SOFAS, treatment effect: 2.42 (95% CI −1.42 to 6.26) | No difference
Long Term (>1 year) | Occupational function | Malik 2009 ^82^ | Brief CBT vs. usual care Relapse N=422 Treatment: 5 months Followup: 2 years | Proportion of patients with occupational recovery: 10% (21/205) vs. 14% (17/125); RR 0.75 (95% CI 0.41 to 1.37) | No difference

CBT = cognitive behavioral therapy; CI = confidence interval; GAF = Global Assessment of Functioning; GAS = Global Assessment Scale; ILSS = Independent Living Skills Survey; MCID = minimally clinical important difference; NS = not significant; RR = relative risk; SFS = Social Functioning Scale; SOFAS = Social and Occupational Functioning Assessment Scale; WBI = Work Behavior Inventory

In total, six trials reported a common measure of global function (GAF score), that when pooled found delivery of CBT resulted in significantly improved function regardless of CBT focus or treatment modality (MD 5.35, 95% CI 1.05 to 9.65, I^2^=77%) (Appendix G-13).^83,274,278,280,281^ The single study of group CBT (focused on positive symptoms) is also the only study that did not find a positive effect of CBT on short-term function.^274^ Removing this study from the pooled analysis resulted in a pooled MD of 6.62 (95% CI 4.47 to 8.78), and eliminated statistical heterogeneity (I^2^=0%). This SOE is moderate.

###### Medium Term

The effect of CBT on medium term function (>6 months to 1 year since CBT initiation) was reported in one RCT of group CBT versus usual care focused on positive symptoms, reporting no difference between CBT and usual care in Global Assessment Scale (GAS) scores (Table 9).^274^ However, it should be noted that this trial evaluated the effect of a group-delivered CBT primarily intended to target positive symptoms of psychosis with functioning assessed as a secondary outcome. This SOE is insufficient to draw conclusions.

###### Long Term

The single trial designed to assess long-term global function reported better adjusted mean GAS scores in the CBT group after 18 months treatment (58.3 vs. 47.9; p=0.03; Table 9).^276^ Patients enrolled in this study had chronic schizophrenia (mean duration of illness was >15 years) and were low-functioning at baseline. Two other trials not specifically focused on function reported no significant difference between CBT and usual care at 6-months and 1-year post-treatment followup.^76,279^ A systematic review pooled three RCTs and found no statistically significant difference in GAF between CBT and usual care (MD 4.20; 95% CI −0.63 to 9.03) (Appendix Table E-6).^78^

###### Social and Occupational Function

###### Short Term

The effects of CBT on short-term (≤6 months since CBT initiation) social and/or occupational function were reported in two RCTs^83,282^ (Table 9). Improvement in function was the CBT focus in one of the trials, which found significant improvement GAF, SFS and SOFAS.^83^ Significant improvement in SOFAS was also found when results from both trials were pooled (MD 9.11; 95% CI 6.31 to 11.91; Appendix G-13). One other trial found a significantly higher proportion of study participants in the CBT group had normal function, based on an SFS score within 95 percent of a normal population, when compared with usual care (RR 2.21; 95% CI 1.25 to 3.93).^279^ This SOE is low.

###### Medium Term

A trial of 6 months of vocational-focused CBT (both group and individual sessions) found a significant effect favoring CBT for hours worked and Work Behavior Inventory (WBI) score.^81^ This evidence is insufficient to draw conclusions due to lack of corroborating evidence. There was no clear effect of CBT on medium term social and combined social and/or occupational function (>6 months to 1 year since CBT initiation) based on one additional RCT (Table 9).^93^ Neither trial identified functional improvement as the primary outcome. In one of the trials, SOFAS scores were assessed at the conclusion of 12–20 sessions over 9 months of individual CBT aimed at preventing relapse, finding no difference between CBT and usual care groups.^93^ This SOE is low.

###### Long Term

Three trials^78,82,279^ with long-term post-treatment followup (9 to 18 months after treatment cessation) did not find sustained benefits in social and/or occupational function, though none of these studies were designed to assess functional outcomes and one study ^279^ used a novel cotherapy approach to CBT (Table 9; Appendix Table E-6). This evidence is low strength.

###### Basic Living Skills

A single trial reported the effect of CBT on measures of basic living skills after 6 months treatment and followup, found improvement in basic living skills, based on the Independent Living Skills Survey (ILSS), (Table 9).^275^ This evidence is insufficient to draw conclusions.

###### Overall Findings on Functional Outcomes

Although many trials reported functional outcomes, few were specifically designed to assess measures of function as a primary outcome (Table 9). Short-term, individual CBT (treatment ≤6 months) consistently resulted in greater functional improvements versus usual care, even if function was not the primary focus of CBT. Studies that employed CBT targeted at improving functioning consistently led to functional improvements. Longer-term effects of CBT focused on functioning were less consistent with CBT focused on other outcomes (e.g., positive symptoms) or with lengthy post-treatment followup, suggesting that CBT was more effective for primary treatment targets than other targets of interest.

Evidence of differences between individual and group CBT and functional outcomes was limited. Only one trial utilized a group CBT approach (directed at improving positive symptoms) finding no difference between CBT and usual care in functional outcomes.^274^ One trial that included both individual and group CBT focused on vocational outcomes found significantly better outcomes with CBT.^81^

###### Health-Related Quality of Life

Quality of life is challenging to assess in people with schizophrenia, and the reliability of such assessments is tied to clinical factors, including the patient’s level of insight.^283^ Only one small study (N=66) included in this review assessed quality of life as a primary outcome,^83^ while three other trials (N=66 to 273) reported on the effect of CBT on quality of life as a tertiary outcome (Appendix Table E-7).^80,93,279^ All four trials employed an individual CBT approach. Patient populations were similar across the four trials, but duration of treatment ranged from 8 weeks to 1 year. Quality of life was assessed using different scales, and measured at time points ranging from the cessation of treatment to 1 year after treatment cessation. CBT was associated with better quality of life than usual care in two trials^80,83^ with short-term followup (12 weeks and 24 weeks), including the single trial designed to assess quality of life.^83^ The two trials with quality of life assessments up to 1 year after cessation of treatment (total followup 18 and 24 months), found no difference between CBT and usual care.^93,279^ This evidence is low strength.

###### Reduction in Self-Harm

No studies reviewed evaluated the effect of CBT on self-harm as a primary outcome. A single trial, included in one systematic review, reported incidental suicide, finding no difference in risk between CBT and nonactive psychological therapies (3% [2/78] versus 4% [3/79]; RR 0.68, 95% CI 0.12 to 3.93).^284^ An additional trial, not included in any of the systematic reviews, found no difference between CBT and usual care in suicide attempts (3% [2/73] versus 5% [4/77]; RR 0.53, 95% CI 0.12 to 2.79) or serious violent incidents (3% [2/73] versus 1% [1/77]; RR 2.11, 95% CI 0.20 to 23).^80^ This evidence is insufficient to draw conclusions.

###### Improvement in Core Illness Symptoms

###### Overall Symptoms

A recent systematic review of 34 RCTs found CBT more effective than usual care at improving overall symptoms (SMD −0.33, 95% CI −0.47 to −0.19; I^2^=68% [a negative estimate favors CBT]; Appendix Table E-6) based on a number of scales (PANSS, BPRS, Comprehensive Psychopathology Rating Scale [CPRS] and the Hopkins Psychiatric Rating Scale).^77^ As noted above, the majority of the included studies in this review were designed to address positive symptoms. The review combined studies of both individual and group CBT, and brief and longer duration CBT, but did not stratify results according to treatment modality or duration. Limiting the analysis to 20 trials in which outcome assessors were blinded to intervention group greatly reduced the effect size (−0.15). Although it remained significant (95% CI −0.27 to −0.03), it is unclear that this difference is clinically meaningful. One trial not included in the systematic review found similar improvements in total PANSS with CBT (Appendix Table E-7).^80^ This evidence is moderate.

###### Negative Symptoms

The effect of CBT on negative symptoms, based on PANSS-negative subscale, BPRS-negative subscale and SANS scales, was mixed based on two reviews. Study inclusion criteria for the two reviews differed slightly in that the Jauhar review included any study of CBT that reported symptom outcomes (positive, negative or overall) regardless of the CBT focus and the Velthorst review only included studies of CBT specifically targeted at either positive or negative symptom reduction. It should be noted that, of the 30 RCTs included in the Velthorst review, only two studies identified negative symptoms as the primary treatment target. The Jauhar review found a small, marginally significant effect in favor of CBT (34 trials; SMD −0.13, 95% CI −0.25 to −0.01; I^2^=48% [a negative estimate favors CBT]),^77^ while the Velthorst review found no difference between CBT and usual care based on 28 trials (SMD 0.09, 95% CI −0.03 to 0.21; I^2^=63% [a positive estimate favors CBT]).^79^ Pooled results from the two trials that specifically targeted negative symptoms as a primary outcome resulted in an improved (but not significant) effect size favoring CBT: SMD 0.16, 95% CI −0.10 to 0.41. Estimates from this review were consistent when trials were limited to those that enrolled outpatients (10 trials; SMD 0.12, 95% CI −0.08 to 0.31). Estimates were also similar when stratified according to short-term (3–6 months after treatment; 13 trials; SMD 0.21, 95% CI −0.05 to 0.46) and long-term (9–12 months after treatment; 10 trials; SMD 0.01, 95% CI −0.02 to 0.18) treatment effects. The same review found individual (SMD 0.21, 95% CI 0.05 to 0.37) more effective than group CBT (SMD −0.17, 95% CI −0.44 to 0.09.) Trials published more recently (since 2009) and higher-quality trials reported smaller effect sizes (Appendix Table E-6).

Because the difference found in the Jauhar review was so small and the Velthorst review found consistent results with multiple sensitivity analyses, we find low strength evidence for negative symptom improvement.

###### Treatment Discontinuation

In addition to one outpatient study included in the systematic reviews,^285^ we identified 11 other RCTs not included in the systematic review reporting on the proportion of patients remaining in treatment.^76,80,82,83,93,274–279^ Treatment duration among the trials ranged from 8 weeks to 18 months. When pooled (Appendix G-14), there was no difference between CBT and usual care (86% vs. 82%; RR 1.02, 95% CI 0.95 to 1.10). The risk of discontinuing treatment was not affected by the intended duration of treatment; ≤6 months or >6 months did not affect the risk estimates (RR 1.07, 95% CI 0.97 to 1.17 versus RR 0.98, 95% CI 0.88 to 1.09). This was low strength evidence. One other study reported that the mean number of sessions attended was higher for employment-focused CBT compared with general social support (17.34 vs. 12.78 sessions; p<0.05).^81^

###### Relapse

We identified five RCTs (in six publications) reporting relapse rates in patients receiving CBT or usual care in the outpatient setting.^82,93,274,277,286,287^ One of these trials ^286,287^ had been included in a good-quality systematic review that pooled data on inpatients with data on outpatients.^78^ In these five trials (N=1,013) duration of treatment ranged widely, from 10 weeks to 2 years. In all of the trials, relapse prevention was a focus of the CBT intervention. Relapse was variably defined among these trials, though all but one included hospitalization as a criterion for relapse (Appendix Table E-7). When results from these five trials were pooled, there was no difference in relapse rate (29% vs. 30%; RR 0.93, 95% CI 0.61 to 1.42), though heterogeneity was high (I^2^=73%; Appendix G-15). When the analysis was limited to three trials^82,277,286,287^ that used only hospitalization as criteria for defining relapse, there was a significant effect in favor of CBT and statistical heterogeneity was eliminated (RR 0.70, 95% CI 0.54 to 0.91; I^2^=0%).

In subgroup of two trials that used criteria related to increasing symptoms and/or hospitalization as criteria for relapse, neither found a significant difference between CBT and usual care.^93,274^ Due to the inconsistency of these risk estimates, this evidence is insufficient to draw conclusions. As with other bodies of evidence in this report, the reasons likely lie in the variability in definition of relapse.

###### Harms

Harms of treatment were infrequently reported in trials of CBT; only one trial identified harms of treatment a priori as an outcome of interest.^80^ This trial found no difference between CBT and usual care in incidence of mortality (no deaths in either group). This evidence is insufficient to draw conclusions.

### Cognitive Remediation/Training Versus Usual Care

#### Key Points

- Two good-quality systematic reviews and one good- and three fair-quality trials (N=56 to 156) provided evidence for cognitive remediation. The reviews stratified results for studies with usual care comparators.
- Compared with usual care, cognitive remediation resulted in a small positive effect on social, occupational, living situation, and global function, based six RCTs (effect sizes ranged from 0.16 to 0.40) (SOE: low).
- Cognitive remediation resulted in small improvements in core illness symptoms, based on two trials (N=153, SMD −0.62 (95% CI −1.01 to −0.24) (SOE: low).
- Negative symptoms were significantly improved with cognitive remediation compared to usual care based on a good-quality systematic review of 18 RCTs (SOE: moderate).

#### Detailed Synthesis

##### Description of Included Studies

Studies of cognitive remediation focus on improving cognitive function. Two good-quality systematic reviews of 39 (Wykes 2011, N=2,104) and 18 (Cella 2017, N=781) trials reported on the effect of cognitive remediation versus active or passive (usual care) controls, with subgroup analyses of studies with usual care comparisons (Appendix Tables E-8 and F-3).^84,85^ Studies were included based on cognitive remediation as defined by the Cognitive Remediation Experts Workshop^288^ or based on standard cognitive remediation principles. Inclusion criteria in the Wykes review^84^ required that at least 70 percent of the study population had a diagnosis of schizophrenia, while the Cella review used a 75 percent threshold.^85^

In the Wykes review, 19 studies were conducted in inpatient, 18 in outpatient, and 2 in mixed in and outpatient populations. Mean age across all studies was 36 years (range 18–49; one other study enrolled adolescents); men made up 67 percent of the study populations. Baseline symptom severity, reported in 26 trials, was characterized as mild to moderate. The review included trials that reported cognitive (outside the scope of our review) or functional outcomes, including 31 studies of individual and nine studies of group cognitive remediation. The review’s inclusion criteria required a usual care control group, although an active comparator was also included in most studies. Separate analyses according to control group were conducted for measures of function. Cognitive remediation was delivered using drill and practice methods in 21 trials, and drill plus strategy in 19 trials. The mean number of sessions per week was 2.2 (range 0.6 to five), for a mean total of 32 hours (range four to 130) over 17 weeks (range 2 to 104 weeks). Study quality among the included studies ranged from poor to fair. The review noted that inadequate method of randomization and allocation concealment, and lack of treatment fidelity were frequent contributors to diminished study quality.

The Cella review provided few details about the 18 included studies comparing cognitive remediation with usual care.^85^ The mean age across all studies was 35 years, and men made up 71 percent of the population. Baseline symptom severity, treatment setting (inpatient or outpatient), and description of cognitive remediation delivery were not reported. Seven studies had treatment duration ≥12 weeks. Negative symptoms were primarily assessed using the PANSS negative subscale, although BPRS and SANS were also used. As with the Wykes review, studies with both passive (usual care) and active control groups were included in the review, but sub-group analyses were conducted according to control group. The studies were judged to have medium to high risk of bias.

We identified four other RCTs (in five publications) of cognitive remediation not included in one or both systematic reviews above (Appendix Table E-9).^86–90^ The trials enrolled between 56 and 156 participants, mean age ranged from 31 to 41 years and <60 percent of participants were female across all studies. Whites comprised 60 percent of the population in the only study reporting race.^89^ Three of the trials required a diagnosis of schizophrenia for study inclusion,^86–88,90^ and in the fourth trial^89^ the vast majority (97%) of the study population had a diagnosis of schizophrenia or schizoaffective disorder. Duration of illness ranged from 10 to 18 years. All four trials provided biweekly, group-based cognitive remediation; duration of treatment ranged from 4 to 6 months. The trials used both computer-based and manual cognitive remediation, often in combination. One study was rated good quality,^86,90^ and the other three were rated fair quality due to unclear method of randomization or allocation concealment and lack of intention to treat analysis (Appendix Table F-4).

##### Findings

###### Function

When limiting analyses to three trials that used a passive control group (usual care), the Wykes systematic review of cognitive remediation found a small positive effect that was not statistically significant (effect size 0.16, 95% CI −0.16 to 0.49). This lack of significance may be due to the paucity of evidence rather than a true reflection of the effect of cognitive remediation on function. For context, when the analysis included 19 trials with either usual care or active control groups (N=1,036) a larger, significant, effect size was found (effect size 0.42; 95% CI 0.21 to 0.62; Appendix Table E-8), and the effect was sustained in 12 trials that provided post-treatment followup (6 to 24 months; effect size 0.37; 95% CI 0.11 to 0.66).^84^ These analyses combined 16 different measures of social, occupational, living situation and global function, and used the effect size measure to standardize across the assessments of function.

Results from three other RCTs, not included in the systematic review, also reported on functional outcomes.^87–89^ The trials used different measures of function at different timepoints, but all found delivery of cognitive remediation improved function relative to usual care, although results were not always significant (Appendix Table E-9). For example, one study found significantly better global function after 15 weeks of cognitive remediation therapy versus usual care based on GAF score (SMD 0.56; 95% CI 0.34 to 0.88),^88^ while the difference between groups was similar in magnitude, though not significant, in another study measuring function and disability with the Life Skills Profile (LSP) after 16 weeks of treatment (SMD 0.41; 95% CI −0.10 to 0.91).^87^ Combined, this evidence is low strength.

###### Health-Related Quality of Life

One study reported on the effect of cognitive remediation on quality of life (Appendix Table E-9).^89^ There was no difference in Subjective Quality of Life (QOLI) scores after 12 weeks of treatment (effect estimate, adjusted for group and time 0.52; p=0.17), but QOLI score was significantly better in the cognitive remediation group at 3-months post-treatment followup (effect estimate, adjusted for group and time 1.15; p=0.002). This evidence is insufficient due to study limitations, lack of confirmatory trials, and imprecision.

###### Improvement in Core Illness Symptoms

###### Overall Symptoms

Results were mixed in two RCTs (N=153), not included in either of the systematic reviews, reporting total symptom scores (Appendix Table E-9). In one trial comparing 6 months of cognitive remediation to usual care, improvements in total PANSS were greater in the cognitive remediation group at the end of treatment (SMD −0.90; 95% CI −1.50 to −0.31) and at 1-year followup (SMD −0.68; 95% CI −1.26 to −0.09).^86^ The other study did not find the difference to be statistically significant at 16 (SMD −0.42; 95% CI −0.92 to 0.09) and 40 weeks (SMD −0.04; 95% CI −0.54 to 0.46).^87^ Pooling these provides a combined point SMD of −0.62 (95% CI-1.01 to −0.24).

The Wykes systematic review combined a wide range of symptom measures, including the Scale for Assessment of Positive Symptoms (SAPS), SANS, PANSS and BPRS, among others (Appendix Table E-8). The review found that cognitive remediation improved symptoms, based on 20 trials (effect size 0.18; 95% CI 0.03 to 0.32).^84^ Symptom improvement was not sustained following treatment removal (8 RCTs, effect size 0.17, 95% CI −0.03 to 0.48). The review did not report results for the subgroup of studies utilizing a passive control group, but the effect sizes for the four studies reporting symptom effects versus usual care ranged from 0.05 to 0.45. Combined, this evidence is low strength.

###### Negative Symptoms

The Cella systematic review (18 RCTs; N=781) conducted a network meta-analysis on the effect of cognitive remediation versus usual care on negative symptoms.^85^ The review found cognitive remediation led to significant improvement in negative symptoms, with an effect size of −0.36 (95% CI −0.52 to −0.20; a negative effect size favors cognitive remediation). These results were consistent when compared to all control interventions (usual care alone and usual care plus an active treatment, excluding three outliers; effect size −0.30, 95% CI −0.36 to −0.22) and at post-treatment followup (effect size −0.36, 95% CI −0.51 to −0.21). One other RCT not included in the systematic review and focused on executive function and metacognition, also found negative symptoms, based on PANSS-negative scores, were significantly improved after 4 months treatment (effect size 0.36, 95% CI 0.01 to 0.70).^87^ There was no difference between groups at 6 month post-treatment followup.

###### Treatment Discontinuation

Treatment discontinuation was not different between cognitive remediation and usual care groups in two RCTs not included in the systematic review (Appendix Table E-9). Relative risk was 1.01 (95% CI 0.91 to 1.12) in one trial, and the other trial normatively reported no difference between groups in the proportion of patients able to maintain treatment (p=0.08).^87,88^ The Cella systematic review found no difference between cognitive remediation and usual care in the proportion of patients discontinuing treatment (21 trials; RR 0.82, 95% CI 0.67 to 1.01; Appendix Table E-8), but did not conduct subgroup analyses of only trials comparing to usual care.^85^ This was moderate strength evidence.

### Family Interventions Versus Usual Care

#### Key Points

- Trials of family interventions differ in type of interventions included, methods of intervention delivery, number of treatment sessions, duration of intervention, level of patient participation, and target of the intervention. Most family interventions are targeted at reducing relapse.
- One fair-quality systematic review provided evidence from 27 trials (N=2,297); six trials not in the systematic review were also included (N=562).
- Family interventions did not affect social function, including employment and housing situation, more than usual care at 1 year (SOE: low).
- Suicide rates were similar in family intervention participants and those who received usual care, but events were few (SOE: low).
- Improvement in core illness symptoms was found with family intervention compared with usual care (four RCTs, N=223, SMD −0.46, 95% CI −0.73 to −0.20) compared with usual care (SOE: low).
- Family interventions resulted in significantly lower relapse rates than usual care when measured at:
  ○ 0 to 6 months (three RCTs; N=244, 23% vs. 37%, RR 0.62, 95% CI 0.41 to 0.92)
  ○ 7–12 months (19 RCTs; N=1118, 30% vs. 44%, RR 0.67; 95% CI 0.54 to 0.83)
  ○ 13–24 months (nine RCTs; N=517; 49% vs. 61%; RR 0.75, 95% CI 0.58 to 0.99)
  ○ 5 years post-treatment (two RCTs; N=140,78% vs. 94%, RR 0.82; 95% CI 0.72 to 0.94)
  ○ Evidence was not adequate to show a difference for 25 to 36 months (SOE: moderate for 7–12 months, low for all others)
  ○ Evidence suggests that relapse is lower with >10 treatment sessions.

#### Detailed Synthesis

##### Description of Included Studies

One fair-quality Cochrane systematic review included 53 trials that enrolled patients with schizophrenia and/or schizoaffective disorder (Appendix Table E-10).^91^ Approximately half of the included trials were conducted in China. As applicability to United States populations was a concern, we excluded these studies and, where necessary, performed our own analyses using the remaining 27 studies (N=2,297). We also included six additional trials (in eight publications, N=562) that were not included in the systematic review.^92–97,289,290^ and pooled results where appropriate. Including all evidence, participant age ranged from 15 to 65 years, and the proportion of men to women was 66.5 to 33.5 percent, although six trials did not report gender distribution. Length of treatment ranged from 6 weeks to 3 years and consisted of any family-oriented psychosocial intervention that required at least five sessions compared with usual care. One trial met all quality criteria.^93^ Relatively few trials reported methods of randomization and allocation concealment or reported blinded outcome assessors. Study attrition and reasons for attrition were also infrequently reported. Information on harms was rare. Most studies were small in size with fewer than 100 participants.

In addition to duration of treatment, trials of family intervention are heterogeneous in what is actually included in the family intervention (Appendix Tables E-11 and E-12). In some instances psychoeducation is included but may consist of one or two brief education sessions or several entire days. Psychoeducation may be the sole part of the intervention or, more frequently, part of a package that may include motivational interviewing, behavioral family therapy, support groups, communication training, stress management, goal setting, and development of social networks. Families may experience the intervention as a single family or in multiple family groups. The patient may be present for some sessions and not others. The target of the intervention may be to prevent relapse (most often) or hospitalization, promote treatment or medication adherence, or improve social or global function, for example. In pooled analyses of trials with relapse as an outcome, we have stratified these trials by number of treatment sessions, duration of treatment, and an estimate of the degree psychoeducation is included in the family intervention, in order to explore the degree to which each factor may influence patient relapse.

##### Findings

###### Function

###### Social Functioning

One small study (N=69) reported patient change scores from baseline on the SFS.^95^ This trial provided 6 months of treatment and assessed social functioning at 6 months and 12 months. Family intervention included motivational interviewing, individual cognitive behavior therapy, along with a family intervention based on carer’s needs. This trial provide insufficient evidence of no difference in social function between family intervention and usual care at either 12 or 24 months (p>0.05).

###### Unemployment

Four trials provided low-strength evidence of no difference in unemployment with family interventions compared with usual care after 6–12 months of followup (N=230; 75% vs. 66%; RR 1.09; 95% CI 0.91 to 1.29, I^2^=0%; Appendix G-16).^91^ Although unemployment rates at 2 years (N=51; 69% vs. 52%; RR 1.33; 95% CI 0.84 to 2.10) and at 3 years of followup (N=99; 82% vs. 69%; RR 1.19; 95% CI 0.92 to 1.55) were also not different between family intervention and usual care, the evidence is insufficient to draw conclusions due to methodological limitations, lack of confirmatory trials, and imprecision.

###### Unable To Live Independently

Based on three RCTs, there was low-strength evidence of no differences between family interventions and usual care in the inability to live independently at 1 year (N=164; 57% vs. 63%; RR 0.83; 95% CI 0.66 to 1.03).^91^ A single trial included in the included systematic review reported independent living at 3 years post intervention (N=99; 54% vs. 66%; RR 0.82; 95% CI 0.59 to 1.14), but this evidence is insufficient. On small trial (N=97) reported data from 63 participants (65%) at a 5-year followup of a 15-month intervention and found family intervention associated with living fewer months in an institution for psychiatric patients (10.87 months vs. 21.18 months, p=0.04) compared with usual care.^291^ Evidence at 5 years was considered insufficient from which to draw meaningful conclusions regarding the effect of family intervention in ability to live independently.

###### Health-Related Quality of Life

One study (N=50) reported mean endpoint change in quality of life scores based on the Heinrichs QLS scale (21-item scale, high score=good).^91^ An additional study (N=55) reported that a 9-month family intervention improved overall quality of life based on the EuroQol scale by 7.38 points over treatment as usual at 24 months but this difference was not statistically significant (−7.38, 95% CI −22.07 to 7.31).^93^ Values on the EuroQol were not reported prior to the 24-month followup. Evidence was considered insufficient to draw meaningful conclusions on the effect of family interventions versus usual care on quality of life.

###### Reduction in Self-Harm

There was low-strength evidence, from six trials, of no difference in risk of suicide for participants who received family interventions compared with usual care, but events were few (N=314, 4% vs. 6%, RR 0.85; 95% CI 0.24 to 3.02, I^2^=23%; Appendix G-17).^91^

###### Improvement in Core Illness Symptoms

###### Overall Symptoms

Combining the scores on the BPRS from three trials (N=190).^91,96^ with PANSS scores from one trial^93^ (N=55) provided low strength evidence of improvement in core illness symptoms with family interventions (four RCTs, N=223, SMD −0.46, 95% CI −0.73 to −0.20, I^2^=0%; Appendix G-18).^91,93,96^ The data from one small trial (N=64) could not be pooled with the other trials, but reported a significant improvement with family intervention in an analysis of covariance (p=0.017).^95^

###### Negative Symptoms

Three trials (N=163) ^92,93,96^ also reported scores on the negative subscale of the BPRS, the, PANSS, and the Modified Scale for the Assessment of Negative Symptoms. A pooled analysis found lower risk of negative symptoms with family intervention (SMD −0.38, 95% CI −0.69 to −0.07; Appendix G-19).

###### Treatment Discontinuation

Six trials provided low strength evidence of no difference between family intervention and usual care on leaving the study early between 3 and 6 months (N=504; 13% vs. 14%; RR 0.86; 95% CI 0.51 to 1.45, I^2^=19%; Appendix G-20).^91^ However, between 7 and 12 months participants receiving usual care were more likely to leave the study early when compared with participants receiving a family intervention (13 RCTs; N=953, 24% vs. 26%, RR 0.77; 95% CI 0.64 to 0.93, I^2^=0%; Appendix G-21)^91,93,94,97^ based on low-strength evidence. Results for leaving the study early were not different between 13 months and 2 years (six RCTs, N=362, 22% vs. 27%, RR 0.82, 95% CI 0.57 to 1.16, I^2^=0%),^91^ based on low-strength evidence. Evidence was insufficient to determine the benefit of family therapy compared with usual care on study departures between 25 and 36 months and after 3 years.

###### Relapse

Consistent with the included systematic review,^91^ we considered participants missing data for relapse as having relapsed. Three trials provided low-strength evidence of lower risk of relapse between 0 and 6 months with family interventions compared with usual care, (N=244, 23% vs. 37%, RR 0.62; 95% CI 0.41 to 0.92, I^2^=0%, Appendix G-22).^91,290^ In the trial with a greater number of sessions (11 to 20) relapse rates were slightly lower than in the two trials with a family intervention of 0 to 10 sessions (RR 0.51 vs. RR 0.69).

Nineteen trials (N=1118) provided moderate-strength evidence of lower risk of relapse between 7 and 12 months with family interventions compared with usual care (30% vs. 44%, RR 0.67; 95% CI 0.54 to 0.83; I^2^=44%; Appendix G-23).^91,93,96,97,290^ As above, studies with greater number of sessions (i.e., greater than 10) were more likely to favor family intervention, while duration of the intervention (Appendix G-24) favored trials up to 12 months, and trials including psychoeducation (Appendix G-25) as all or part of the treatment package were slightly less likely to show a treatment effect (RR 0.78; 95% CI 0.60 to 1.02).

The SOE was considered low for relapse rates beyond 12 months. Relapse rates at 13 to 24 months also favored family intervention (nine RCTs; N=517; 49% vs. 61%; RR 0.75, 95% CI 0.58 to 0.99; I^2^=57%; Appendix G-26).^91^ There were no difference in the statistical significance of the treatment effect based on number of sessions within the family intervention or the duration of the intervention (Appendix G-27). Almost all trials included psychoeducation. For 25 to 36 months, there was low-strength evidence of no difference between family intervention and usual care on relapse rates (two RCTs; N=147; 79% vs. 73%; RR 1.05; 95% CI 0.79 to 1.39; I^2^=45%; Appendix G-28).

Two small studies (N=140) provided relapse data at 5 years followup (after 15 months of intervention).^91,289^ Pooled analysis provided low-strength evidence that the benefit of family interventions on the risk of relapse may be retained at 5 years (78% vs. 94%, RR 0.82; 95% CI 0.72 to 0.94, I^2^=0%; Appendix G-29). One small, study (N=63) provided data at 8 years and found no difference in risk of relapse between family intervention and usual care (81% vs. 94%, RR 0.86; 95% CI 0.71 to 1.05).^91^ This evidence at 8 years is insufficient for which to draw conclusions.

###### Harms

One small study (N=51) provided insufficient evidence on measures of family burden to determine whether family interventions reduce family burden when compared with usual care.^91^

There was insufficient evidence of no difference in nonsuicide mortality based on three trials (N=113, 3% vs. 4%, RR 0.96; 95% CI 0.17 to 5.33, I^2^=0%; Appendix G-30).^91^

### Intensive Case Management Versus Usual Care

#### Key Points

- ICM was assessed in one good-quality systematic review (10 trials; N=1,652) and one RCT (N=77).
- ICM was not different to usual care in improvements in social function, based on pooled analysis of three trials (MD 0.46; 95% CI −0.34 to 1.26) (SOE: low).
- There was no difference in rates of imprisonment with ICM versus usual care, based on pooled analysis of five trials (OR 0.90, 95% CI 0.45 to 1.82) (SOE: low).
- ICM did not improve quality of life more than usual care in two trials (SOE: low).
- ICM did not improve core illness symptoms more than usual care, based on pooled analysis of two trials (MD, 0.46; 95% CI −3.67 to 4.60). One subsequent trial also reported no difference in symptoms using a different scale (SOE: low).

#### Detailed Synthesis

##### Description of Included Studies

A good-quality systematic review of 10 trials (N=1,652) assessed ICM compared with usual care (Appendix Tables E-13 and F-3).^98^ Another review that combined evidence for assertive community treatment and ICM was not used, as we considered these to be distinct interventions.^272^ However, all of the studies included in the second review are included here. Included studies enrolled patients with schizophrenia or schizophrenia-like disorders, bipolar disorder, or depression with psychotic features. Mean age of participants enrolled in the studies ranged from 35 to 49 years, 0 to 59 percent were female, and 0 to 91 percent were nonwhite. Included interventions were explicitly described as case management; studies (or arms of studies) of assertive community treatment and home-based care were excluded. Study quality of included trials ranged from fair to good; poor-quality studies were excluded.

We identified one other RCT of ICM published since the systematic review described above (Appendix Tables E-14 and F-4).^99^ The fair-quality study (N=77) enrolled participants with a mean age of 37 years, and the proportion of female participants was 53 percent; race/ethnicity was not reported. The trial enrolled Swedish patients with diagnosed mental illness and serious functional impairment. Patients were followed for 3 years.

##### Findings

###### Function

###### Global and Social Function

The systematic review of ICM found no significant effect on social function, based on pooled analysis of three trials (N=197) (MD0.46, 95% CI −0.34 to 0.1.26; I^2^=48%; Appendix Table E-13).^98^

One trial published since the systematic review also reported on functional outcomes.^99^ Consistent with the findings of the systematic review, the study reported no difference between groups in function assessed using the Strauss Carpenter scale (Appendix Table E-14). The SOE for this comparison is low due to study limitations and imprecision.

###### Encounters With the Legal System

The systematic review reported no significant differences in imprisonment based on five trials (N=757; OR 0.90, 95% CI 0.45 to 1.82; I^2^=0%).^98^ This was low-strength evidence due to study limitations and imprecision.

###### Health-Related Quality of Life

The systematic review of ICM identified two trials reporting quality of life (Appendix Table E-13).^98^ ICM was not associated with differences in quality of life scores on the Quality of Life Scale (MD, 0.09, 95% CI −0.23 to 0.42). One subsequent trial,^99^ which assessed quality of life using the Lancashire Quality of Life Profile, also found no difference between groups in quality of life. This evidence is low strength due to study limitations and imprecision.

###### Improvement in Core Illness Symptoms

The systematic review reported no significant differences between groups in symptoms based on BPRS scores (two trials; N=126; MD, 0.46; 95% CI −3.67 to 4.60).^98^ One subsequent trial assessed symptoms using the Hopkins Symptom Check List and also reported no difference between groups (Appendix Table E-14).^99^ This evidence is low strength due to study limitations and imprecision.

###### Treatment Discontinuation

The systematic review reported significantly less loss to followup with ICM compared to usual care based on seven trials (N=1,210; OR 0.70, 95% CI 0.54 to 0.90; I^2^=36%; Appendix Table E-13).^98^ The addition of data from the single study published since the systematic review did not substantially alter these results (eight trials; N=1,287; OR 0.71, 95% CI 0.54 to 0.95; I^2^=11%; Appendix G-32). This was moderate-strength evidence.

### Illness Self-Management and Recovery Versus Usual Care

#### Key Points

- One fair-quality systematic review provided evidence from 13 trials (N=1,404); one other trial not included in the review provided additional evidence.
- Participants receiving a self-management education intervention were significantly more likely to demonstrate a reduction in severity of symptoms based on the BPRS (five RCTs, WMD −4.19, 95% CI −5.84 to −2.54) (SOE: moderate), but no change in negative symptoms based PANSS – negative subscale (SOE: low).
- Patients receiving more than 10 self-management intervention sessions had a greater reduction in the likelihood of experiencing relapse compared with usual care (OR 0.41; 95% CI 0.21 to 0.79), whereas those receiving 10 or fewer sessions had a smaller, nonsignificant, reduction in the risk of relapse (OR 0.67, 95% CI 0.39 to 1.15) (SOE: low).

#### Detailed Synthesis

##### Description of Included Studies

Illness self-management training programs are designed to improve knowledge, management of symptoms, social and occupational functioning, with a primary goal of reducing the risk of relapse by focusing on medication management, recognizing signs or relapse, and developing a relapse prevention plan and coping skills for persistent symptoms. Given these, the primary target of this intervention is reducing the risk of relapse.

We identified one fair-quality systematic review^100^ that examined the effect of self-management education interventions compared with usual care, which was not clearly defined (Appendix Tables E-15 and F-3). This review included 13 trials (N=1404; range 23 to 125) with three trials from United States populations (N=211). Only three to five trials (N=257 to 534) reported results for each outcome of interest. The proportion of female participants ranged from 27 to 58 percent in 12 trials; one study enrolled exclusively male participants. Mean age ranged from 30 to 40 years. All interventions were delivered in a group setting and the number of intervention sessions ranged from 7 to 48 sessions lasting 45 minutes to 90 minutes each. Duration of followup ranged from the time of treatment cessation to 24 months post-treatment.

We included one other fair-quality RCT comparing a specific illness self-management training program for schizophrenia, the Illness Management and Recovery program compared with usual care.^101^ This Israeli study included 210 people with severe mental illness and measured efficacy using the Coping Efficacy Scale and the Illness Management and Recovery scale. The percentage of participants with schizophrenia was 80 and 89 percent in the intervention and control groups, respectively. Fidelity to the program was measured via the Illness Management and Recovery Fidelity scale after 4 to 5 months and ranged from 2.66 to 4.77 (means) on a scale of 1 to 5. There were no significant differences between groups in any of the sociodemographic variables (Appendix Tables E-16 and F-4).

##### Findings

###### Function

Functional outcomes were reported in 10 RCTs included in the systematic review,^100^ and the single RCT that was published after the review,^101^ but none of the trials used the same method to measure the outcomes. Overall, five trials found benefit with self-management interventions on global, social, and occupational outcomes whereas the other six trials did not. This evidence is insufficient to draw conclusions.

###### Improvement in Core Illness Symptoms

###### Overall Symptoms (BPRS)

The systematic review^100^ reported the effect of self-management education interventions on psychiatric symptoms (Appendix Table E-15). Five trials (N=409) reported mean data for psychiatric symptoms using the BPRS, with meta-analysis of these data demonstrating that participants in the intervention group were significantly more likely to demonstrate a reduction in the severity of symptoms (WMD −4.19, 95% CI −5.84 to −2.54). A measure of statistical heterogeneity was not reported, and it is not clear that a difference of 4.19 points is clinically meaningful. This evidence was moderate strength. A meta-analysis of 3 of 13 trials (N=257) showed a significant reduction in the severity of positive symptoms (WMD −2.12, 95% CI −3.04 to −1.20) as measured by the PANSS, but total scores were not assessed.

###### Negative Symptoms (PANSS-Negative)

The effect of self-management education on negative symptoms, based on PANSS - Negative symptoms subscale, was reported in one systematic review that included three RCTs for this outcome (N=257).^100^ Results demonstrate a significant reduction in severity of negative symptoms reported favoring the intervention group (WMD −4.01, 95% CI −5.23 to −2.79; Appendix Table E-15). This evidence was low strength due to study limitations and imprecision.

###### Relapse

The systematic review included five trials (N=534) that reported outcome data on relapse and stratified the analysis by the number of self-management education sessions (Appendix Table E-15).^100^ Three trials had more than 10 sessions and two trials had less than 10 sessions. Patients receiving more than 10 sessions were 59 percent less likely to experience relapse than those receiving usual care (OR 0.41, 95% CI 0.21 to 0.79) whereas those receiving 10 sessions or less were 33 percent less likely to experience relapse than those receiving usual care (OR 0.67, 95% CI 0.39–1.15). This was low-strength evidence.

###### Other Outcomes

The fair-quality RCT published after the systematic review included the Illness Management and Recovery Scale as the primary outcome measure (Appendix Table E-16).^101^ The scale is a composite scale, measuring personal goals, knowledge of mental illness, involvement with significant others, functioning, symptoms, stress, coping, relapse prevention, hospitalization, medication, and use of drugs and alcohol (range to 5; higher scores better). The intervention resulted in significantly greater improvement on this scale, although the absolute improvements were small (0.18 vs. 0.03; p<0.01). The study also reported the Coping Efficacy Scale, which assesses symptoms, substance use and sleep problems experienced, strategies used to cope, and the patient’s assessment of the efficacy of these strategies, with scores ranging from 1 to 5. On this scale, the intervention also resulted in small but statistically significant improvements compared with usual care (final scores 3.25 versus 3.09; p<0.05). In post hoc analyses, this study found better results with higher intervention fidelity scores.

### Patient Psychoeducation (Individual or Group) Versus Usual Care

#### Key Points

- One good-quality systematic review provided evidence from 10 trials (N=1,125).
- Psychoeducation had a greater effect than usual care on global functional outcomes at 1 year of followup based on one good-quality systematic review of three trials (MD −5.23, 95% CI −8.76 to −1.71) (SOE: low).
- Psychoeducation had a greater effect than usual care on relapse rates (with or without readmission) at 9 to 18 months of followup based on one good-quality systematic review of six trials (RR 0.80, 95% CI 0.70 to 0.92) (SOE: moderate).

#### Detailed Synthesis

##### Description of Included Studies

We identified one good-quality systematic review^102^ comparing formalized psychoeducation to usual care (Appendix Tables E-17 and F-3). This review included 10 RCTs (total N=1,125), eight of which included stabilized outpatients, with duration of followup as long as 5 years. Subjects among the included studies had various diagnoses, including schizophrenia, schizophreniform disorder, schizoaffective disorder, and schizotypal disorder (with inclusion of individuals with multiple diagnoses). Studies were conducted primarily in North America and northern Europe (with 15% of subjects from the United States). Psychoeducational interventions were diverse, including variations of brief, usual length, individual, and group techniques. Usual care was also diversely defined, including elements of medication management, psychosocial rehabilitation, and supportive psychotherapy.

Psychoeducation itself is related to the informed consent process, which is an integral part of usual management of any illness. This could be hypothesized to account for some difficulty in observing differences in outcomes between psychoeducation and usual care. Heterogeneity in study designs further complicates the synthesis of available data into overall assessments of the effect of psychoeducation.

##### Findings

###### Function

Functional outcomes at 1 year of followup as measured by use of either the GAF or GAS scales in three trials were pooled, showing a significant beneficial effect of psychoeducation (MD −5.23, 95% CI −8.76 to −1.71; I^2^=79%).^102^ Nevertheless, the SOE for this effect was low related to study limitations mentioned above and small number of observations. Individual trials reported the GAS or GAF at the end of treatment, 6 months, 18 months, and 2 and 5 years after treatment, but this evidence was insufficient to draw conclusions due to study limitations, lack of confirmatory studies, and small sample sizes. Within this evidence, two RCTs suggested the possibility of improved functional outcomes with psychoeducation; one study finding a significant benefit of psychoeducation at 2 years, but not 5 years of followup, and the other finding improvement in psychosocial functioning immediately after the intervention, with no observable difference at 6 or 18 months of followup using the SAS scale (Appendix Table E-17).

###### Health-Related Quality of Life

Although a single small RCT (N=114) observed a nonsignificant finding of improved quality of life as measured by Heinrich’s Scale at the end of treatment and at 3 months, the SOE evidence was insufficient due to study limitations and small number of observations and inability to assess consistency in this single RCT.^102^

###### Improvement in Core Illness Symptoms

Differences in BPRS total scores were compared in two RCTs (one observing a small but nonsignificant benefit, one showing no effect), with overall SOE insufficient related to study design, imprecision, and unknown consistency.^102^

###### Relapse

A combined relapse and readmission analysis was conducted in the systematic review in order to increase the amount of extractable data (Appendix Table E-17). Based on six trials (N=720), psychoeducation had a greater effect than usual care on relapse rates (with or without readmission) at 9 to 18 months of followup (RR 0.80, 95% CI 0.70 to 0.92; I^2^=54%)^102^ SOE for this finding is moderate. Other analyses of the available RCTs restricted to relapse without readmission showed no significant effects of psychoeducation, and had low SOE related to study methodologies and lack of precision. One group included in this SR^292^ has reported data suggesting benefit from psychoeducation in reducing readmission rates after 7 years of followup.

###### Harms

Potential harms that might be related to a psychoeducation intervention that were analyzed in the systematic review^102^ included death and all-cause dropouts of subjects exposed to the psychoeducation intervention (Appendix Table E-17). Only two RCTs reported on deaths, with no indication that deaths varied between groups, but the SOE was low primarily related to imprecision and the infrequency of death during the trials. No difference was detected in rates of subjects who left trials or were lost to followup in eight trials (RR 1.13, 95% CI 0.89 to 1.44; I^2^=15%)

### Social Skills Training Versus Usual Care

#### Key Points

- Three fair-quality RCTs (N=384) provided evidence for social skills training.
- Global function was significantly better in patients receiving 6 months (SMD on the GAF scale 1.60, 95% CI 1.19 to 2.02) and 1 year (SMD 2.02; 95% CI 1.53 to 2.52) of social skills training. Social function was significantly better in patients receiving 2 years (SMD on The Multnomah Community Ability Scale (MCAS) 0.65, 95% CI 0.36 to 0.95) of social skills training in three trials (SOE: low).
- In patients with schizophrenia, symptoms, based on the PANSS, improved more with social skills training at 6 months (SMD −1.50, 95% CI −1.92 to −1.09) and 2 years (SMD −0.81, 95% CI −1.22 to −0.40) (SOE: low).
- Negative symptoms were consistently and significantly improved with social skills training relative to usual care in three trials (SMD range −0.45 to −1.30) (SOE: low).

#### Detailed Synthesis

##### Description of Included Studies

We identified two systematic reviews of social skills training (Kurtz 2008^293^ and Almerie 2015^294^), however both were subsequently excluded due to the inclusion of a high number of inpatients and short-term studies (i.e., less than 12 weeks duration), and/or studies that used an active control group with no separate analysis according to active or passive controls. Although these reviews did not meet our inclusion criteria, for contextual purposes we have included the findings from the Kurtz review below for function, negative symptoms and relapse. We did not report results from the Almerie review due to the inclusion of a high proportion of studies conducted in China, which have been shown to overestimate treatment effects and are of questionable relevance to United States clinical practice.^295^

Review of the reference lists of these reviews and literature searches identified three RCTs (in 4 publications) meeting inclusion criteria comparing social skills training and usual care (Appendix Table E-18).^97,103–105^ One other RCT of cognitive behavioral social skills training is included in the CBT section of this report.^275^

The three RCTs of social skills training enrolled between 98 and 183 study participants. In these trials, social skills training consisted weekly sessions (ranging from 24 weeks to 1 year; total followup 6 month to 3 years) of specific, progressive intervention modules that generally included management of symptoms and medication, improving social and family relationships, and increasing functional skills such as money management, among others. In all three trials, social skills training was specifically focused on improving psychosocial function and reducing relapse and need for hospitalization. One study was conducted in the United States,^103,104^ and the other two were conducted in Mexico.^97,105^ Mean age was about 30 years in two trials.^97,105^ In the other study, which specifically enrolled older adults, the mean age was 60 years.^103,104^ In the same study, more than half of study participants were female, and >80 percent were white. In the other two trials, women made up about 30 percent of participants and race was not reported.^97,105^ Two trials required a diagnosis of schizophrenia for study inclusion, but in the other, only about 55 percent of participants had schizophrenia or schizoaffective disorder. Duration of illness was 8 and 9 years in two trials,^97,105^ and not reported in the other. All three trials were rated fair quality (Appendix Table F-4). Methodological limitations among the studies were inadequate reporting of methods of randomization and allocation concealment, dissimilarities of baseline groups (one study) and no intention to treat analysis (two studies).

##### Findings

###### Function

Functional improvement is a primary focus of social skills training. All three trials reported significant improvements functional outcomes with social skills training, based on different measures (Appendix Table E-18).^97,103–105^ Since functional outcomes were reported in various ways in the trials, we converted scale scores to SMDs here for comparison purposes. In two trials, GAF scores were significantly better in social skills training groups compared with usual care after 6 months (N=119; SMD 1.60, 95% CI 1.19 to 2.02)^105^ and 1 year of treatment (N=98; SMD 2.02, 95% CI 1.53 to 2.52).^97^ The third study, which included a mix of patients with schizophrenia and mood disorders, reported improvement in function based on MCAS score after 2 years of social skills training (N=183; SMD 0.65, 95% CI 0.36 to 0.95) but these results were not sustained at 3 years followup (1 year after treatment was stopped; SMD 0.24; 95% CI −0.05 to 0.53).^103,104^ These results are consistent with those in the Kurtz 2008 systematic review described above, which also reported a positive effect of social skills training on psychosocial function (seven trials, N=371); effect size 0.52, 95% CI 0.31 to 0.73).^293^ The evidence on improvements during treatment was low strength; evidence on maintenance of effect after discontinuing treatment was limited to one small study and is therefore insufficient to draw conclusions.

###### Improvement in Core Illness Symptoms

###### Overall Symptoms

Significantly greater reduction in overall symptoms was found following completion of social skills training compared with usual care in the two trials (N=119 and 98) that exclusively enrolled patients with schizophrenia (Appendix Table E-18).^97,105^ SMD in total PANSS scores was −1.50 (95% CI −1.92 to −1.09) and −0.81 (95% CI −1.22 to −0.40) after 6 months and 1 year, respectively. This evidence was low strength. In the third study, there was a small, nonsignificant effect in favor of social skills training based on BPRS score (N=183; SMD −0.04, 95% CI −0.33 to 0.25). This study enrolled a combination of patients with schizophrenia/schizoaffective disorder (56%), depression (24%), and bipolar disorder (20%), potentially limiting the effect on symptom scores.^103,104^

###### Negative Symptoms

Negative symptoms were consistently improved following 6 months (SMD −1.30, 95% CI −1.70 to −0.90),^97^ 1 year (SMD −0.82; 95% CI −1.23 to −1.40),^105^ and 2 years (SMD −0.45; 95% CI −0.74 to −0.15)^104^ of social skills training based on the SANS (1 study) and PANSS (two trials) scores (low-strength evidence). Results from these trials are consistent with the findings in the Kurtz systematic review, which also found that social skills training significantly improved negative symptom scores (6 trials, N=363; effect size 0.40, 95% CI 0.19 to 0.61).^293^ In the only study meeting inclusion criteria to follow patients after the cessation of treatment, negative symptom scores were still significantly better in social skills training patients 1 year after treatment had ended (SMD −0.45, 95% CI −0.74 to −0.15).^103^ Evidence on maintenance of effect after treatment discontinuation is insufficient due to study limitations, lack of confirmatory studies, and imprecision.

###### Treatment Discontinuation

There was no difference in treatment discontinuation, based on two trials with 1- (88% [43/49] vs. 80% [39/49]; RR 1.10, 95% CI 0.92 to 1.31) and 2-year (82% [76/93] vs. 81% [73/90]; RR 1.01; 95% CI 0.88 to 1.16) followup (Appendix Table E-18).^97,104^ This was low-strength evidence.

###### Relapse

In one study with 1-year followup reporting undefined relapse, patients in the social skills training group were half as likely to relapse compared with those in the usual care group (5% vs. 10%), but absolute number of patients relapsing was small (5/49 vs. 10/49) and the risk estimate was not significant (RR 0.50; 95% CI 0.18 to 1.36).^97^ Due to the lack of confirmatory studies in relevant populations, and small sample size, this evidence is insufficient. The 2008 Kurtz review reported a combined effect size for relapse and hospitalization, indicating a small (0.23) but significant finding (95% CI 0.04 to 0.41) in favor of social skills training based on nine trials (N=485).^293^

### Supported Employment Versus Usual Care

#### Key Points

- Supported employment, using the individual placement and support (IPS) model, results in better employment outcomes than usual care with 2 years of followup. The evidence is based on one fair-quality trial (N=204), and is supported by evidence from a systematic review of 14 RCTs with vocational training comparisons, and a large RCT (N=1,273) with both usual care and vocational training comparisons.
- Patients receiving IPS were significantly more likely to obtain competitive work than those receiving usual care (75% vs. 27.5%, p=0.001). These findings are consistent with findings of a large trial of various supported employment interventions that included other comparison groups (SOE: moderate). The time to obtaining first competitive employment was 22 days shorter with IPS than with usual care (p<0.001, SOE: low).
- IPS resulted in more patients working more than 20 hours per week (13% vs. 34%; p=0.00), having more weeks of employment overall (24 more weeks competitive and 11 more weeks any employment; p< 0.001), and longer tenure per individual job (4 weeks; p= 0.048) than those in either usual care, other vocational interventions, or both. These findings are consistent with findings of a large trial and a systematic review of 14 trials that included other comparison groups (SOE: moderate).
- Patients receiving IPS earned more money than those in usual care ($2,078/month vs $617.59/month; p< 0.001). These findings are consistent with findings of a large trial of supported employment interventions that included other comparison groups, except that the overall earnings and the magnitude of difference between groups was smaller. ($122/month vs $99/month; p=0.04, SOE: moderate)

#### Detailed Synthesis

##### Description of Included Studies

In our review, we included studies that compared supported employment with usual care as direct evidence. We identified one fair-quality trial (N=204) that examined the effect of the IPS model of supported employment compared with standard services offered off-site from the mental health center (usual care) and a psychosocial rehabilitation intervention (Appendix Tables E-19 and F-4).^109^ The target population included patients with severe mental illness receiving care at a state mental health department with an Axis I diagnosis and severe impairment in psychosocial functioning or self-care; lacking competitive employment; desire for competitive work; capable of providing informed consent. Comprehensive employment data were collected and interviews were conducted at baseline and every 6 months for the 2-year study duration. Fidelity to the IPS model was evaluated yearly, with the IPS group achieving high fidelity scores (using the IPS Fidelity Scale). Study participants received services at the lead community mental health center in Hartford, Connecticut. The study was conducted in a population that was mainly African American and Latino; the proportion of eligible patients enrolled was highest among Latinos (86%) and African Americans (81%) with a lower rate among white patients (66%). Participants in the study were mostly men in their 40s (mean age 41 years, 63% male).

A number of employment outcomes were collected, with the two main outcomes categorized as competitive work, “jobs paying competitive wages in integrated settings, contracted by clients, and not reserved for persons with disabilities,” and any paid work, which could include jobs set aside for persons with disabilities. Nonvocational outcomes were evaluated using standardized scales, but were reported as “trends” because of the large number of tests conducted. Although intention-to-treat analysis was undertaken, the impact of missing data was a concern, as less than 40 percent of patients assigned to usual care contributed data in the second year versus 90 percent for the IPS group.

Because there was only one eligible study comparing supported employment with usual care, we included evidence, comparing supported employment with other vocational interventions. This evidence included a good quality systematic review of 14 RCTs with other vocational training interventions as controls (N=2,265)^106^ (Appendix Tables E-20 and F-3). The psychosocial rehabilitation intervention arm of the study described above was also included. Thirteen of the 14 included studies used IPS as the model for supported employment. Duration of followup was 12 to 24 months. We also included a large, United States-based, fair quality RCT of supported employment conducted in eight states (N=1,273) which made comparisons to usual care and active vocational interventions, depending on the study site^108^ (Appendix Tables E-19 and F-4). Approximately half of the study sites used a usual care comparison group, and three of eight states explicitly used the IPS model. Duration of followup was two years. An analysis of results in patients with and without a schizophrenia diagnosis was also published.^107^ The review and the trial reported similar outcome measures as the RCT described above.

##### Findings

###### Occupational Function

Based on intention-to-treat analysis, the trial of IPS versus usual care described above found that patients in the IPS group were significantly more likely to obtain competitive work (75% vs. 27.5% p<0.001).^109^ The other RCT, with both usual care and vocational intervention comparators, also found that more patients obtained competitive employment while receiving supported employment interventions than other interventions, including usual care (55% vs 34%; p<0.001).^108^ Subgroup analysis of only patients diagnosed with schizophrenia showed a similar pattern although the overall success in obtaining competitive employment was lower (22% vs. 12%; p< 0.001 with mixed effects logistic regression).^107^ Overall, this evidence was moderate strength. Based on the trial data comparing IPS to usual care, the mean time for patient to obtain their first competitive employment was 22 days (p<0.001) shorter with IPS than with usual care.^109^ This was low-strength evidence.

Patients receiving IPS were also significantly more likely to obtain any work than those receiving usual care (75% vs. 53.6%, p=0.001).^109^ This finding is supported by the systematic review findings, where the risk ratio, based on seven RCTs (N=951) for finding any employment was 2.62 (95% CI 2.18 to 3.16) with IPS over vocational training interventions.^106^ Combined, this was moderate-strength evidence.

The measures of how much a patient worked, how consistently they were employed and for how long varied, but all showed that supported employment interventions were beneficial over either usual care or other vocational interventions. Compared with usual care, the RCT found that significantly more patients receiving IPS worked more than 20 hours per week (33.8% vs. 13%; p=0.001).^109^ This evidence is consistent with evidence that finds that more patients receiving supported employment interventions work 40 or more hours per month than those receiving other vocational training or usual care (51% vs. 39%; p<0.001).^107,108^ Patients receiving IPS worked more weeks in competitive employment than those in usual care (mean 29.72 vs 5.45 weeks; p<0.001).^109^ The systematic review also found that IPS results in more days of competitive employment than other interventions (MD 70.63 days, 95% CI 43.22 to 98.04).^106^ Similarly, evidence with both usual care and active controls find that patients receiving IPS have more time in any employment than those receiving usual care (30.18 weeks vs. 19.08 weeks; p<0.001 for IPS versus usual care,^109^ and MD of 84.94 days more [95% CI 51.99 to 117.89] versus other vocational interventions). The tenure on any individual job was also longer with IPS. Compared with usual care, IPS resulted in a mean 19.75 weeks compared with 15.56 weeks per job with usual care (p<0.001).^109^ Findings from the systematic review, based on two trials, were very similar with a MD of 3.86 weeks (95% CI −5.66 to 13.38).^106^ These findings were moderate SOE.

Patients receiving supported employment interventions earned more money than those in usual care ($2,078/month with IPS vs $617.59/month with usual care; p< 0.001).^109^ Findings from a trial with both vocational training and usual care comparison groups supports this finding, although the amount earned per month and the relative difference was smaller ($122/month vs $99/month; p=0.04).^107,108^ Combined, this evidence was moderate strength for the direction of effect. The variation in magnitude of effect was lower strength.

###### Improvement in Core Illness Symptoms

Differences in nonvocational outcomes were reported as not being significant between IPS and usual care.^109^ This outcome was either not significantly different or not reported in the other studies.

###### Treatment Discontinuation

Treatment discontinuation (withdrawal from study) was much higher in the usual care group compared with the IPS group; rates of retention in the study were less than 40 percent for standard services in the second year versus 90 percent for IPS.^109^

### Supportive Therapy Versus Usual Care

#### Key Points

- A good-quality systematic review evaluated five trials of supportive therapy versus usual care and found no differences in global functioning (SOE: low).

#### Detailed Synthesis

##### Description of Included Studies

We identified one good-quality systematic review comparing supportive therapy or supportive care that included 24 RCTs (total N=2126, range 12 to 315 per study) and 10 weeks to 3 years of followup (Appendix Tables E-21 and F-3).^110^ Only five of the trials used a usual care control group (N=822). Three of these were conducted in the outpatient setting and two were conducted in the United States. Most of the patients in the trials had been diagnosed with schizophrenia and the ages ranged from 16 to 72. Four of the trials specified that the patients had to be suffering from on-going hallucinations and/or delusions. Four of the trials enrolled patients with long-standing disease, but one enrolled majority experiencing their first episode and included inpatients.^284^ This study also had a lower median age (27 years) than the mean in other trials (36 to 47 years). All studies enrolled more men than women.

Definitions of the interventions were not consistent, but generally the study interventions were aimed at maintaining current functioning or to assist the patients with pre-existing coping abilities. Specific treatments received in the usual care group were not reported. The frequency and duration of treatments varied, ranging from twice a week for 3 months with monthly booster sessions for 4 months, to sessions every 2 weeks for a total of 10 sessions, with no booster sessions. Although this review was good quality, the trials themselves were mostly fair or even poor quality (only 1 of the 5 was good quality).

##### Findings

###### Function

The effect of supportive therapy on function was reported in two trials in the systematic review, but differences were not found at 9 months in either global or social functioning (Appendix Table E-21).^110^ Although two trials used similar scales to measure global functioning, the results were not pooled GAF (modified version), N=29, MD 1.40, 95% CI −5.09 to 7.89; GAS, N=260, MD −2.66, 95% CI −6.20 to 0.88). Only one of these trials also measured social functioning (using the SFS), and found no difference between the groups. (N=260, MD−0.67, 95% CI −7.05 to 5.71). The trials were small, such that this evidence is imprecise. The evidence on global functioning was low strength, whereas the evidence on social functioning is insufficient.

###### Health-Related Quality of Life

In the systematic review, a single study reported outcomes that were categorized as quality of life, although the three scales reported do not measure global health-related quality of life (Appendix Table E-21). The scales used were the Rosenberg Self-Esteem Scale (RSES) noted to measure positive aspects of psychological functioning, the Well-being Scale (WBS) Global health questionnaire (GHQ) noted to measure nonpsychotic psychiatric symptoms. No differences were found on these measures and the evidence is insufficient.

###### Improvement in Core Illness Symptoms

###### Overall Symptoms

The systematic review identified one study reporting general symptomatology using the PANSS, one in the short term and one in the long term, with neither study finding significant differences between groups: short term (13 to 26 weeks; N=131, MD −4.42 (95% CI −10.13 to 1.29); long term (more than 26 weeks; N=36, MD 4.70 (95% CI −6.71 to 16.11; Appendix Table E-21). This evidence is insufficient.

###### Negative Symptoms

The systematic review found only one study that reported negative symptoms, using the SANS, but determined that the data were skewed and did not analyze the significance of the findings. In the short term the endpoint scores were very similar (10.19 and 10.73 for treatment and control), although in the long term the scores were more different (9.90 and 11.46, respectively). The study was very small (N=47) so this evidence is insufficient.

###### Treatment Discontinuation

Leaving the study early was reported in four RCTs (N=354) in the systematic review, resulting in a pooled estimate that indicated no significant difference between groups (RR 0.86, 95% CI 0.53 to 1.40). This was low-strength evidence.

###### Relapse

Only one study reported on relapse, but defined it as readmission to hospital for clinical deterioration that lased at least 5 days and resulted in functional impairment (Appendix Table E-21). The systematic review found no significant difference in relapse rates between supportive therapy and usual care at either medium-term followup (13 to 26 weeks, N=54, RR 0.12, 95% CI 0.01 to 2.11), or long-term followup (more than 26 weeks, N=54, RR 0.96, 95% CI 0.44 to 2.11). This evidence is insufficient.

## Key Question 2b Variation of Benefits and Harms of Psychosocial and Other Nonpharmacological Treatments Versus Usual Care for Adults With Schizophrenia by Patient Characteristics

### Key Points

#### Clinical Subgroups

- Patients experiencing a first episode of psychosis: Pooled results found that the team-based multi-component interventions resulted in higher global functioning, based on GAF and GAS scores after up to 2 years of treatment (three RCTs; WMD: 3.88; 95% CI 0.91 to 6.85) (SOE: moderate).
  ○ Team-based multi-component interventions resulted in significantly more people (22%) working or in school after up to 2 years of treatment (three RCTs; RR 1.22; 95% CI 1.01 to 1.47) (SOE: moderate).
  ○ There were no significant differences between multi-component treatment programs and usual care on housing status for up to 2-year treatment duration based on two RCTs (SOE: low).
  ○ Two RCTs found significant differences between multi-component programs and usual care on quality of life scores for up to 2-year treatment duration (effect size 0.84; 95% CI 0.14 to 1.55) (SOE: moderate).
  ○ There was no difference in reduction in self-harm in two trials of multi-component programs versus usual care (SOE: low).
  ○ There was no difference between multi-component programs and usual care in total PANSS scores based on three RCTs (WMD −2.53; 95% CI −5.45 to 0.39). (SOE: low). Removal of one study with between-group baseline differences resulted in a small but significant estimate (−1.40, 95% CI −2.25 to −0.55) (SOE: low).
  ○ Team-based multi-component program participants were significantly less likely to relapse compared with those in usual care based on two RCTs (RR 0.64; 95% CI 0.52 to 0.79) (SOE: moderate).
- Comorbidities:
  ○ Substance use: One good-quality systematic review of 32 trials (N=3,165) of co-occurring SUD and schizophrenia found no differences between integrated assertive community treatment and usual care in function at 12 months and mortality, and substance use at 36 months in people with co-occurring SUD (SOE: low for all outcomes).

#### Demographic Subgroups

- Evidence from systematic reviews and RCTs of CBT, cognitive remediation, and social skills training found no difference for any outcome when results were stratified according to patient age, or when comparing results from trials conducted in younger versus older adults.
  ○ A systematic review of CBT found no difference in negative symptom outcomes when results were stratified according to sex. Limited evidence from one RCT of a mixed population (about 50% diagnosed with schizophrenia or schizoaffective disorder) of social skills training suggested that the intervention may be more effective in men than women for function and symptoms.

### Detailed Synthesis

#### Findings

##### Clinical Subgroups

###### Early Interventions for Patients With a First Episode of Psychosis Versus Usual Care

We identified one fair-quality systematic review comparing 12 early intervention programs for treating first-episode psychosis with usual care.^296^ This review was subsequently excluded, as 11 of the included studies did not meet our inclusion criteria, either due to small sample size, enrollment of inpatients, lack of applicability to the United States population, and/or use of a one-off intervention. One trial (the Danish OPUS trial) of team-based multi-component treatment programs included in the systematic review met our inclusion criteria (Appendix Table E-22).^111^

Literature searches identified three additional RCTs (in seven publications) not included in the systematic review reporting on the effect of team-based multi-component treatment compared to usual care (Appendix Table E-22).^112–117,119^ We identified one other study reporting 10-year outcomes from the OPUS trial.^118^ The number of participants enrolled in these studies ranged from 99 to 1,268. Mean age ranged from 23 to 27 years, and 32 to 46 percent of participants were female. In two trials reporting race, Blacks comprised about 50 percent of the study population in both. Baseline psychotic symptom severity was similar in two studies (mean PANSS total score ranging from 67.4 to 77.5),^113,116^ but was lower in a third study (mean total PANSS 44.6).^115^ Mean duration of untreated psychosis, was 50 weeks ^118^ to over 3 years^116^ in two trials. Duration of followup ranged from 1 to 10 years. Two trials were rated good quality,^111,112^ one was rated fair quality,^115^ and one was rated poor quality.^116^ Methodological limitations in the fair- and poor-quality trials included unclear randomization method and high attrition rates (Appendix Table F-4).

###### Function

Global. The effect of team-based multi-component treatment programs on global function was reported in three RCTs.^111,113,114^ Pooled results found that the multi-component programs resulted in higher functioning, based on GAF and GAS scores during up to 2 years of intervention (three RCTs; WMD 3.88, 95% CI 0.91 to 6.85, I^2^=64%). This evidence was moderate strength. Treatment effects were not sustained at 5^111^ and 10 years^118^ after treatment removal.

Employment or school attendance. The effect of multi-component programs versus usual care on participation in work and school was reported in three RCTs.^111,113,114^ Pooled results found that multi-component programs resulted in significantly more people working or in school for the (up to) 2-year intervention period (three RCTs; pooled RR 1.22, 95% CI 1.01 to 1.47). This evidence was moderate strength. These effects were not sustained at 5^111^ and 10 years^118^ after treatment removal.

Living situation. Pooled results from two RCTs found no significant differences between the team-based multi-component interventions and usual care during the up to 2-year intervention period (two RCTs; pooled RR 1.06, 95% CI 0.86 to 1.30).^111,113^ This SOE was low. Five-year followup data suggest findings in favor of the team-based approach, with significantly more participants living in noninstitutional supported housing (N=547, RR 0.42 CI 0.21 to 0.83).^111^ This result was not significant at 10-year followup.^118^

###### Health-Related Quality of Life

Team-based multi-component programs resulted in greater quality of life ratings after 18 months to 2 years treatment, based on results from two trials (pooled effect size 0.84, 95% CI 0.14 to 1.55, p=0.02).^113,116^ This evidence was moderate strength.

###### Reduction in Self-Harm

One trial, included in the systematic review, reported suicide incidence, finding no difference in risk between multi-component treatment programs and usual care (N=506, RR, CI 0.93 0.06 to 14.81)^111^ A second trial found that the proportion of participants who, at 10-year followup, had experienced thoughts of suicide within the preceding 2 years was similar within multi-component programs (39.4%) and in usual care (379%, p=0.77).^118^ This was low SOE.

###### Improvement in Core Illness Symptoms

The effect of team-based multi-component programs on psychotic symptoms, based on PANSS scores, was reported in three trials.^113,114,116^ Pooled results found no difference between groups in scores (WMD −2.53; 95% CI −5.45 to 0.39; I^2^=55%). Sensitivity analysis removing a study with a 5.9-point difference at baseline results in a very small but significant difference and no heterogeneity (WMD −1.40; 95% CI −2.25 to −0.55; Cochran Q for heterogeneity 0.0014, df=1).^114,116^ This evidence was low strength. There was no effect on depressive symptoms, based on the Calgary Depression Scale (two RCTs; WMD −0.44; 95% CI −1.08 to 0.20). This was low strength evidence.

###### Treatment Discontinuation

Results from two trials found participants in team-based multi-component treatment programs had a significantly greater rate of treatment retention compared with usual care after 12 to 18 months treatment (RR 1.27; 95% CI 1.16 to 1.38; Cochran Q=0.03, df=1).^112,114^ This evidence was moderate strength. When rates were adjusted for baseline differences in sex, previous psychotic episode, and ethnicity, drop-out rates remained significant based on one trial (RR 0.28, CI 0.12 to 0.73).^112^ While a third RCT^116^ found significant differences in treatment retention, favoring team-based programs, this study had a 49 percent attrition rate, so those findings are not included here.

###### Relapse

Pooled analysis from two trials found that participants in team-based multi-component treatment programs were significantly less likely to relapse (defined as worsening of psychotic symptoms and/or hospitalization) than those in usual care (RR 0.64; 95% CI 0.52 to 0.79; Cochran Q=0.024, df=1).^112,114^ This evidence was moderate strength.

###### Harms

One trial found no significant differences between team-based multi-component care and usual care in rates of accidental death (RR 0.31; 95% CI 0.01 to 7.59) or unexplained death (RR 0.31; 95% CI 0.01 to 7.56).^111^ Ten-year followup from the same trial found no difference in between-group mortality (RR 0.92; 95% CI 0.45 to 1.88).^118^

###### Comorbidities: Substance Use Disorder and Schizophrenia

One good-quality Cochrane systematic review included 32 randomized trials that enrolled a total of 3,165 patients (aged 18 years to 65 years) with severe mental illness and comorbid substance misuse (Appendix Table E-23).^120^ Most trial participants were diagnosed with a schizophrenia spectrum disorder or psychosis with a concurrent diagnosis of substance misuse (e.g., cannabis, cocaine, opioids) and were diagnosed using American Psychiatric Association’s Diagnostic and Statistical Manual of Mental Disorders (DSM) criteria. Studies that enrolled only patients with major depressive disorder, bipolar disorder, or patients who only misused tobacco were excluded. Interventions were more intense (e.g., integrated models of care with assertive community treatment) or were stand-alone treatments (e.g., cognitive behavioral therapy, social skills training). Three trials were conducted solely in the hospital (10% of patients), 19 in community, and the remaining were a combination of settings. Function, mortality, relapse rates, and treatment maintenance (reported as loss to treatment) were among the reported outcomes. None of the included trials met all quality criteria. Three trials met most criteria, with the majority of trials reporting adequate randomization techniques. However, few trials reported appropriate allocation concealment or blinding of participants. Most SOE was rated as low strength or insufficient.

###### Long-Term Intervention: Integrated Models of Care Versus Usual Care

Integrated models of care refer to the coordination of care at the provider (or team of providers) level for both the mental health and substance misuse diagnoses and the actual services provided vary according to the needs of the patient. Within the Cochrane review, four RCTs provided data for 735 participants.^120^ SOE was low for all outcomes.

###### Function

One trial (N=198) provided data on global functioning using the GAF and found low-strength evidence of no difference between assertive community treatment compared with usual care at 12 months (40.4 vs. 39.7, MD 0.70; 95% CI −2.07 to 3.47).^120^ Findings were similar at multiple timepoints, beginning at 6 months through 36 months and continued to show no difference between treatments based on low-strength evidence (Appendix Table E-23).

###### Treatment Discontinuation

Pooled analysis of three trials (N=603) indicated no difference in likelihood of being lost to treatment between integrated treatment and usual care at 36 months (24% vs. 21%, RR 1.09, 95% CI 0.82 to 1.45, I^2^=0%) based on low-strength evidence.^120^

###### Substance Use

One trial (N=143) found low-strength evidence of no difference between integrated assertive community treatment compared with standard case management at 36 months for not being in remission for alcohol use (57% vs. 50%, RR 1.15, 95% CI 0.84 to 1.56) and for drug use (58% vs. 65%, RR 0.89, 95% CI 0.63 to 1.25).^120^

###### Harms

Two trials (N=421) reported all-cause mortality and found low strength evidence of no difference between assertive community treatment and usual care through 36 months (3% vs. 3%, RR 1.18, 95% CI 0.39 to 3.57, I^2^=0%).^120^

###### Long-Term Intervention: Nonintegrated Models of Care Versus Usual Care

Nonintegrated models of care describe interventions where care teams do not coordinate care. ICM with higher skilled case managers with smaller caseloads is included as a nonintegrated model. However, models still had to address the patient’s substance misuse. Within the Cochrane review four trials (N=163) met criteria for nonintegrated models of care.^120^ Included interventions were nonintegrated assertive community treatment (2 trials, N=84) and intense case management (two trials, N=79). Trials were small and of lower quality and provided insufficient strength evidence to compare patient function and loss to treatment between nonintegrated models of care and usual care.

###### Short-Term, Patient-Focused Interventions: Cognitive-Behavioral Therapy Versus Usual Care

CBT was an included intervention to address substance misuse in patients with a dual diagnosis of schizophrenia and substance misuse disorder.^120^

Treatment discontinuation. Pooled analysis from two trials (N=152) found no difference between treatment with CBT and usual care at 3 months in risk of discontinuing treatment (12% vs. 10%, RR 1.12; 95% CI 0.44 to 2.86, I^2^=0%) based on low-strength evidence.^120^

###### Short-Term, Patient-Focused Interventions: Social Skills Training Versus Usual Care

Social skills training was included help patients improve interpersonal skills and relationships and manage conflict in social situations involving substance misuse.^120^ Evidence for loss to treatment was considered insufficient to draw meaningful conclusions based on data from two trials (N=94).

###### Demographic Characteristics

###### Age

Evidence of the effect of nonpharmacological interventions on schizophrenia outcomes from subgroup analyses based on patient age, whereas very limited, suggests that age is not a moderating factor. Systematic reviews of CBT^79^ and cognitive remediation^84^ review found no difference between interventions and usual care when trials were stratified according to age. In individual trials of cognitive remediation^89^ and social skills training^103,104^ enrolling older adults (over age 50), there was also no difference in outcomes when compared with trials enrolling a younger population.^86–88,90,97,105^ Age-based subgroup analyses were not reported for other nonpharmacological interventions.

###### Sex

Evidence on differences in outcomes based on sex is extremely limited. One systematic review of 30 RCTs of CBT found no difference in negative symptom outcomes when results were stratified according to sex.^79^

One study of social skills training that exclusively enrolled older adults (mean age 60 years) had an effect size for men that was consistently better than that for women for outcomes related to function and symptoms, suggesting that social skills training was more effective in men compared with women.^103,104^ Of note is the fact that only about half of participants in this study had a diagnosis of schizophrenia or schizoaffective disorder, whereas the remaining participants had various mood disorders. This potentially limits the applicability of these findings, as additional subgroup analysis found consistently lower benefit of social skills training for all outcomes when compared with participants with mood disorders.

Other trials of nonpharmacological interventions did not report subgroup analyses according to sex.