# References

1 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, 5th ed. Arlington, VA: American Psychiatric Publishing; 2013.
2 Tandon R, Gaebel W, Barch DM, . Definition and description of schizophrenia in the DSM-5. Schizophr Res. 2013 Oct;150(1):3–10. doi: 10.1016/j.schres.2013.05.028. PMID: 23800613.23800613
3 McGrath J, Saha S, Chant D, . Schizophrenia: a concise overview of incidence, prevalence, and mortality. Epidemiol Rev. 2008;30:67–76. PMID: 18480098.18480098
4 Harding CM. Changes in Schizophrenia Across Time: Pardoxes, Patterns and Predictors. In: Cohen CI, ed Schizophrenia into later life: Treatment, research and policy. Arlington, VA: American Psychiatric Publishing, Inc.; 2003:19–41.
5 Wils RS, Gotfredsen DR, Hjorthøj C, . Antipsychotic medication and remission of psychotic symptoms 10 years after a first-episode psychosis. Schizophr Res. 2017;182:42–8. doi: 10.1016/j.schres.2016.10.030. PMID: 28277310.28277310
6 Frese FJ, 3rd, Knight EL, Saks E. Recovery from schizophrenia: with views of psychiatrists, psychologists, and others diagnosed with this disorder. Schizophr Bull. 2009 Mar;35(2):370–80. doi: 10.1093/schbul/sbn175. PMID: 19304812.19304812
7 Buchy L, Cadenhead KS, Cannon TD, . Substance use in individuals at clinical high risk of psychosis. Psychol Med. 2015;45(11):2275–84. PMID: 25727300.25727300
8 Goerke D, Kumra S. Substance abuse and psychosis. Psychiatr Clin North Am. 2013;22(4):643–54. PMID: 24012078.24012078
9 Mesholam-Gately RI, Gibson LE, Seidman LJ, . Schizophrenia and co-occurring substance use disorder: reward, olfaction and clozapine. Schizophr Res. 2014;155(1–3):45–51. PMID: 24685823.24685823
10 De Witte NA, Crunelle CL, Sabbe B, . Treatment for outpatients with comorbid schizophrenia and substance use disorders: a review. Eur Addict Res. 2014;20(3):105–14. doi: 10.1159/000355267. PMID: 24192558.24192558
11 American Diabetes Association, American Psychiatric Association, American Association of Clinical Endocrinologists, . Consensus development conference on antipsychotic drugs and obesity and diabetes. Diabetes Care. 2004 Feb;27(2):596–601. PMID: 14747245.14747245
12 Newcomer JW, Hennekens CH. Severe mental illness and risk of cardiovascular disease. JAMA. 2007;298(15):1794–6. PMID: 17940236.17940236
13 Henderson D, Vincenzi B, Andrea NV, . Pathophysiological mechanisms of increased cardiometabolic risk in people with schizophrenia and other severe mental illnesses. Lancet Psychiatry. 2015;2(5):452–64. PMID: 26360288.26360288
14 Marder SR, Essock SM, Miller AL, . Physical health monitoring of patients with schizophrenia. Am J Psychiatry. 2004;161(8):1334–49. PMID: 15285957.15285957
15 McDonagh MS, Peterson K, Carson S, . Drug class review of atypical antipsychotic drugs; update 3. Portland, OR: Oregon Health & Science University Drug Effectiveness Review Project; 2010. http://www.ohsu.edu/xd/research/centers-institutes/evidence-based-practice-center/drug-effectiveness-review-project/current-past-reports.cfm Accessed April 22, 2017.
16 Mayo Clinic. Diseases and conditions: schizophrenia. http://www.mayoclinic.org/diseases-conditions/schizophrenia/basics/definition/CON-20021077. Accessed April 22, 2017.
17 Centers for Disease Control. Burden of mental illness. 2013. http://www.cdc.gov/mentalhealth/basics/burden.htm. Accessed April 22, 2017.
18 National Institute of Mental Health. Schizophrenia. http://www.nimh.nih.gov/health/topics/schizophrenia/index.shtml. Accessed April 22, 2017.
19 Gareri P, De Fazio P, Manfredi VG, . Use and safety of antipsychotics in behavioral disorders in elderly people with dementia. J Clin Psychopharmacol. 2014;34(1):109–23. PMID: 24158020.24158020
20 Kales HC, Kim HM, Zivin K, . Risk of mortality among individual antipsychotics in patients with dementia. Am J Psychiatry. 2012;169(1):71–9. PMID: 22193526.22193526
21 Schneider LS, Dagerman KS, Insel P. Risk of death with atypical antipsychotic drug treatment for dementia: meta-analysis of randomized placebo-controlled trials. JAMA. 2005 Oct 19;294(15):1934–43. doi: 10.1001/jama.294.15.1934. PMID: 16234500.16234500
22 Gill SS, Bronskill SE, Normand SL, . Antipsychotic drug use and mortality in older adults with dementia. Ann Intern Med. 2007 Jun 5;146(11):775–86. PMID: 17548409.17548409
23 Alexopoulos GS, Jeste DV, Chung H, . The expert consensus guideline series. Treatment of dementia and its behavioral disturbances. Introduction: methods, commentary, and summary. Postgrad Med. 2005 Jan;Spec No:6–22. PMID: 17203561.17203561
24 Jeste DV, Rockwell E, Harris MJ, . Conventional vs. newer antipsychotics in elderly patients. Am J Geriatr Psychiatry. 1999 Winter;7(1):70–6. PMID: 9919323.9919323
25 Moher D, Liberati A, Tetzlaff J, . Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. BMJ. 2009 Jul 21;339:b2535. doi: 10.1136/bmj.b2535. PMID: 19622551.19622551
26 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville MD: January 2014. Chapters available at: www.effectivehealthcare.ahrq.gov Accessed April 22, 2017.
27 Hartling L, Abou-Setta AM, Dursun S, . Antipsychotics in adults with schizophrenia: comparative effectiveness of first-generation versus second-generation medications: a systematic review and meta-analysis. Ann Intern Med. 2012 Oct 2;157(7):498–511. PMID: 22893011.22893011
28 Abou-Setta AM, Mousavi SS, Spooner C, . First-generation versus second-generation antipsychotics in adults: comparative effectiveness. Comparative effectiveness review No. 63. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-200-10021.) AHRQ Publication No. 12-EHC054-EF. Rockville, MD: Agency for Healthcare Research and Quality: 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm Accessed April 22, 2017. PMID: 2303527523035275.
29 McDonagh M, Peterson K, Fu R, . Second Generation Antipsychotic Drugs. Final Update 4 Report prepared by the Pacific Northwest Evidence-based Practice Center for the Drug Effectiveness Review Project. Oregon Health & Science University, Portland, Oregon, November 2013. 2013. Available with membership in the Drug Effectiveness Review Project. http://www.ohsu.edu/xd/research/centers-institutes/evidence-based-practice-center/drug-effectiveness-review-project/upload/SGA_final-update-4-report_Nov-2013_version-2.pdf. Accessed May 23, 2017.
30 Kreyenbuhl J, Buchanan RW, Dickerson FB, . The Schizophrenia Patient Outcomes Research Team (PORT): updated treatment recommendations 2009. Schizophr Res. 2010 Jan;36(1):94–103. doi: 10.1093/schbul/sbp130. PMID: 19955388.19955388
31 Treadwell J, Singh S, Talati R, . A Framework for “Best Evidence” Approaches in Systematic Reviews. Methods Research Report. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. HHSA 290-2007-10063-I.) AHRQ Publication No. 11-EHC046-EF. Rockville, MD: Agency for Healthcare Research and Quality. June 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed May 19, 2017. 2011.
32 McDonagh MS, Jonas DE, Gartlehner G, . Methods for the drug effectiveness review project. BMC Med Res Methodol. 2012;12(1):140. doi: 10.1186/1471-2288-12-140. PMID: 22970848.22970848
33 Shea BJ, Grimshaw JM, Wells GA, . Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007 Feb 15;7:10. doi: 10.1186/1471-2288-7-10. PMID: 17302989.17302989
34 Review Manager (RevMan), Version 5.3. Copenhagen: The Nordic Cochrane Centre; 2014.
35 StatsDirect Statistical Software. Chesire, UK: StatsDirect Ltd.; 2013.
36 Stata Statistical Software, Release 14. College Station, TX: StataCorp LP; 2015.
37 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. 2004;23(20):3105–24. doi: 10.1002/sim.1875 PMID: 1544933815449338
38 Lu X, Cheng H, Song S, . A study of quetiapine and risperidone and clozapine in the treatment of schizophrenia. China and Foreign Medical Journal. 2006;4 (6):62–4.; 2006.
39 Bucher HC, Guyatt GH, Griffith LE, . The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol. 1997 Jun;50(6):683–91. PMID: 9250266.9250266
40 Dias S, Welton NJ, Caldwell DM, . Checking consistency in mixed treatment comparison meta-analysis. Stat Med. 2010 Mar 30;29(7–8):932–44. doi: 10.1002/sim.3767. PMID: 20213715.20213715
41 Brooks SP, Gelman A. General Methods for Monitoring Convergence of Iterative Simulations. J Comp Graph Stat. 1998;7(4):434–55. doi: 10.1080/10618600.1998.10474787.
42 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 11//;68(11):1312–24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
43 Citrome L, Ota A, Nagamizu K, . The effect of brexpiprazole (OPC-34712) and aripiprazole in adult patients with acute schizophrenia: results from a randomized, exploratory study. Int Clin Psychopharmacol. 2016 Jul;31(4):192–201. doi: 10.1097/yic.0000000000000123. PMID: 26963842.26963842
44 Detke HC, Weiden PJ, Llorca PM, . Comparison of olanzapine long-acting injection and oral olanzapine: a 2-year, randomized, open-label study in outpatients with schizophrenia. J Clin Psychopharmacol. 2014 Aug;34(4):426–34. doi: 10.1097/JCP.0000000000000140. PMID: 24781441.24781441
45 Di Fiorino M, Montagnani G, Trespi G, . Extended-release quetiapine fumarate (quetiapine XR) versus risperidone in the treatment of depressive symptoms in patients with schizoaffective disorder or schizophrenia: a randomized, open-label, parallel-group, flexible-dose study. Int Clin Psychopharmacol. 2014 May;29(3):166–76. doi: 10.1097/YIC.0000000000000017. PMID: 24681810.24681810
46 Durgam S, Starace A, Li D, . An evaluation of the safety and efficacy of cariprazine in patients with acute exacerbation of schizophrenia: a phase II, randomized clinical trial. Schizophr Res. 2014 Feb;152(2–3):450–7. doi: 10.1016/j.schres.2013.11.041. PMID: 24412468.24412468
47 Fleischhacker WW, Sanchez R, Perry PP, . Aripiprazole once-monthly for treatment of schizophrenia: double-blind, randomised, non-inferiority study. Br J Psychol. 2014 Aug;205(2):135–44. doi: 10.1192/bjp.bp.113.134213. PMID: 24925984.24925984
48 Green AI, Brunette MF, Dawson R, . Long-acting injectable vs oral risperidone for schizophrenia and co-occurring alcohol use disorder: a randomized trial. J Clin Psychiatry. 2015 Oct;76(10):1359–65. doi: 10.4088/JCP.13m08838. PMID: 26302441.26302441
49 Ishigooka J, Nakamura J, Fujii Y, . Efficacy and safety of aripiprazole once-monthly in Asian patients with schizophrenia: a multicenter, randomized, double-blind, non-inferiority study versus oral aripiprazole. Schizophr Res. 2015 Feb;161(2–3):421–8. doi: 10.1016/j.schres.2014.12.013. PMID: 25556976.25556976
50 Koshikawa Y, Takekita Y, Kato M, . The comparative effects of risperidone long-acting injection and paliperidone palmitate on social functioning in schizophrenia: a 6-month, open-label, randomized controlled pilot trial. Neuropsychobiology. 2016;73(1):35–42. doi: 10.1159/000442209. PMID: 2681261826812618
51 Li H, Luo J, Wang C, . Efficacy and safety of aripiprazole in Chinese Han schizophrenia subjects: a randomized, double-blind, active parallel-controlled, multicedinter clinical trial. Schizophr Res. 2014 Aug;157(1–3):112–9. doi: 10.1016/j.schres.2014.05.040. PMID: 24994555.24994555
52 Liu J, Sun J, Shen X, . Randomized controlled trial comparing changes in serum prolactin and weight among female patients with first-episode schizophrenia over 12 months of treatment with risperidone or quetiapine. Shanghai Arch Psychiatry. 2014;26(2):88–94. PMID: 25092954.25092954
53 Maat A, Cahn W, Gijsman HJ, . Open, randomized trial of the effects of aripiprazole versus risperidone on social cognition in schizophrenia. Eur Neuropsychopharmacol. 2014 Apr;24(4):575–84. PMID: 24418213.24418213
54 Naber D, Hansen K, Forray C, . Qualify: a randomized head-to-head study of aripiprazole once-monthly and paliperidone palmitate in the treatment of schizophrenia. Schizophr Res. 2015;168(1–2):498–504. PMID: 2623224126232241
55 Naber D, Peuskens J, Schwarzmann N, . Subjective well-being in schizophrenia: a randomised controlled open-label 12-month non-inferiority study comparing quetiapine XR with risperidone (RECOVER). Eur Neuropsychopharmacol. 2013 Oct;23(10):1257–69. doi: 10.1016/j.euroneuro.2013.07.006. PMID: 23953270.23953270
56 Nemeth G, Laszlovszky I, Czobor P, . Cariprazine versus risperidone monotherapy for treatment of predominant negative symptoms in patients with schizophrenia: a randomised, double-blind, controlled trial. Lancet. 2017 Feb 07doi: 10.1016/s0140-6736(17)30060-0. PMID: 28185672.28185672
57 Parabiaghi A, Tettamanti M, D’Avanzo B, . Metabolic syndrome and drug discontinuation in schizophrenia: a randomized trial comparing aripiprazole olanzapine and haloperidol. Acta Psychiatr Scand. 2016;133(1):63–75. PMID: 26252780.26252780
58 Park S, Yi KK, Kim MS, . Effects of ziprasidone and olanzapine on body composition and metabolic parameters: an open-label comparative pilot study. Behav Brain Funct. 2013;9:27. doi: 10.1186/1744-9081-9-27. PMID: 23866300.23866300
59 Robinson DG, Gallego JA, John M, . A randomized comparison of aripiprazole and risperidone for the acute treatment of first-episode schizophrenia and related disorders: 3-month outcomes. Schizophr Bull. 2015;41(6):1227–36. PMID: 26338693.26338693
60 Sanz-Fuentenebro J, Taboada D, Palomo T, . Randomized trial of clozapine vs. risperidone in treatment-naive first-episode schizophrenia: results after one year. Schizophr Res. 2013 Sep;149(1–3):156–61. doi: 10.1016/j.schres.2013.07.003. PMID: 23870807.23870807
61 Savitz AJ, Xu H, Gopal S, . Efficacy and safety of paliperidone palmitate 3-month formulation for patients with schizophrenia: a randomized, multicenter, double-blind, noninferiority study. Int J Neuropsychopharmacol. 2016 Jul;19(7)doi: 10.1093/ijnp/pyw018. PMID: 26902950.26902950
62 Shoja Shafti S, Kaviani H. Quetiapine versus aripiprazole in the management of schizophrenia. Ther Adv Psychopharmacol. 2015;5(3):166–71. PMID: 26199719.26199719
63 Subotnik KL, Casaus LR, Ventura J, . Long-acting injectable risperidone for relapse prevention and control of breakthrough symptoms after a recent first episode of schizophrenia. A randomized clinical trial. JAMA Psychiatry. 2015 Aug;72(8):822–9. doi: 10.1001/jamapsychiatry.2015.0270. PMID: 26107752.26107752
64 Tybura P, Mak M, Samochowiec A, . The influence of antipsychotic therapy on the cognitive functions of schizophrenic patients. Psychiatr Pol. 2013;47(4):567–76. PMID: 24946464.24946464
65 Tybura P, Trzesniowska-Drukala B, Bienkowski P, . Pharmacogenetics of adverse events in schizophrenia treatment: comparison study of ziprasidone, olanzapine and perazine. Psychiatry Res. 2014 Oct 30;219(2):261–7. doi: 10.1016/j.psychres.2014.05.039. PMID: 24930580.24930580
66 Wani RA, Dar MA, Chandel RK, . Effects of switching from olanzapine to aripiprazole on the metabolic profiles of patients with schizophrenia and metabolic syndrome: a double-blind, randomized, open-label study. Neuropsychiatr Dis Treat. 2015;11:685–93. PMID: 25792838.25792838
67 Crespo-Facorro B, Perez-Iglesias R, Mata I, . Effectiveness of haloperidol, risperidone and olanzapine in the treatment of first-episode non-affective psychosis: results of a randomized, flexible-dose, open-label 1-year follow-up comparison. J Psychopharmacol. 2011 Jun;25(6):744–54. PMID: 21292922.21292922
68 San L, Arranz B, Perez V, . One-year, randomized, open trial comparing olanzapine, quetiapine, risperidone and ziprasidone effectiveness in antipsychotic-naive patients with a first-episode psychosis. Psychiatry Res. 2012 Dec 30;200(2–3):693–701. doi: 10.1016/j.psychres.2012.07.005. PMID: 22954905.22954905
69 Amr M, Lakhan SE, Sanhan S, . Efficacy and tolerability of quetiapine versus haloperidol in first-episode schizophrenia: a randomized clinical trial. Int Arch Med. 2013;6 (1)PMID: 24308507.24308507
70 McEvoy JP, Byerly M, Hamer RM, . Effectiveness of paliperidone palmitate vs haloperidol decanoate for maintenance treatment of schizophrenia: a randomized clinical trial.[Erratum appears in JAMA. 2014 Oct 8;312(14):1473]. JAMA. 2014 May 21;311(19):1978–87. doi: 10.1001/jama.2014.4310. PMID: 24846035.24846035
71 Marshall M, Lockwood A. Assertive community treatment for people with severe mental disorders. Cochrane Database Syst Rev. 2000a(2):Cd001089. doi: 10.1002/14651858.cd001089. PMID: 10796415.10796415
72 Sytema S, Wunderink L, Bloemers W, . Assertive community treatment in the Netherlands: a randomized controlled trial. Acta Psychiatr Scand. 2007 Aug;116(2):105–12. PMID: 17650271.17650271
73 Velligan DI, Diamond P, Mueller J, . The short-term impact of generic versus individualized environmental supports on functional outcomes and target behaviors in schizophrenia. Psychiatry Res. 2009 Jul 30;168(2):94–101. doi: 10.1016/j.psychres.2008.03.016. PMID: 19523690.19523690
74 Velligan DI, Diamond PM, Maples NJ, . Comparing the efficacy of interventions that use environmental supports to improve outcomes in patients with schizophrenia. Schizophr Res. 2008 Jul;102(1–3):312–9. doi: 10.1016/j.schres.2008.02.005. PMID: 18374542.18374542
75 Velligan DI, Diamond PM, Mintz J, . The use of individually tailored environmental supports to improve medication adherence and outcomes in schizophrenia. Schizophr Bull. 2008 May;34(3):483–93. PMID: 17932089.17932089
76 Velligan DI, Tai S, Roberts DL, . A randomized controlled trial comparing cognitive behavior therapy, cognitive adaptation training, their combination and treatment as usual in chronic schizophrenia. Schizophr Bull. 2015 May;41(3):597–603. doi: 10.1093/schbul/sbu127. PMID: 25193976.25193976
77 Jauhar S, McKenna PJ, Radua J, . Cognitive-behavioural therapy for the symptoms of schizophrenia: systematic review and meta-analysis with examination of potential bias. Br J Psychiatry. 2014 Jan;204(1):20–9. doi: 10.1192/bjp.bp.112.116285. PMID: 24385461.24385461
78 Jones C, Hacker D, Cormac I, . Cognitive behavioural therapy versus other psychosocial treatments for schizophrenia. Cochrane Database Syst Rev. 2012 Apr 18(4):Cd008712. doi: 10.1002/14651858.CD008712.pub2. PMID: 22513966.22513966
79 Velthorst E, Koeter M, van der Gaag M, . Adapted cognitive-behavioural therapy required for targeting negative symptoms in schizophrenia: meta-analysis and meta-regression. Psychol Med. 2015 Feb;45(3):453–65. doi: 10.1017/S0033291714001147. PMID: 24993642.24993642
80 Freeman D, Dunn G, Startup H, . Effects of cognitive behaviour therapy for worry on persecutory delusions in patients with psychosis (WIT): a parallel, single-blind, randomised controlled trial with a mediation analysis. Lancet Psychiatry. 2015;2(4):305–13. PMID: 26360083.26360083
81 Lysaker PH, Davis LW, Bryson GJ, . Effects of cognitive behavioral therapy on work outcomes in vocational rehabilitation for participants with schizophrenia spectrum disorders. Schizophr Res. 2009 Feb;107(2–3):186–91. doi: 10.1016/j.schres.2008.10.018. PMID: 19046856.19046856
82 Malik N, Kingdon D, Pelton J, . Effectiveness of brief cognitive-behavioral therapy for schizophrenia delivered by mental health nurses: relapse and recovery at 24 months. J Clin Psychiatry. 2009 Feb;70(2):201–7. PMID: 19210949.19210949
83 Zimmer M, Duncan AV, Laitano D, . A twelve-week randomized controlled study of the cognitive-behavioral integrated psychological therapy program: positive effect on the social functioning of schizophrenic patients. Rev Bras Psiquiatr. 2007 Jun;29(2):140–7. PMID: 17650536.17650536
84 Wykes T, Huddy V, Cellard C, . A meta-analysis of cognitive remediation for schizophrenia: methodology and effect sizes. Am J Psychiatry. 2011 May;168(5):472–85. doi: 10.1176/appi.ajp.2010.10060855. PMID: 21406461.21406461
85 Cella M, Preti A, Edwards C, . Cognitive remediation for negative symptoms of schizophrenia: A network meta-analysis. Clin Psychol Rev. 2017 Mar;52:43–51. doi: 10.1016/j.cpr.2016.11.009. PMID: 27930934.27930934
86 Deste G, Barlati S, Cacciani P, . Persistence of effectiveness of cognitive remediation interventions in schizophrenia: a 1-year follow-up study. Schizophr Res. 2015 Feb;161(2–3):403–6. doi: 10.1016/j.schres.2014.12.004. PMID: 25533593.25533593
87 Farreny A, Aguado J, Ochoa S, . REPYFLEC cognitive remediation group training in schizophrenia: looking for an integrative approach. Schizophr Res. 2012 Dec;142(1–3):137–44. doi: 10.1016/j.schres.2012.08.035. PMID: 23017827.23017827
88 Mueller DR, Schmidt SJ, Roder V. One-year randomized controlled trial and follow-up of integrated neurocognitive therapy for schizophrenia outpatients. Schizophr Bull. 2015 May;41(3):604–16. doi: 10.1093/schbul/sbu223. PMID: 25713462.25713462
89 Twamley EW, Vella L, Burton CZ, . Compensatory cognitive training for psychosis: effects in a randomized controlled trial. J Clin Psychiatry. 2012 Sep;73(9):1212–9. doi: 10.4088/JCP.12m07686. PMID: 22939029.22939029
90 Vita A, De Peri L, Barlati S, . Effectiveness of different modalities of cognitive remediation on symptomatological, neuropsychological, and functional outcome domains in schizophrenia: a prospective study in a real-world setting. Schizophr Res. 2011 Dec;133(1–3):223–31. doi: 10.1016/j.schres.2011.08.010. PMID: 21907544.21907544
91 Pharoah F, Mari J, Rathbone J, . Family intervention for schizophrenia. Cochrane Database Syst Rev. 2010 Dec 08(12):CD000088. doi: 10.1002/14651858.CD000088.pub2. PMID: 21154340.21154340
92 Dyck DG, Short RA, Hendryx MS, . Management of negative symptoms among patients with schizophrenia attending multiple-family groups. Psychiatr Serv. 2000 Apr;51(4):513–9. PMID: 10737828.10737828
93 Garety PA, Fowler DG, Freeman D, . Cognitive--behavioural therapy and family intervention for relapse prevention and symptom reduction in psychosis: randomised controlled trial. Br J Psychiatry. 2008 Jun;192(6):412–23. doi: 10.1192/bjp.bp.107.043570. PMID: 18515890.18515890
94 Kopelowicz A, Zarate R, Wallace CJ, . The ability of multifamily groups to improve treatment adherence in Mexican Americans with schizophrenia. Arch Gen Psychiatry. 2012 Mar;69(3):265–73. doi: 10.1001/archgenpsychiatry.2011.135. PMID: 22393219.22393219
95 Sellwood W, Barrowclough C, Tarrier N, . Needs-based cognitive-behavioural family intervention for carers of patients suffering from schizophrenia: 12-month follow-up. Acta Psychiatr Scand. 2001 Nov;104(5):346–55. PMID: 11722315.11722315
96 Mayoral F, Berrozpe A, de la Higuera J, . Efficacy of a family intervention program for prevention of hospitalization in patients with schizophrenia. A naturalistic multicenter controlled and randomized study in Spain. Rev Psiquiatr Salud Ment. 2015 Apr–Jun;8(2):83–91. doi: 10.1016/j.rpsm.2013.11.001. PMID: 25017624.25017624
97 Valencia M, Rascon ML, Juarez F, . A psychosocial skills training approach in Mexican out-patients with schizophrenia. Psychol Med. 2007 Oct;37(10):1393–402. PMID: 17472761.17472761
98 Marshall M, Gray A, Lockwood A, . Case management for people with severe mental disorders. Cochrane Database Syst Rev. 2000b(2):Cd000050. doi: 10.1002/14651858.cd000050. PMID: 10796288.10796288
99 Bjorkman T, Hansson L, Sandlund M. Outcome of case management based on the strengths model compared to standard care. A randomised controlled trial. Soc Psychiatry Psychiatr Epidemiol. 2002 Apr;37(4):147–52. PMID: 12027240.12027240
100 Zou H, Li Z, Nolan MT, . Self-management education interventions for persons with schizophrenia: a meta-analysis. Int J Ment Health Nurs. 2013 Jun;22(3):256–71. doi: 10.1111/j.1447-0349.2012.00863.x. PMID: 22882803.22882803
101 Hasson-Ohayon I, Roe D, Kravetz S. A randomized controlled trial of the effectiveness of the illness management and recovery program. Psychiatr Serv. 2007 Nov;58(11):1461–6. doi: 10.1176/ps.2007.58.11.1461. PMID: 17978257.17978257
102 Pekkala E, Merinder L. Psychoeducation for schizophrenia. Cochrane Database Syst Rev. 2002(2):Cd002831. doi: 10.1002/14651858.cd002831. PMID: 12076455.12076455
103 Bartels SJ, Pratt SI, Mueser KT, . Long-term outcomes of a randomized trial of integrated skills training and preventive healthcare for older adults with serious mental illness. Am J Geriatr Psychiatry. 2014 Nov;22(11):1251–61. doi: 10.1016/j.jagp.2013.04.013. PMID: 23954039.23954039
104 Mueser KT, Pratt SI, Bartels SJ, . Randomized trial of social rehabilitation and integrated health care for older people with severe mental illness. J Consult Clin Psychol. 2010 Aug;78(4):561–73. doi: 10.1037/a0019629. PMID: 20658812.20658812
105 Valencia M, Fresan A, Juarez F, . The beneficial effects of combining pharmacological and psychosocial treatment on remission and functional outcome in outpatients with schizophrenia. J Psychiatr Res. 2013 Dec;47(12):1886–92. doi: 10.1016/j.jpsychires.2013.09.006. PMID: 24112947.24112947
106 Kinoshita Y, Furukawa TA, Kinoshita K, . Supported employment for adults with severe mental illness. Cochrane Database Syst Rev. 2013 Sep 13(9):Cd008297. doi: 10.1002/14651858.CD008297.pub2. PMID: 24030739.24030739
107 Cook JA, Blyler CR, Burke-Miller JK, . Effectiveness of supported employment for individuals with schizophrenia: results of a multi-site, randomized trial. Clin Schizophr Relat Psychoses. 2008;2(1):37–46.
108 Cook JA, Leff HS, Blyler CR, . Results of a multisite randomized trial of supported employment interventions for individuals with severe mental illness. Arch Gen Psychiatry. 2005 May;62(5):505–12. PMID: 15867103.15867103
109 Mueser KT, Clark RE, Haines M, . The Hartford study of supported employment for persons with severe mental illness. J Consult Clin Psychol. 2004 Jun;72(3):479–90. doi: 10.1037/0022-006x.72.3.479. PMID: 15279531.15279531
110 Buckley LA, Maayan N, Soares-Weiser K, . Supportive therapy for schizophrenia. Cochrane Database Syst Rev. 2015 Apr 14(4):Cd004716. doi: 10.1002/14651858.CD004716.pub4. PMID: 25871462.25871462
111 Bertelsen M, Jeppesen P, Petersen L, . Course of illness in a sample of 265 patients with first-episode psychosis—five-year follow-up of the Danish OPUS trial. Schizophr Res. 2009;107(2–3):173–8. doi: 10.1016/j.schres.2008.09.018. PMID: 18945593.18945593
112 Craig TK, Garety P, Power P, . The Lambeth Early Onset (LEO) team: randomised controlled trial of the effectiveness of specialised care for early psychosis. BMJ. 2004 Nov 6;329(7474):1067. doi: 10.1136/bmj.38246.594873.7C. PMID: 15485934.15485934
113 Garety PA, Craig TK, Dunn G, . Specialised care for early psychosis: symptoms, social functioning and patient satisfaction: randomised controlled trial. Br J Psychiatry. 2006 Jan;188:37–45. doi: 10.1192/bjp.bp.104.007286. PMID: 16388068.16388068
114 Guo X, Zhai J, Liu Z, . Effect of antipsychotic medication alone vs combined with psychosocial intervention on outcomes of early-stage schizophrenia: a randomized, 1-year study. Arch Gen Psychiatry. 2010 Sep;67(9):895–904. doi: 10.1001/archgenpsychiatry.2010.105. PMID: 20819983.20819983
115 Guo X, Zhao J, Liu Z, . Antipsychotic combination with psychosocial intervention on outcome of schizophrenia (acpios): rationale and design of the clinical trial. Clin Schizophr Relat Psychoses. 2007;1(2):185–92.
116 Kane JM, Robinson DG, Schooler NR, . Comprehensive versus usual community care for first-episode psychosis: 2-year outcomes from the NIMH RAISE early treatment program. Am J Psychiatry. 2016 Apr 1;173(4):362–72. doi: 10.1176/appi.ajp.2015.15050632. PMID: 26481174.26481174
117 Kane JM, Schooler NR, Marcy P, . The RAISE early treatment program for first-episode psychosis: background, rationale, and study design. J Clin Psychiatry. 2015 Mar;76(3):240–6. doi: 10.4088/JCP.14m09289. PMID: 25830446.25830446
118 Secher RG, Hjorthoj CR, Austin SF, . Ten-year follow-up of the OPUS specialized early intervention trial for patients with a first episode of psychosis. Schizophr Bull. 2015 May;41(3):617–26. doi: 10.1093/schbul/sbu155. PMID: 25381449.25381449
119 Tempier R, Balbuena L, Garety P, . Does assertive community outreach improve social support? Results from the Lambeth study of early-episode psychosis. Psychiatr Serv. 2012 Mar;63(3):216–22. doi: 10.1176/appi.ps.20110013. PMID: 22388528.22388528
120 Hunt GE, Siegfried N, Morley K, . Psychosocial interventions for people with both severe mental illness and substance misuse. Cochrane Database Syst Rev. 2013 Oct 03(10):Cd001088. doi: 10.1002/14651858.CD001088.pub3. PMID: 24092525.24092525
121 Lieberman JA, Stroup TS, McEvoy JP, . Effectiveness of antipsychotic drugs in patients with chronic schizophrenia. N Engl J Med. 2005 Sep 22;353(12):1209–23. doi: 10.1056/NEJMoa051688. PMID: 16172203.16172203
122 McEvoy JP, Lieberman JA, Stroup TS, . Effectiveness of clozapine versus olanzapine, quetiapine, and risperidone in patients with chronic schizophrenia who did not respond to prior atypical antipsychotic treatment. Am J Psychiatry. 2006 Apr;163(4):600–10. PMID: 16585434.16585434
123 Stroup TS, Lieberman JA, McEvoy JP, . Effectiveness of olanzapine, quetiapine, and risperidone in patients with chronic schizophrenia after discontinuing perphenazine: a CATIE study. Am J Psychiatry. 2007 Mar;164(3):415–27. PMID: 17329466.17329466
124 Stroup TS, Lieberman JA, McEvoy JP, . Effectiveness of olanzapine, quetiapine, risperidone, and ziprasidone in patients with chronic schizophrenia following discontinuation of a previous atypical antipsychotic. Am J Psychiatry. 2006 Apr;163(4):611–22. PMID: 16585435.16585435
125 Stroup TS, Lieberman JA, McEvoy JP, . Results of phase 3 of the CATIE schizophrenia trial. Schizophr Res. 2009 Jan;107(1):1–12. PMID: 19027269.19027269
126 Manschreck TC, Boshes RA. The CATIE schizophrenia trial: results, impact, controversy. Harv Rev Psychiatry. 2007 Sep–Oct;15(5):245–58. PMID: 17924259.17924259
127 Teich J. The CATIE study. Am J Psychiatry. 2006 Mar;163(3):554–5; author reply 5–6. PMID: 16513894.16513894
128 Weiden PJ. Discontinuing and switching antipsychotic medications: understanding the CATIE schizophrenia trial. J Clin Psychiatry. 2007;68(Suppl1):12–9. PMID: 17286523.17286523
129 Jerrell JM. Cost-effectiveness of risperidone, olanzapine, and conventional antipsychotic medications. Schizophr Bull. 2002;28(4):589–605. PMID: 1279549312795493
130 Ciudad A, Olivares JM, Bousono M, . Improvement in social functioning in outpatients with schizophrenia with prominent negative symptoms treated with olanzapine or risperidone in a 1 year randomized, open-label trial. Prog Neuropsychopharmacol Biol Psychiatry. 2006 Dec 30;30(8):1515–22. PMID: 16820255.16820255
131 Haro J, . Effectiveness of antipsychotic treatment for schizophrenia: 6-month results of the Pan-European Schizophrenia Outpatient Health Outcomes (SOHO) study. Acta Psychiatr Scand. 2005;111:220–31. doi: 10.1111/j.1600-0447.2004.00450.x PMID: 1570110715701107
132 Harvey PD, Patterson TL, Potter LS, . Improvement in social competence with short-term atypical antipsychotic treatment: a randomized, double-blind comparison of quetiapine versus risperidone for social competence, social cognition, and neuropsychological functioning. Am J Psychiatry. 2006 Nov;163(11):1918–25. PMID: 17074943.17074943
133 Zhong KX, Sweitzer DE, Hamer RM, . Comparison of quetiapine and risperidone in the treatment of schizophrenia: a randomized, double-blind, flexible-dose, 8-week study. J Clin Psychiatry. 2006 Jul;67(7):1093–103. PMID: 16889453.16889453
134 Wahlbeck K, Cheine M, Tuisku K, . Risperidone versus clozapine in treatment-resistant schizophrenia: a randomized pilot study. Prog Neuropsychopharmacol Biol Psychiatry. 2000a;24(6):911–22. PMID: 11041534.11041534
135 Meltzer HY, Bobo WV, Nuamah IF, . Efficacy and tolerability of oral paliperidone extended-release tablets in the treatment of acute schizophrenia: pooled data from three 6-week, placebo-controlled studies. J Clin Psychiatry. 2008 May;69(5):817–29. PMID: 18466043.18466043
136 Li H, Rui Q, Ning X, . A comparative study of paliperidone palmitate and risperidone long-acting injectable therapy in schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2011 Jun 1;35(4):1002–8. doi: 10.1016/j.pnpbp.2011.02.001. PMID: 21315787.21315787
137 Takekita Y, Koshikawa Y, Fabbri C, . Cognitive function and risperidone long-acting injection vs. paliperidone palmitate in schizophrenia: a 6-month, open-label, randomized, pilot trial. BMC Psychiatry. 2016 May 29;16:172. doi: 10.1186/s12888-016-0883-9. PMID: 27236412.27236412
138 Rouillon F, Eriksson L, Burba B, . Functional recovery results from the risperidone long-acting injectable versus quetiapine relapse prevention trial (ConstaTRE). Acta Neuropsychiatr. 2013;25(5):297–306. doi: 10.1017/neu.2013.7 PMID: 25287730.25287730
139 Resnick SG, Rosenheck RA, Canive JM, . Employment outcomes in a randomized trial of second-generation antipsychotics and perphenazine in the treatment of individuals with schizophrenia. J Behav Health Serv Res. 2008 Apr;35(2):215–25. PMID: 18246429.18246429
140 Alonso J, Croudace T, Brown J, . Health-related quality of life (HRQL) and continuous antipsychotic treatment: 3-year results from the Schizophrenia Health Outcomes (SOHO) study. Value Health. 2009 Jun;12(4):536–43. PMID: 19900255.19900255
141 Ritsner M, Gibel A, Perelroyzen G, . Quality of life outcomes of risperidone, olanzapine, and typical antipsychotics among schizophrenia patients treated in routine clinical practice: a naturalistic comparative study. J Clin Psychopharmacol. 2004;24(6):582–91. PMID: 15538118.15538118
142 Bond GR, Kim HW, Meyer PS, . Response to vocational rehabilitation during treatment with first- or second-generation antipsychotics. Psychiatr Serv. 2004;55(1):59–66. doi: 10.1176/appi.ps.55.1.59 PMID: 14699202.14699202
143 Miller DD, Caroff SN, Davis SM, . Extrapyramidal side-effects of antipsychotics in a randomised trial. Br J Psychol. 2008 Oct;193(4):279–88. PMID: 18827289.18827289
144 Kinon BJ, Noordsy DL, Liu-Seifert H, . Randomized, double-blind 6-month comparison of olanzapine and quetiapine in patients with schizophrenia or schizoaffective disorder with prominent negative symptoms and poor functioning. J Clin Psychopharmacol. 2006 Oct;26(5):453–61. PMID: 16974184.16974184
145 Gasquet I, . Pharmacological treatment and other predictors of treatment outcomes in previously untreated patients with schizophrenia: results from the European Schizophrenia Outpatient Health Outcomes (SOHO) study. Int Clin Psychopharmacol. 2005 Jul;20:199–205. PMID: 1593348015933480
146 Kraemer S, Chartier F, Augendre-Ferrante B, . Effectiveness of two formulations of oral olanzapine in patients with schizophrenia or bipolar disorder in a natural setting: results from a 1-year European observational study. Hum Psychopharmacol. 2012 May;27(3):284–94. doi: 10.1002/hup.2224. PMID: 22473831.22473831
147 Kane J, Honigfeld G, Singer J, . Clozapine for the treatment-resistant schizophrenic. Arch Gen Psychiatry. 1988;45(9):789–96. PMID: 30465533046553
148 Addington DE, Pantelis C, Dineen M, . Efficacy and tolerability of ziprasidone versus risperidone in patients with acute exacerbation of schizophrenia or schizoaffective disorder: an 8-week, double-blind, multicenter trial. J Clin Psychiatry. 2004 Dec;65(12):1624–33. PMID: 1564186715641867
149 Alvarez E, Ciudad A, Olivares JM, . A randomized, 1-year follow-up study of olanzapine and risperidone in the treatment of negative symptoms in outpatients with schizophrenia. J Clin Psychopharmacol. 2006 Jun;26(3):238–49. PMID: 16702888.16702888
150 Apiquian R, Fresan A, Herrera K, . Minimum effective doses of haloperidol for the treatment of first psychotic episode: a comparative study with risperidone and olanzapine. Int J Neuropsychopharmacol. 2003 Dec;6(4):403–8. PMID: 14604455.14604455
151 Azorin JM, Spiegel R, Remington G, . A double-blind comparative study of clozapine and risperidone in the management of severe chronic schizophrenia. Am J Psychiatry. 2001;158(8):1305–13. doi: 10.1176/appi.ajp.158.8.1305 PMID: 1148116711481167
152 Bitter I, Dossenbach MR, Brook S, . Olanzapine versus clozapine in treatment-resistant or treatment-intolerant schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2004 Jan;28(1):173–80. doi: 10.1016/j.pnpbp.2003.09.033 PMID: 14687871.14687871
153 Bondolfi G, Dufour H, Patris M, . Risperidone versus clozapine in treatment-resistant chronic schizophrenia: a randomized double-blind study. The Risperidone study group. Am J Psychiatry. 1998;155(4):499–504. doi: 10.1176/ajp.155.4.499 PMID: 95459959545995
154 Buchanan RW, Panagides J, Zhao J, . Asenapine versus olanzapine in people with persistent negative symptoms of schizophrenia. J Clin Psychopharmacol. 2012 Feb;32(1):36–45. doi: 10.1097/JCP.0b013e31823f880a. PMID: 22198451.22198451
155 Chan H-Y, Lin W-W, Lin S-K, . Efficacy and safety of aripiprazole in the acute treatment of schizophrenia in Chinese patients with risperidone as an active control: a randomized trial. J Clin Psychiatry. 2007 Jan;68(1):29–36. PMID: 17284127.17284127
156 Chowdhury AN, Mukherjee A, Ghosh K, . Horizon of a new hope: recovery of schizophrenia in India. IMJ. 1999;6(3):181–5.
157 Conley RR, Mahmoud R. A randomized double-blind study of risperidone and olanzapine in the treatment of schizophrenia or schizoaffective disorder.[erratum appears in Am J Psychiatry 2001 Oct;158(10):1759]. Am J Psychiatry. 2001;158(5):765–74. doi: 10.1176/appi.ajp.158.5.765 PMID: 11329400.11329400
158 Conley RR, Kelly DL, Nelson MW, . Risperidone, quetiapine, and fluphenazine in the treatment of patients with therapy-refractory schizophrenia. Clin Neuropharmacol. 2005 Jul–Aug;28(4):163–8. PMID: 1606209416062094
159 Crespo-Facorro B, Perez-Iglesias R, Ramirez-Bonilla M, . A practical clinical trial comparing haloperidol, risperidone, and olanzapine for the acute treatment of first-episode nonaffective psychosis. J Clin Psychiatry. 2006 11/21/2007;67(10):1511–21. PMID: 17107241.17107241
160 Fleischhacker WW, McQuade RD, Marcus RN, . A double-blind, randomized comparative study of aripiprazole and olanzapine in patients with schizophrenia. Biol Psychiatry. 2009 Mar 15;65(6):510–7. PMID: 18986646.18986646
161 Grootens KP, van Veelen NMJ, Peuskens J, . Ziprasidone vs olanzapine in recent-onset schizophrenia and schizoaffective disorder: results of an 8-week double-blind randomized controlled trial. Schizophr Res. 2011 Mar;37(2):352–61. doi: 10.1093/schbul/sbp037. PMID: 19542525.19542525
162 Gureje O, Miles W, Keks N, . Olanzapine vs risperidone in the management of schizophrenia: a randomized double-blind trial in Australia and New Zealand. Schizophr Res. 2003;61(2–3):303–14. PMID: 1272988212729882
163 Jeste DV, Barak Y, Madhusoodanan S, . International multisite double-blind trial of the atypical antipsychotics risperidone and olanzapine in 175 elderly patients with chronic schizophrenia. Am J Geriatr Psychiatry. 2003;11(6):638–47. PMID: 14609804.14609804
164 Kane JM, Osuntokun O, Kryzhanovskaya LA, . A 28-week, randomized, double-blind study of olanzapine versus aripiprazole in the treatment of schizophrenia. J Clin Psychiatry. 2009 Apr;70(4):572–81. PMID: 19323965.19323965
165 Keefe R, . One-year double-blind study of the neurocognitive efficacy of olanzapine, risperidone, and haloperidol in schizophrenia. Schizophr Res. 2006;81:1–15. doi: 10.1016/j.schres.2005.07.038 PMID: 16202565.16202565
166 Keks NA, Ingham M, Khan A, . Long-acting injectable risperidone v. olanzapine tablets for schizophrenia or schizoaffective disorder. Randomised, controlled, open-label study. Br J Psychol. 2007;191:131–9. doi: 10.1192/bjp.bp.105.017020 PMID: 17666497.17666497
167 Li YM, Zhao JP, Ou JJ, . Efficacy and tolerability of ziprasidone vs. olanzapine in naive first-episode schizophrenia: a 6-week, randomized, open-label, flexible-dose study. Pharmacopsychiatry. 2012 Jul;45(5):177–81. doi: 10.1055/s-0031-1299769. PMID: 22290206.22290206
168 McCue RE, Waheed R, Urcuyo L, . Comparative effectiveness of second-generation antipsychotics and haloperidol in acute schizophrenia. Br J Psychol. 2006 Nov;189:433–40. PMID: 17077434.17077434
169 McEvoy JP, Lieberman JA, Perkins DO, . Efficacy and tolerability of olanzapine, quetiapine, and risperidone in the treatment of early psychosis: a randomized, double-blind 52-week comparison. Am J Psychiatry. 2007 Jul;164(7):1050–60. PMID: 17606657.17606657
170 McQuade RD, Stock E, Marcus R, . A comparison of weight change during treatment with olanzapine or aripiprazole: results from a randomized, double-blind study. J Clin Psychiatry. 2004;65 Suppl 18:47–56. PMID: 15600384.15600384
171 Newcomer JW, Ratner RE, Eriksson JW, . A 24-week, multicenter, open-label, randomized study to compare changes in glucose metabolism in patients with schizophrenia receiving treatment with olanzapine, quetiapine, or risperidone. J Clin Psychiatry. 2009 Apr;70(4):487–99. PMID: 19358783.19358783
172 Potkin SG, Gharabawi GM, Greenspan AJ, . A double-blind comparison of risperidone, quetiapine and placebo in patients with schizophrenia experiencing an acute exacerbation requiring hospitalization. Schizophr Res. 2006 Jul;85(1–3):254–65. PMID: 16797162.16797162
173 Robinson DG, Woerner MG, Napolitano B, . Randomized comparison of olanzapine versus risperidone for the treatment of first-episode schizophrenia: 4-month outcomes. Am J Psychiatry. 2006 Dec;163(12):2096–102. PMID: 17151160.17151160
174 Sacchetti E, Valsecchi P, Parrinello G, . A randomized, flexible-dose, quasi-naturalistic comparison of quetiapine, risperidone, and olanzapine in the short-term treatment of schizophrenia: the QUERISOLA trial. Schizophr Res. 2008 Jan;98(1–3):55–65. PMID: 17933497.17933497
175 Savitz AJ, Lane R, Nuamah I, . Efficacy and safety of paliperidone extended release in adolescents with schizophrenia: a randomized, double-blind study. J Am Acad Child Adolesc Psychiatry. 2015;54(2):126–37.e1. PMID: 25617253.25617253
176 Schoemaker J, Stet L, Vrijland P, . Long-term efficacy and safety of asenapine or olanzapine in patients with schizophrenia or schizoaffective disorder: an extension study. Pharmacopsychiatry. 2012 Jul;45(5):196–203. doi: 10.1055/s-0031-1301310. PMID: 22454251.22454251
177 Schreiner A, Niehaus D, Shuriquie NA, . Metabolic effects of paliperidone extended release versus oral olanzapine in patients with schizophrenia: a prospective, randomized, controlled trial. J Clin Psychopharmacol. 2012 Aug;32(4):449–57. doi: 10.1097/JCP.0b013e31825cccad. PMID: 22722501.22722501
178 Simpson GM, Glick ID, Weiden PJ, . Randomized, controlled, double-blind multicenter comparison of the efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. Am J Psychiatry. 2004 Oct;161(10):1837–47. doi: 10.1176/ajp.161.10.1837 PMID: 15465981.15465981
179 Suzuki T, Uchida H, Watanabe K, . How effective is it to sequentially switch among olanzapine, quetiapine and risperidone?--A randomized, open-label study of algorithm-based antipsychotic treatment to patients with symptomatic schizophrenia in the real-world clinical setting. Psychopharmacology (Berl). 2007 Dec;195(2):285–95. PMID: 17701027.17701027
180 Tollefson GD, Birkett MA, Kiesler GM, . Double-blind comparison of olanzapine versus clozapine in schizophrenic patients clinically eligible for treatment with clozapine. Biol Psychiatry. 2001;49(1):52–63. PMID: 1116378011163780
181 Tran PV, Hamilton SH, Kuntz AJ, . Double-blind comparison of olanzapine versus risperidone in the treatment of schizophrenia and other psychotic disorders. J Clin Psychopharmacol. 1997;17(5):407–18. PMID: 9315992.9315992
182 van Bruggen J, Tijssen J, Dingemans P, . Symptom response and side-effects of olanzapine and risperidone in young adults with recent onset schizophrenia. Int Clin Psychopharmacol. 2003;18(6):341–6. doi: 10.1097/01.yic.0000097037.25861.df PMID: 14571154.14571154
183 Samara MT, Dold M, Gianatsi M, . Efficacy, acceptability, and tolerability of antipsychotics in treatment-resistant schizophrenia: a network meta-analysis. JAMA Psychiatry. 2016 Mar;73(3):199–210. doi: 10.1001/jamapsychiatry.2015.2955. PMID: 26842482.26842482
184 AstraZeneca. A multicenter, open-label, flexible-dose, parallel-group evaluation of the cataractogenic potential of quetiapine fumarate (Seroquel) and risperidone (Risperdal) in the Long-term treatment of patients with schizophrenia or schizoaffective disorder [CLEARS]. Clinical Study Report Synopsis. 2010.
185 AstraZeneca. An 8-week, multicenter, double-blind, randomized, parallel-group, placebo-controlled study of the efficacy and safety of quetiapine fumarate (SEROQUEL) extended-release in children and adolescent subjects with bipolar depression. Clinical Study Report Synopsis. 2011 31 May 2011;D144AC00001.
186 Mullen J, Jibson MD, Sweitzer D. A comparison of the relative safety, efficacy, and tolerability of quetiapine and risperidone in outpatients with schizophrenia and other psychotic disorders: the quetiapine experience with safety and tolerability (QUEST) study. Clin Ther. 2001;23(11):1839–54. PMID: 11768836.11768836
187 Schoemaker J, Naber D, Vrijland P, . Long-term assessment of asenapine vs. olanzapine in patients with schizophrenia or schizoaffective disorder.[Erratum appears in Pharmacopsychiatry. 2011 Nov;44(7):343]. Pharmacopsychiatry. 2010 Jun;43(4):138–46. doi: 10.1055/s-0030-1248313. PMID: 20205074.20205074
188 Fleischhacker W, Gopal S, Lane R, . A randomized trial of paliperidone palmitate and risperidone long-acting injectable in schizophrenia. Int J Neuropsychopharmacol. 2012 Feb;15(1):107–18. doi: 10.1017/S1461145711001076. PMID: 21777507.21777507
189 Pasternak B, Svanstrom H, Ranthe MF, . Atypical antipsychotics olanzapine, quetiapine, and risperidone and risk of acute major cardiovascular events in young and middle-aged adults: a nationwide register-based cohort study in Denmark. CNS Drugs. 2014 Oct;28(10):963–73. doi: 10.1007/s40263-014-0176-0. PMID: 24895158.24895158
190 Kiviniemi M, Suvisaari J, Koivumaa-Honkanen H, . Antipsychotics and mortality in first-onset schizophrenia: prospective Finnish register study with 5-year follow-up. Schizophr Res. 2013 Oct;150(1):274–80. doi: 10.1016/j.schres.2013.07.043. PMID: 23953217.23953217
191 Kelly DL, McMahon RP, Liu F, . Cardiovascular disease mortality in patients with chronic schizophrenia treated with clozapine: a retrospective cohort study. J Clin Psychiatry. 2010 Mar;71(3):304–11. doi: 10.4088/JCP.08m04718yel. PMID: 20079332.20079332
192 Meltzer HY, Alphs L, Green AI, . Clozapine treatment for suicidality in schizophrenia: International Suicide Prevention Trial (InterSePT). Arch Gen Psychiatry. 2003;60(1):82–91. PMID: 1251117512511175
193 Bitter I, Katona L, Zambori J, . Comparative effectiveness of depot and oral second generation antipsychotic drugs in schizophrenia: a nationwide study in Hungary. Eur Neuropsychopharmacol. 2013 Nov;23(11):1383–90. doi: 10.1016/j.euroneuro.2013.02.003. PMID: 23477752.23477752
194 Leucht S, Cipriani A, Spineli L, . Comparative efficacy and tolerability of 15 antipsychotic drugs in schizophrenia: a multiple-treatments meta-analysis. Lancet. 2013 Sep 14;382(9896):951–62. doi: 10.1016/S0140-6736(13)60733-3. PMID: 23810019.23810019
195 Hermes E, Rosenheck R. Choice of randomization to clozapine versus other second generation antipsychotics in the CATIE schizophrenia trial. J Clin Psychopharmacol. 2012 Sep;26(9):1194–200. doi: 10.1177/0269881112443744. PMID: 22516668.22516668
196 AstraZeneca. (D1444C00132-EMBOLDEN II) A 6-week, international, multicenter, double-blind, doubledummy, randomized comparison of the efficacy and safety of sustained-release formulation quetiapine fumarate (SEROQUEL™ ) and placebo in the treatment of acutely ill patients with schizophrenia. 2007.
197 Breier A, . Olanzapine versus ziprasidone: results of a 28-week double-blind study in patients with schizophrenia. Am J Psychiatry. 2005 Oct;162:1879–87. doi: 10.1176/appi.ajp.162.10.1879 PMID: 16199834.16199834
198 Canuso CM, Dirks B, Carothers J, . Randomized, double-blind, placebo-controlled study of paliperidone extended-release and quetiapine in inpatients with recently exacerbated schizophrenia. Am J Psychiatry. 2009 Jun;166(6):691–701. PMID: 19411369.19411369
199 Chue P, Eerdekens M, Augustyns I, . Comparative efficacy and safety of long-acting risperidone and risperidone oral tablets. Eur Neuropsychopharmacol. 2005 Jan;15(1):111–7. doi: 10.1016/j.euroneuro.2004.07.003 PMID: 1557228015572280
200 Citrome L, Cucchiaro J, Sarma K, . Long-term safety and tolerability of lurasidone in schizophrenia: a 12-month, double-blind, active-controlled study. Int Clin Psychopharmacol. 2012 May;27(3):165–76. doi: 10.1097/YIC.0b013e32835281ef. PMID: 22395527.22395527
201 Cutler AJ, Kalali AH, Weiden PJ, . Four-week, double-blind, placebo- and ziprasidone-controlled trial of iloperidone in patients with acute exacerbations of schizophrenia. J Clin Psychopharmacol. 2008 Apr;28(2 Suppl 1):S20–8. PMID: 18334909.18334909
202 Davidson M, Emsley R, Kramer M, . Efficacy, safety and early response of paliperidone extended-release tablets (paliperidone ER): results of a 6-week, randomized, placebo-controlled study. Schizophr Res. 2007 Jul;93(1–3):117–30. PMID: 17466492.17466492
203 Emsley R, Lambert T, McGrath J, . Risperidone in the treatment of first-episode psychotic patients: a double-blind multicenter study. Schizophr Bull. 1999;25(4):721–9. PMID: 10667742.10667742
204 Gaebel W, Schreiner A, Bergmans P, . Relapse prevention in schizophrenia and schizoaffective disorder with risperidone long-acting injectable vs quetiapine: results of a long-term, open-label, randomized clinical trial. Neuropsychopharmacology. 2010 Nov;35(12):2367–77. doi: 10.1038/npp.2010.111. PMID: 20686456.20686456
205 Kane J, Canas F, Kramer M, . Treatment of schizophrenia with paliperidone extended-release tablets: a 6-week placebo-controlled trial. Schizophr Res. 2007 Feb;90(1–3):147–61. PMID: 17092691.17092691
206 Kim S-W, Chung Y-C, Lee Y-H, . Paliperidone ER versus risperidone for neurocognitive function in patients with schizophrenia: a randomized, open-label, controlled trial. Int Clin Psychopharmacol. 2012 Sep;27(5):267–74. doi: 10.1097/YIC.0b013e328356acad. PMID: 22809972.22809972
207 Kluge M, Himmerich H, Wehmeier PM, . Sleep propensity at daytime as assessed by Multiple Sleep Latency Tests (MSLT) in patients with schizophrenia increases with clozapine and olanzapine. Schizophr Res. 2012 Mar;135(1–3):123–7. doi: 10.1016/j.schres.2011.12.017. PMID: 22257975.22257975
208 Kluge M, Schuld A, Himmerich H, . Clozapine and olanzapine are associated with food craving and binge eating: results from a randomized double-blind study. J Clin Psychopharmacol. 2007 Dec;27(6):662–6. PMID: 18004133.18004133
209 Kane JM, Detke HC, Naber D, . Olanzapine long-acting injection: a 24-week, randomized, double-blind trial of maintenance treatment in patients with schizophrenia. Am J Psychiatry. 2010 Feb;167(2):181–9. PMID: 20008947.20008947
210 Lindenmayer JP. The efficacy and tolerability of once-daily extended release quetiapine fumarate in hospitalized patients with acute schizophrenia: a 6-week randomized, double-blind, placebo-controlled study. Psychopharmacol Bull. 2008;41(3):11–35. PMID: 18779774.18779774
211 Macfadden W, Ma Y-W, Haskins J, . A prospective study comparing the long-term effectiveness of injectable risperidone long-acting therapy and oral aripiprazole in patients with schizophrenia. Psychiatry. 2010 Nov;7(11):23–31. PMID: 21191530.21191530
212 McDonnell DP, Kryzhanovskaya LA, Zhao F, . Comparison of metabolic changes in patients with schizophrenia during randomized treatment with intramuscular olanzapine long-acting injection versus oral olanzapine. Hum Psychopharmacol. 2011 Aug;26(6):422–33. doi: 10.1002/hup.1225 PMID: 21823172.21823172
213 Meltzer HY, Cucchiaro J, Silva R, . Lurasidone in the treatment of schizophrenia: a randomized, double-blind, placebo- and olanzapine-controlled study. Am J Psychiatry. 2011 Sep;168(9):957–67. doi: 10.1176/appi.ajp.2011.10060907. PMID: 21676992.21676992
214 Naber D, Riedel M, Klimke A, . Randomized double blind comparison of olanzapine vs. clozapine on subjective well-being and clinical outcome in patients with schizophrenia. Acta Psychiatr Scand. 2005 Feb;111(2):106–15. PMID: 15667429.15667429
215 Nakajima S, Takeuchi H, Fervaha G, . Comparative efficacy between clozapine and other atypical antipsychotics on depressive symptoms in patients with schizophrenia: analysis of the CATIE phase 2E data. Schizophr Res. 2015 Feb;161(2–3):429–33. PMID: 25556080.25556080
216 Newcomer JW, Campos JA, Marcus RN, . A multicenter, randomized, double-blind study of the effects of aripiprazole in overweight subjects with schizophrenia or schizoaffective disorder switched from olanzapine. J Clin Psychiatry. 2008 Jul;69(7):1046–56. PMID: 18605811.18605811
217 Alphs L, Bossie CA, Sliwa JK, . Paliperidone palmitate and risperidone long-acting injectable in subjects with schizophrenia recently treated with oral risperidone or other oral antipsychotics. Neuropsychiatr Dis Treat. 2013 Mar;9:341–50. PMID: 23493643.23493643
218 Pandina G, Lane Rd, Gopal S, . A double-blind study of paliperidone palmitate and risperidone long-acting injectable in adults with schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2011 Jan 15;35(1):218–26. doi: 10.1016/j.pnpbp.2010.11.008. PMID: 21092748.21092748
219 Potkin SG, Cohen M, Panagides J. Efficacy and tolerability of asenapine in acute schizophrenia: a placebo- and risperidone-controlled trial. J Clin Psychiatry. 2007 Oct;68(10):1492–500. PMID: 17960962.17960962
220 Potkin SG, Ogasa M, Cucchiaro J, . Double-blind comparison of the safety and efficacy of lurasidone and ziprasidone in clinically stable outpatients with schizophrenia or schizoaffective disorder. Schizophr Res. 2011 Nov;132(2–3):101–7. doi: 10.1016/j.schres.2011.04.008. PMID: 21889878.21889878
221 Potkin SG, Saha AR, Kujawa MJ, . Aripiprazole, an antipsychotic iith a novel mechanism of action, and risperidone vs placebo in patients with schizophrenia and schizoaffective disorder. Arch Gen Psychiatry. 2003b;60(7):681–90. doi: 10.1001/archpsyc.60.7.681 PMID: 12860772.12860772
222 Sacchetti E, Galluzzo A, Valsecchi P, . Ziprasidone vs clozapine in schizophrenia patients refractory to multiple antipsychotic treatments: the MOZART study. Schizophr Res. 2009 May;110(1–3):80–9. PMID: 19269791.19269791
223 Schering Plough. Data on file. (Unpublished Study 25543) A multicenter, double-blind, flexible-dose, 6-month trial comparing the efficacy and safeaty of asenapine with olanzapnie in stable subjects with predominant, persistent negative symptoms of schizophrenia. 2006.
224 Schering Plough. Data on file. (Unpublished Study 25517) Long-term assessment of asenapine versus olanzapine in patients with schizophrenia or schizoaffective disorder. 2006.
225 Schering Plough. (Study 041022) A multicenter, randomized, double-blind, flexible-dose, 6-week trial of the efficacy and safety of asenapine compared with placebo using olanzapine positive control in subjects with an acute exacerbation of schizophrenia. 2006.
226 Simpson G, . Six-month, blinded, multicenter continuation study of ziprasidone versus olanzapine in schizophrenia. Am J Psychiatry. 2005 Aug;162:1535–8. doi: 10.1176/appi.ajp.162.8.1535 PMID: 16055779.16055779
227 Sirota P, Pannet I, Koren A, . Quetiapine versus olanzapine for the treatment of negative symptoms in patients with schizophrenia. Hum Psychopharmacol. 2006 Jun;21(4):227–34. PMID: 16783811.16783811
228 Conley RR, Kelly DL, Richardson CM, . The efficacy of high-dose olanzapine versus clozapine in treatment-resistant schizophrenia: A double-blind, crossover study. J Clin Psychopharmacol. 2003 Dec;23(6):668–71. PMID: 14624201.14624201
229 Daniel DG, Goldberg TE, Weinberger DR, . Different side effect profiles of risperidone and clozapine in 20 outpatients with schizophrenia or schizoaffective disorder: a pilot study. Am J Psychiatry. 1996 Mar;153(3):417–9. doi: 10.1176/ajp.153.3.417 PMID: 8610833.8610833
230 Hatta K, Sato K, Hamakawa H, . Effectiveness of second-generation antipsychotics with acute-phase schizophrenia. Schizophr Res. 2009;113(1):49–55. doi: 10.1016/j.schres.2009.05.030 PMID: 19553086.19553086
231 Kahn RS. Effectiveness of antipsychotic drugs in first-episode schizophrenia and schizophreniform disorder: an open randomized clinical trial. World Psychiatry. 2009;8(Suppl 1):44–5.
232 Krakowski MI, Czobor P, Citrome L, . Atypical antipsychotic agents in the treatment of violent patients with schizophrenia and schizoaffective disorder. Arch Gen Psychiatry. 2006 Jun;63(6):622–9. PMID: 16754835.16754835
233 Lindenmayer JP, Iskander A, Park M, . Clinical and neurocognitive effects of clozapine and risperidone in treatment-refractory schizophrenic patients: a prospective study. J Clin Psychiatry. 1998 Oct;59(10):521–7. PMID: 9818633.9818633
234 Lublin H, Haug H-J, Koponen H, . Ziprasidone versus olanzapine, risperidone or quetiapine in patients with chronic schizophrenia: a 12-week open-label, multicentre clinical trial. World J Biol Psychiatry. 2009;10(4 Pt 3):710–8. doi: 10.1080/15622970802269589. PMID: 18803070.18803070
235 Perez-Iglesias R, Crespo-Facorro B, Amado JA, . A 12-week randomized clinical trial to evaluate metabolic changes in drug-naive, first-episode psychosis patients treated with haloperidol, olanzapine, or risperidone. J Clin Psychiatry. 2007 Nov;68(11):1733–40. PMID: 18052567.18052567
236 Potkin SG, Alphs L, Hsu C, . Predicting suicidal risk in schizophrenic and schizoaffective patients in a prospective two-year trial. Biol Psychiatry. 2003;54(4):444–52. PMID: 12915289.12915289
237 Potkin SG, Litman RE, Torres R, . Efficacy of iloperidone in the treatment of schizophrenia: initial phase 3 studies. J Clin Psychopharmacol. 2008 Apr;28(2 Suppl 1):S4–11. PMID: 18334911.18334911
238 Purdon SE, Jones BD, Stip E, . Neuropsychological change in early phase schizophrenia during 12 months of treatment with olanzapine, risperidone, or haloperidol. The Canadian Collaborative Group for research in schizophrenia. Arch Gen Psychiatry. 2000 Mar;57(3):249–58. PMID: 10711911.10711911
239 Riedel M, . Quetiapine has equivalent efficacy and superior tolerability to risperidone in the treatment of schizophrenia with predominantly negative symptoms. Eur Arch Psychiatry Clin Neurosci. 2005 Nov;255:432–7. doi: 10.1007/s00406-005-0622-6 PMID: 16267634.16267634
240 Ritchie C, . A comparison of the efficacy and safety of olanzapine and risperidone in the treatment of elderly patients with schizophrenia: an open study of six months duration. Int J Geriatr Psychiatry. 2006;21(2):171–9. doi: 10.1002/gps.1446 PMID: 1641645816416458
241 Volavka J, Czobor P, Nolan K, . Overt aggression and psychotic symptoms in patients with schizophrenia treated with clozapine, olanzapine, risperidone, or haloperidol. J Clin Psychopharmacol. 2004 Apr;24(2):225–8. PMID: 15206671.15206671
242 Zhang Y, Dai G. Efficacy and metabolic influence of paliperidone ER, aripiprazole and ziprasidone to patients with first-episode schizophrenia through 52 weeks follow-up in China. Hum Psychopharmacol. 2012 Nov;27(6):605–14. doi: 10.1002/hup.2270. PMID: 24446539.24446539
243 Chrzanowski WK, Marcus RN, Torbeyns A, . Effectiveness of long-term aripiprazole therapy in patients with acutely relapsing or chronic, stable schizophrenia: a 52-week, open-label comparison with olanzapine. Psychopharmacology (Berl). 2006 Dec;189(2):259–66. PMID: 17058105.17058105
244 Perez-Iglesias R, Ortiz-Garcia de la Foz V, Martinez Garcia O, . Comparison of metabolic effects of aripiprazole, quetiapine and ziprasidone after 12 weeks of treatment in first treated episode of psychosis. Schizophr Res. 2014 Oct;159(1):90–4. doi: 10.1016/j.schres.2014.07.045. PMID: 25151200.25151200
245 Hennessy S, Bilker WB, Knauss JS, . Cardiac arrest and ventricular arrhythmia in patients taking antipsychotic drugs: cohort study using administrative data. BMJ. 2002 Nov 09;325(7372):1070. PMID: 12424166.12424166
246 Lambert BL, Cunningham FE, Miller DR, . Diabetes risk associated with use of olanzapine, quetiapine, and risperidone in veterans health administration patients with schizophrenia. Am J Epidemiol. 2006 Oct 1;164(7):672–81. PMID: 16943266.16943266
247 Feldman PD, Kaiser CJ, Kennedy JS, . Comparison of risperidone and olanzapine in the control of negative symptoms of chronic schizophrenia and related psychotic disorders in patients aged 50 to 65 years. J Clin Psychiatry. 2003;64(9):998–1004.14628974
248 Usall J, Suarez D, Haro JM, . Gender differences in response to antipsychotic treatment in outpatients with schizophrenia. Psychiatry Res. 2007 Dec 3;153(3):225–31. PMID: 17681611.17681611
249 Ciliberto N, Bossie CA, Urioste R, . Lack of impact of race on the efficacy and safety of long-acting risperidone versus placebo in patients with schizophrenia or schizoaffective disorder. Int Clin Psychopharmacol. 2005 Jul;20(4):207–12. PMID: 15933481.15933481
250 Opolka J, . Role of ethnicity in predicting antipsychotic medication adherence. Ann Pharmacother. 2003;37:625–30. PMID: 12708934.12708934
251 Kim JH, Kim D, Marder SR. Time to rehospitalization of clozapine versus risperidone in the naturalistic treatment of comorbid alcohol use disorder and schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2008 May 15;32(4):984–8. PMID: 18262321.18262321
252 Swartz MS, Wagner HR, Swanson JW, . The effectiveness of antipsychotic medications in patients who use or avoid illicit substances: results from the CATIE study. Schizophr Res. 2008 Mar;100(1–3):39–52. PMID: 18191383.18191383
253 Akerele E, Levin FR. Comparison of olanzapine to risperidone in substance-abusing individuals with schizophrenia. Am J Addict. 2007 Jul–Aug;16(4):260–8. PMID: 17661193.17661193
254 Kinon B, ed. Improvement of comorbid depression with olanzapine versus ziprasidone treatment in patients with schizophrenia or schizoaffective disorder. Eleventh Biennial Winter Workshop on Schizophrenia; 2004 Feb 7–14; Davos, Switzerland.
255 Addington DE, Labelle A, Kulkarni J, . A comparison of ziprasidone and risperidone in the long-term treatment of schizophrenia: a 44-week, double-blind, continuation study. Can J Psychiatry. 2009 Jan;54(1):46–54. PMID: 19175979.19175979
256 Tollefson GD, Andersen SW. Should we consider mood disturbance in schizophrenia as an important determinant of quality of life? J Clin Psychiatry. 1999b;60(5):23–9. PMID: 1019240410192404
257 Sajatovic M, Mullen JA, Sweitzer DE. Efficacy of quetiapine and risperidone against depressive symptoms in outpatients with psychosis. J Clin Psychiatry. 2002;63(12):1156–63. PMID: 12523876.12523876
258 Zhang J-P, Robinson DG, Gallego JA, . Association of a schizophrenia risk variant at the DRD2 locus with antipsychotic treatment response in first-episode psychosis. Schizophr Bull. 2015 Nov;41(6):1248–55. doi: 10.1093/schbul/sbv116. PMID: 26320194.26320194
259 Boter H, Derks EM, Fleischhacker WW, . Generalizability of the results of efficacy trials in first-episode schizophrenia: comparisons between subgroups of participants of the European First Episode Schizophrenia Trial (EUFEST). J Clin Psychiatry. 2010 Jan;71(1):58–65. PMID: 19852905.19852905
260 Gafoor R, Landau S, Craig TKJ, . Esquire trial: efficacy and adverse effects of quetiapine versus risperidone in first-episode schizophrenia. J Clin Psychopharmacol. 2010 Oct;30(5):600–6. doi: 10.1097/JCP.0b013e3181f198da. PMID: 20814318.20814318
261 Crespo-Facorro B, Ortiz-Garcia de la Foz V, Mata I, . Aripiprazole, ziprasidone and quetiapine in the treatment of first-episode nonaffective psychosis: a 12-week randomized, flexible-dose, open-label trial. Schizophr Res. 2013 Jul;147(2–3):375–82. doi: 10.1016/j.schres.2013.04.014. PMID: 23643328.23643328
262 Lieberman JA. Pathophysiologic mechanisms in the pathogenesis and clinical course of schizophrenia. J Clin Psychiatry. 1999;60 Suppl 12:9–12. PMID: 10372603.10372603
263 Souza JS, Kayo M, Tassell I, . Efficacy of olanzapine in comparison with clozapine for treatment-resistant schizophrenia: evidence from a systematic review and meta-analyses. CNS Spectr. 2013 Apr;18(2):82–9. doi: 10.1017/S1092852912000806. PMID: 23253621.23253621
264 Ranasinghe I, Sin J. A systematic review of evidence-based treatment for individuals with treatment-resistant schizophrenia and a suboptimal response to clozapine monotherapy. Psychosis. 2014 Jul;6(3):253–65. doi: 10.1080/17522439.2013.830319.
265 Ritchie CW, Harrigan S, Mastwyk M, . Predictors of adherence to atypical antipsychotics (risperidone or olanzapine) in older patients with schizophrenia: an open study of 3(1/2) years duration. Int J Geriatr Psychiatry. 2010 Apr;25(4):411–8. doi: 10.1002/gps.2354. PMID: 19946860.19946860
266 Sutton VK, Street JS, Kennedy JS, . Superiority of olanzapine over risperidone in the control of negative symptoms of schizophrenia and related psychotic disorders in older patients. Eur Neuropsychopharmacol. 2001;11:276.
267 Meyer JM, Rosenblatt LC, Kim E, . The moderating impact of ethnicity on metabolic outcomes during treatment with olanzapine and aripiprazole in patients with schizophrenia. J Clin Psychiatry. 2009 Mar;70(3):318–25. PMID: 19192469.19192469
268 Kishi T, Matsuda Y, Matsunaga S, . Aripiprazole for the management of schizophrenia in the Japanese population: a systematic review and meta-analysis of randomized controlled trials. Neuropsychiatr Dis Treat. 2015 Feb;11:419–34. doi: 10.2147/NDT.S78977 PMID: 25759585.25759585
269 Zhang H, Li H, Liu Y, . Safety and efficacy of paliperidone extended-release in Chinese patients with schizophrenia: A 24-week, open-label extension of a randomized, double-blind, placebo-controlled study. Neuropsychiatr Dis Treat. 2016 Jan;12:69–77. doi: 10.2147/NDT.S88875 PMID: 2681167926811679
270 Sevy S, Robinson DG, Sunday S, . Olanzapine vs. risperidone in patients with first-episode schizophrenia and a lifetime history of cannabis use disorders: 16-week clinical and substance use outcomes. Psychiatry Res. 2011 Aug 15;188(3):310–4. doi: 10.1016/j.psychres.2011.05.001. PMID: 21636134.21636134
271 Kim SH, Han DH, Joo SY, . The effect of dopamine partial agonists on the nicotine dependency in patients with schizophrenia. Hum Psychopharmacol. 2010 Mar;25(2):187–90. doi: 10.1002/hup.1089. PMID: 20033907.20033907
272 Dieterich M, Irving CB, Park B, . Intensive case management for severe mental illness. Cochrane Database Syst Rev. 2010 Oct 06(10):Cd007906. doi: 10.1002/14651858.CD007906.pub2. PMID: 20927766.20927766
273 Leucht S, Kane JM, Kissling W, . What does the PANSS mean? Schizophr Res. 2005 Nov 15;79(2–3):231–8. doi: 10.1016/j.schres.2005.04.008. PMID: 15982856.15982856
274 Barrowclough C, Haddock G, Lobban F, . Group cognitive-behavioural therapy for schizophrenia. Randomised controlled trial. Br J Psychiatry. 2006 Dec;189:527–32. PMID: 17139037.17139037
275 Granholm E, McQuaid JR, McClure FS, . A randomized, controlled trial of cognitive behavioral social skills training for middle-aged and older outpatients with chronic schizophrenia. Am J Psychiatry. 2005 Mar;162(3):520–9. PMID: 15741469.15741469
276 Grant PM, Huh GA, Perivoliotis D, . Randomized trial to evaluate the efficacy of cognitive therapy for low-functioning patients with schizophrenia. Arch Gen Psychiatry. 2012 Feb;69(2):121–7. doi: 10.1001/archgenpsychiatry.2011.129. PMID: 21969420.21969420
277 Gumley A, O’Grady M, McNay L, . Early intervention for relapse in schizophrenia: results of a 12-month randomized controlled trial of cognitive behavioural therapy. Psychol Med. 2003 Apr;33(3):419–31. PMID: 12701663.12701663
278 Lincoln TM, Ziegler M, Mehl S, . Moving from efficacy to effectiveness in cognitive behavioral therapy for psychosis: a randomized clinical practice trial. J Consult Clin Psychol. 2012 Aug;80(4):674–86. doi: 10.1037/a0028665. PMID: 22663901.22663901
279 van der Gaag M, Stant AD, Wolters KJ, . Cognitive-behavioural therapy for persistent and recurrent psychosis in people with schizophrenia-spectrum disorder: cost-effectiveness analysis. Br J Psychiatry. 2011 Jan;198(1):59–65, sup 1. doi: 10.1192/bjp.bp.109.071522. PMID: 21200078.21200078
280 Haddock G, Barrowclough C, Shaw JJ, . Cognitive-behavioural therapy v. social activity therapy for people with psychosis and a history of violence: randomised controlled trial. Br J Psychiatry. 2009 Feb;194(2):152–7. doi: 10.1192/bjp.bp.107.039859. PMID: 19182178.19182178
281 Kemp R, Kirov G, Everitt B, . Randomised controlled trial of compliance therapy. 18-month follow-up. Br J Psychiatry. 1998 May;172:413–9. PMID: 9747403.9747403
282 Jackson HJ, McGorry PD, Killackey E, . Acute-phase and 1-year follow-up results of a randomized controlled trial of CBT versus befriending for first-episode psychosis: the ACE project. Psychol Med. 2008 May;38(5):725–35. PMID: 18005494.18005494
283 Karow A, Wittmann L, Schottle D, . The assessment of quality of life in clinical practice in patients with schizophrenia. Dialogues Clin Neurosci. 2014 Jun;16(2):185–95. PMID: 25152657.25152657
284 Lewis S, Tarrier N, Haddock G, . Randomised controlled trial of cognitive-behavioural therapy in early schizophrenia: acute-phase outcomes. Br J Psychiatry Suppl. 2002 Sep;43:s91–7. PMID: 12271807.12271807
285 Sensky T, Turkington D, Kingdon D, . A randomized controlled trial of cognitive-behavioral therapy for persistent symptoms in schizophrenia resistant to medication. Arch Gen Psychiatry. 2000 Feb;57(2):165–72. PMID: 10665619.10665619
286 Tarrier N, Wittkowski A, Kinney C, . Durability of the effects of cognitive-behavioural therapy in the treatment of chronic schizophrenia: 12-month follow-up. Br J Psychiatry. 1999 Jun;174:500–4. doi: 10.1192/bjp.174.6.500. PMID: 10616627.10616627
287 Tarrier N, Yusupoff L, Kinney C, . Randomised controlled trial of intensive cognitive behaviour therapy for patients with chronic schizophrenia. BMJ. 1998 Aug 1;317(7154):303–7. PMID: 9685273.9685273
288 Saperstein AM, Medalia A. The empirical basis for the practice of cognitive remediation for schizophrenia. Neuropsychiatry. 2012;2(2):101–9. doi: 10.2217/npy.12.10.
289 Sellwood W, Wittkowski A, Tarrier N, . Needs-based cognitive-behavioural family intervention for patients suffering from schizophrenia: 5-year follow-up of a randomized controlled effectiveness trial. Acta Psychiatr Scand. 2007 Dec;116(6):447–52. PMID: 17961200.17961200
290 Barrowclough C, Tarrier N, Lewis S, . Randomised controlled effectiveness trial of a needs-based psychosocial intervention service for carers of people with schizophrenia. Br J Psychiatry. 1999 Jun;174:505–11. PMID: 10616628.10616628
291 Lenior ME, Dingemans PM, Linszen DH, . Social functioning and the course of early-onset schizophrenia: five-year follow-up of a psychosocial intervention. Br J Psychiatry. 2001;179:53–8. PMID: 11435269.11435269
292 Bauml J, Pitschel-Walz G, Volz A, . Psychoeducation in schizophrenia: 7-year follow-up concerning rehospitalization and days in hospital in the Munich Psychosis Information Project Study. J Clin Psychiatry. 2007 Jun;68(6):854–61. PMID: 17592908.17592908
293 Kurtz MM, Mueser KT. A meta-analysis of controlled research on social skills training for schizophrenia. J Consult Clin Psychol. 2008 Jun;76(3):491–504. doi: 10.1037/0022-006X.76.3.491. PMID: 18540742.18540742
294 Almerie MQ, Okba Al Marhi M, Jawoosh M, . Social skills programmes for schizophrenia. Cochrane Database Syst Rev. 2015 Jun 09(6):Cd009006. doi: 10.1002/14651858.CD009006.pub2. PMID: 26059249.26059249
295 Dixon LB, Dickerson F, Bellack AS, . The 2009 schizophrenia PORT psychosocial treatment recommendations and summary statements. Schizophr Bull. 2010 Jan;36(1):48–70. doi: 10.1093/schbul/sbp115. PMID: 19955389.19955389
296 Marshall M, Rathbone J. Early intervention for psychosis. Cochrane Database Syst Rev. 2011 Jun 15(6):Cd004718. doi: 10.1002/14651858.CD004718.pub3. PMID: 21678345.21678345
297 Kishimoto T, Robenzadeh A, Leucht C, . Long-acting injectable vs oral antipsychotics for relapse prevention in schizophrenia: a meta-analysis of randomized trials. Schizophr Bull. 2014 Jan;40(1):192–213. doi: 10.1093/schbul/sbs150. PMID: 23256986.23256986
298 Zhang J-P, Gallego JA, Robinson DG, . Efficacy and safety of individual second-generation vs. first generation antipsychotics in first-episode psychosis: a systematic review and meta-analysis. Int J Neuropsychopharmacol. 2013 Jul;16(6):1205–18. doi: 10.1017/S1461145712001277. PMID: 23199972.23199972
299 Fusar-Poli P, Kempton MJ, Rosenheck RA. Efficacy and safety of second-generation long-acting injections in schizophrenia: a meta-analysis of randomized-controlled trials. Int Clin Psychopharmacol. 2013 Mar;28(2):57–66. doi: 10.1097/YIC.0b013e32835b091f. PMID: 23165366.23165366
300 Soares-Weiser K, Bechard-Evans L, Lawson AH, . Time to all-cause treatment discontinuation of olanzapine compared to other antipsychotics in the treatment of schizophrenia: a systematic review and meta-analysis. Eur Neuropsychopharmacol. 2013 Feb;23(2):118–25. doi: 10.1016/j.euroneuro.2012.05.001. PMID: 22633617.22633617
301 Tonin FS, Piazza T, Wiens A, . Adverse events and treatment failure leading to discontinuation of recently approved antipsychotic drugs in schizophrenia: a network meta-analysis. Schizophr Res. 2015 Dec;169(1–3):483–5. doi: 10.1016/j.schres.2015.09.019. PMID: 26516102.26516102
302 Asenjo Lobos C, Komossa K, Rummel-Kluge C, . Clozapine versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2010 Nov 10(11):Cd006633. doi: 10.1002/14651858.CD006633.pub2. PMID: 21069690.21069690
303 Asmal L, Flegar SJ, Wang J, . Quetiapine versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2013 Nov 18(11):Cd006625. doi: 10.1002/14651858.CD006625.pub3. PMID: 24249315.24249315
304 Ayub M, Saeed K, Munshi TA, . Clozapine for psychotic disorders in adults with intellectual disabilities. Cochrane Database Syst Rev. 2015 Sep 23(9):Cd010625. doi: 10.1002/14651858.CD010625.pub2. PMID: 26397173.26397173
305 Kirsch I. Placebo psychotherapy: synonym or oxymoron? J Clin Psychol. 2005 Jul;61(7):791–803. doi: 10.1002/jclp.20126. PMID: 15827992.15827992
306 Chambless DL, Hollon SD. Defining empirically supported therapies. J Consult Clin Psychol. 1998 Feb;66(1):7–18. PMID: 9489259.9489259
307 Jensen PS, Weersing R, Hoagwood KE, . What is the evidence for evidence-based treatments? A hard look at our soft underbelly. Ment Health Serv Res. 2005 Mar;7(1):53–74. PMID: 15832693.15832693
308 Vickers A, Goyal N, Harland R, . Do certain countries produce only positive results? A systematic review of controlled trials. Control Clin Trials. 1998;19(2):159–66. doi: 10.1016/S0197-2456(97)00150-5. PMID: 9551280.9551280
309 Wykes T, Steel C, Everitt B, . Cognitive behavior therapy for schizophrenia: effect sizes, clinical models, and methodological rigor. Schizophr Bull. 2008 May;34(3):523–37. PMID: 17962231.17962231
310 Rector NA, Beck AT. Cognitive behavioral therapy for schizophrenia: An empirical review. J Nerv Ment Dis. 2001 May;189(5):278–87. doi: 10.1097/00005053-200105000-00002. PMID: 11379970.11379970
311 Sarin F, Wallin L, Widerlov B. Cognitive behavior therapy for schizophrenia: a meta-analytical review of randomized controlled trials. Nord J Psychiatry. 2011 Jun;65(3):162–74. doi: 10.3109/08039488.2011.577188. PMID: 21563994.21563994
312 Turkington D, Sensky T, Scott J, . A randomized controlled trial of cognitive-behavior therapy for persistent symptoms in schizophrenia: a five-year follow-up. Schizophr Res. 2008 Jan;98(1–3):1–7. PMID: 17936590.17936590
313 Drury V, Birchwood M, Cochrane R. Cognitive therapy and recovery from acute psychosis: a controlled trial. 3. Five-year follow-up. Br J Psychiatry. 2000 Jul;177:8–14. PMID: 10945081.10945081
314 McGurk SR, Twamley EW, Sitzer DI, . A meta-analysis of cognitive remediation in schizophrenia. Am J Psychiatry. 2007 Dec;164(12):1791–802. PMID: 18056233.18056233
315 Pitschel-Walz G, Leucht S, Bauml J, . The effect of family interventions on relapse and rehospitalization in schizophrenia--a meta-analysis. Schizophr Bull. 2001;27(1):73–92. PMID: 11215551.11215551
316 Dixon L, Adams C, Lucksted A. Update on family psychoeducation for schizophrenia. Schizophr Bull. 2000;26(1):5–20. PMID: 10755667.10755667
317 Dixon L, Duncan DC, Johnson P, . Occupational therapy for patients with Parkinson’s disease. Cochrane Database Syst Rev. 2009 (4)PMID: 17636709.17636709
318 Xia J, Merinder BL, Belgamwar MR. Psychoeducation for schizophrenia. Cochrane Database Syst Rev. 2013 (1)PMID: 21678337.21678337
319 Pfammatter M, Junghan UM, Brenner HD. Efficacy of psychological therapy in schizophrenia: conclusions from meta-analyses. Schizophr Bull. 2006;32(suppl_1):S64–S80. doi: 10.1093/schbul/sbl030. PMID: 16905634.16905634
320 Marshall T, Goldberg RW, Braude L, . Supported employment: assessing the evidence. Psychiatr Serv. 2014 Jan 01;65(1):16–23. doi: 10.1176/appi.ps.201300262. PMID: 24247197.24247197
321 Balshem H, Helfand M, Schünemann HJ, . GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011;64(4):401–6. PMID: 21208779.21208779
322 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines: 2. Framing the question and deciding on important outcomes. J Clin Epidemiol. 2011;64(4):395–400. PMID: 21194891.21194891
323 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines: 6. Rating the quality of evidence—imprecision. J Clin Epidemiol. 2011;64(12):1283–93. PMID: 21839614.21839614
324 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines: 8. Rating the quality of evidence—indirectness. J Clin Epidemiol. 2011;64(12):1303–10. PMID: 21802903.21802903
325 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines: 7. Rating the quality of evidence—inconsistency. J Clin Epidemiol. 2011;64(12):1294–302. PMID: 21803546.21803546
326 Guyatt GH, Oxman AD, Montori V, . GRADE guidelines: 5. Rating the quality of evidence—publication bias. J Clin Epidemiol. 2011;64(12):1277–82. PMID: 29802904.21802904
327 Guyatt GH, Oxman AD, Vist G, . GRADE guidelines: 4. Rating the quality of evidence—study limitations (risk of bias). J Clin Epidemiol. 2011;64(4):407–15. PMID: 21247734.21247734
328 American Psychiatric Association. Work group on Schizophrenia; Lehman AF, Lieberman JA, Dixon LB, . Practice guideline for the treatment of patients with schizophrenia, second edition. Am J Psychiatry. 2004;161:1–56. PMID: 15000267.15000267
329 American Psychiatric Association. Dixon L, Perkins D, Calmes C. Guideline watch: practice guideline for the treatment of patients with schizophrenia. Arlington, VA: American Psychiatric Association; September 2009. http://psychiatryonline.org/pb/assets/raw/sitewide/practice_guidelines/guidelines/schizophrenia-watch.pdf. Accessed April 22, 2017.
330 Ben-Zeev D, Davis KE, Kaiser S, . Mobile technologies among people with serious mental illness: opportunities for future services. Adm Policy Ment Health. 2013 Jul;40(4):340–3. doi: 10.1007/s10488-012-0424-x. PMID: 22648635.22648635
331 Gaynes BN, Brown C, Lux LJ, . Management Strategies To Reduce Psychiatric Readmissions. Rockville (MD): Agency for Healthcare Research and Quality (US); 2015.
332 Schulz KF, Altman DG, Moher D. CONSORT 2010 Statement: updated guidelines for reporting parallel group randomised trials. BMJ. 2010;340. doi: 10.1136/bmj.c332. PMID: 20332509.20332509
333 Guise JM, Chang C, Viswanathan M, . AHRQ Methods for Effective Health Care Agency for Healthcare Research and Quality (US). Rockville (MD): 2014. PMID: 2469689024696890.
334 Guise JM, Chang C, Viswanathan M, . Agency for Healthcare Research and Quality Evidence-based Practice Center methods for systematically reviewing complex multicomponent health care interventions. J Clin Epidemiol. 2014 Nov;67(11):1181–91. doi: 10.1016/j.jclinepi.2014.06.010. PMID: 25438663.25438663