# Methods

The methods for this systematic review follow the Agency for Healthcare Research & Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews and the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.^25,26^ See the review protocol (http://effectivehealthcare.ahrq.gov/index.cfm) for full details.

## Topic Refinement and Review Protocol

Initially a panel of key informants gave input on the key questions to be examined; these key questions were posted on AHRQ’s Effective Health Care (EHC) Web site for public comment in May 2016 for 3 weeks and revised in response to comments. We then drafted a protocol for the systematic review and recruited a panel of technical experts to provide high-level content and methodological expertise throughout the development of the review. The finalized protocol is posted on the EHC Web site at http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2279. The International Prospective Register of Systematic Reviews (PROSPERO) registration is PROSPERO 2016:CRD42016048403.

## Literature Search Strategy

Publication date range. For Key Question 1 on pharmacological interventions, recent high-quality systematic reviews directly addressing large portions of the key questions in the current review have been published and were used as the starting point for the review.^27–29^ Based on the search dates in these reviews, searches for trials and systematic reviews began in 2011 for first generation antipsychotic (FGA) versus second generation antipsychotic (SGA) drugs and in 2013 for SGA versus SGA drugs. Starting the searches in January of 2011 and 2013, respectively, allows for multiple months of overlap of the new search dates with the search dates in the prior reviews.

For Key Question 2 on nonpharmacological interventions, search dates were not restricted. Within these searches we first identified the most recent, good-quality systematic reviews for particular interventions. Any trials identified in our searches that were published since the search dates in these reviews were also included to update the included reviews.

Library searches were updated through February 1, 2017 during which the draft report was posted for public comment and peer review to capture any new publications. Literature identified during the updated search, or through other methods described below, was assessed by following the same process of dual review as all other trials considered for inclusion in the report.

Literature databases. A research librarian searched Ovid MEDLINE^®^, the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and PsycINFO^®^ to capture published literature (Appendix A.).

Scientific information packets. The AHRQ Evidence-based Practice Center (EPC) Scientific Resource Center sent email notification to relevant stakeholders about the opportunity to submit scientific information packets (SIPs) via the EHC Web site for the pharmaceutical interventions listed in Key Question 1.

Hand searching. Reference lists of included articles were reviewed for includable literature.

Grey literature. Searches for grey (unpublished) literature include the SIPs submitted for pharmacological interventions and the ClinicalTrials.gov trial registry to identify trials that have been completed but not yet published.

## Inclusion and Exclusion Criteria

Population(s)
- Adults with a diagnosis of schizophrenia, including those with co-occurring substance use disorders (SUDs), and including those experiencing a first episode of schizophrenia (including those with schizophreniform disorder)
  ○ Key Question 1:
    ■ At least 90 percent of patients must have been diagnosed with schizophrenia
    ■ For studies specifically on harms of antipsychotic drugs, populations can be mixed-diagnoses, as the harms are not diagnosis-specific
  ○ Key Question 2:
    ■ 50 percent of patients must have been diagnosed with a schizophrenia spectrum disorder (i.e., schizophrenia, schizoaffective disorder, or schizophreniform disorder).^30^

Interventions
- Key Question 1: Antipsychotic medications
  ○ Key first-generation antipsychotic drugs
    ■ Fluphenazine (Prolixin^®^, Permitil^®^)
    ■ Haloperidol (Haldol^®^)
    ■ Perphenazine (Trilafon^®^)
  ○ Second-generation antipsychotic drugs
    ■ Aripiprazole (Abilify^®^, Aristada™)
    ■ Asenapine (Saphris^®^),
    ■ Brexpiprazole (Rexulti^®^ )
    ■ Cariprazine (Vraylar™)
    ■ Clozapine^b^ (Clozaril^®^, Fazaclo^®^ oral dissolving tablet [ODT], Versacloz™)
    ■ Iloperidone (Fanapt^®^)
    ■ Lurasidone (Latuda^®^)
    ■ Olanzapine ^b^ (Zyprexa^®^, Zyprexa Zydis^®^), Olanzapine Pamoate (Zyprexa^®^ Relprevv™)
    ■ Paliperidone ^b^ (Invega® ) and Paliperidone palmitate (Invega® Sustenna®, Invega Trinza™)
      - Oral paliperidone is marketed only as an extended-release product, and will be noted as paliperidone in the report because there is no immediate-release formulation.
    ■ Quetiapine ^b^ (Seroquel^®^, Seroquel XR^®^)
      - The extended release formulation is noted as quetiapine extended release (ER) in this report; the immediate-release formulation is not noted by a suffix, to be consistent with the other immediate release formulations of SGAs.
    ■ Risperidone ^b^ (Risperdal^®^, Risperdal^®^ M-TAB^®^ ODT, Risperdal^®^ Consta^®^)
    ■ Ziprasidone^b^ (Geodon^®^)

Excluded: Short-acting injectable drugs, as they are generally only used in emergent, acute conditions and on a short-term basis (hours to days)

- Key Question 2: Psychosocial and other nonpharmacological interventions^c^
  ○ Assertive community treatment
  ○ Cognitive adaptive training
  ○ Cognitive behavioral therapy
  ○ Cognitive remediation/training
  ○ Co-occurring substance use and schizophrenia interventions (reported in Key Question 2b)
  ○ Early interventions for first episode psychosis (reported in Key Question 2b)
  ○ Family interventions
  ○ Intensive case management
  ○ Illness self-management training
  ○ Psychoeducation
  ○ Social skills training
  ○ Supported employment
  ○ Supportive therapy

Comparators
- Key Question 1:
  ○ Head-to-head comparisons: three FGAs (listed above) and all FDA-approved SGAs
    ■ Exclude: FGA versus FGA drug comparisons
- Key Question 2:
  ○ Antipsychotic drugs (alone)
  ○ Usual care/standard care/treatment as usual/waitlist, as defined in the trials
    ■ Usual care can consist of elements of medication treatment, medication management, case management, rehabilitation services, and psychotherapy. We assumed that randomization would balance the specific elements of usual care interventions between treatment and control arms within each randomized controlled trial (RCT). Both groups (treatment and usual care) received usual care, including drug treatment throughout the study.
    ■ Evidence with active controls (other interventions with expected benefit, or attention controls which have minimal or no benefit but similar patient participation time) was considered where the evidence base with usual care comparisons for a given intervention is too small to draw conclusions (i.e., one or two trials, no systematic reviews).

Outcomes for each question:^d^
- Benefits outcomes
  ○ Key Questions 1 and 2
    ■ Functional
      - Improvements in social and occupational/educational functioning
      - Enhanced level of independent or stable living situation
      - Reductions in legal system encounters
      - Global functioning
    ■ Reductions in self-harm, including suicide and suicide attempts
    ■ Improvements in health-related quality of life (using validated scales and including mental and physical health)
    ■ Treatment discontinuation (e.g., treatment discontinuation/switching rate, time to discontinuation for any reason including lack of efficacy or intolerable adverse effects)
    ■ Improvements in core illness symptoms (e.g., delusions, hallucinations, disorganized thinking)
      - Rates of response, remission, and relapse; speed and duration of response
      - Total scale scores of positive (i.e., delusions and hallucinations) and negative (i.e., passive or apathetic social withdrawal and blunted affect) symptoms
      - Reductions in agitation symptoms or aggressive behaviors
    ■ Changes in the status of co-occurring SUD (Key Question 2b).
- Exclusions:
  ○ Rehospitalization was not included as an outcome because: (1) there is important variation in the indications for and length of psychiatric hospitalizations across time, in different localities, and with different financial contexts, and (2) there is important variation across trials in how rehospitalization is measured/evaluated, which may confound study interpretation. However, it was reported in addition to the prioritized outcomes for assertive community treatment because it is the target of this intervention for patients with a history of frequent hospitalization.
  ○ Neurocognitive testing is an intermediate outcome, rather than a patient-centered health outcome, and is excluded in favor of improvements in functioning that reflect cognition.
- Harms outcomes
  ○ Key Question 1
    ■ Overall adverse events (frequency of any adverse events reported in trials)
    ■ Withdrawals due to adverse events, time to withdrawal due to adverse events
    ■ Mortality (all-cause and cause-specific as defined by studies)
    ■ Significant (major) adverse events (e.g., life threatening, results in long-term morbidity, or require medical intervention to treat, such as cerebrovascular or cardiovascular disease and related events, development of diabetes mellitus, diabetic ketoacidosis, neuroleptic malignant syndrome, seizures, extrapyramidal symptoms (EPS), tardive dyskinesia, clinically important weight changes, dyslipidemia, incidence and severity of sexual dysfunction, galactorrhea, amenorrhea, orthostatic hypotension, and agranulocytosis/severe neutropenia)
  ○ Key Question 2
    ■ Overall adverse events (frequency of any adverse events reported in trials)
    ■ Withdrawals due to adverse events, time to withdrawal due to adverse events
    ■ Mortality (all-cause and cause-specific as defined by trials)
    ■ Outcomes reported as adverse events related to the intervention, such as:
      - New or worsening symptoms (e.g., anxiety or depression) using validated scales
      - Negative effect on family or other relationships.

Timing
- Minimum duration of followup: 12 weeks.

Settings
- United States-relevant, for example such as countries listed as “high” or “very high” on the United Nations International Human Development Index (HDI), and applicable to United States practices.
- Excluded: inpatient setting

Study designs
- Key Questions 1 and 2:
  ○ Best-evidence approach:^31^
    ■ Recent, comprehensive, good- or fair-quality systematic reviews to be used as primary evidence, as well as RCTs published since the systematic reviews
      - For benefits of any included intervention, systematic reviews of RCTs will be included
      - For harms of any included intervention, systematic reviews of observational trials to evaluate harms will be included in addition to reviews of trials
      - Note: We included some systematic reviews that included a portion of trials with inpatients, otherwise, most evidence would have had to be excluded. However, we did not include individual trials that included inpatients.
    ■ If no systematic reviews available for particular interventions, RCTs will be included
- Key Question 2: Studies must have a sample size of >50.

## Study Selection

The pre-established criteria (described above) was used to determine eligibility for inclusion and exclusion of abstracts in accordance with the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^26^ All citations deemed appropriate for inclusion by at least one of the reviewers was retrieved; excluded abstracts were dual reviewed. Each full-text article was independently reviewed for eligibility by at least two team members. Any disagreements were resolved by consensus.

A list of included studies is available in Appendix B, and a list of excluded studies with reasons for exclusion is available in Appendix C.

## Data Extraction

After studies were selected for inclusion, the following data was abstracted into predetermined table templates: study design, year, setting, country, sample size, eligibility criteria, population and clinical characteristics, intervention characteristics, and results relevant to each key question, as well as other information (e.g., funding source). When results were reported as scale scores, we included the scale abbreviation in our tables; full names of scales used, score ranges, and direction of effect are available in Appendix D. Abstracted information that is relevant for assessing applicability included the number of patients randomized relative to the number of patients enrolled, use of run-in or wash-out periods (for drug studies), and characteristics of the population, intervention, and care settings. All study data has been verified for accuracy and completeness by a second team member. Data extraction tables are available in Appendix E.

## Quality Assessment of Individual Studies

The quality of individual controlled trials and systematic reviews were assessed by using clearly predefined criteria. RCTs were evaluated with appropriate criteria and methods developed by the Drug Effectiveness Review Project (DERP).^32^ Systematic reviews were assessed using the Assessing the Methodological Quality of Systematic Reviews (AMSTAR) quality-rating instrument.^33^ These criteria and methods were used in conjunction with the approach recommended in the chapter, “Assessing the Risk of Bias of Individual Studies When Comparing Medical Interventions” in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^26^ Studies were rated as “good,” “fair,” or “poor.” Observational studies that were included in systematic reviews included in this review must have been assessed for quality or risk of bias using a design-appropriate tool.

Studies rated “good” quality were considered to have the least risk of bias, and their results will be considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes.

Studies rated “fair” quality were susceptible to some bias, although not enough to invalidate the results. These studies may not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The fair-quality category is broad, and studies with this rating will vary in their strengths and weaknesses.

Studies rated “poor” quality have significant flaws that imply biases of various types that may invalidate the results. They will have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies will be as likely to reflect flaws in the study as the true difference between the compared interventions. We will not exclude studies rated as being poor in quality a priori, but poor-quality studies will be considered to be less reliable than higher-quality studies when synthesizing the evidence, particularly if discrepancies between studies are present (see strength of evidence [SOE] rating system below).

This approach to evaluating the internal validity of studies is similar to the “risk of bias” method, although the direction of the scale for ratings is inverse to the good, fair, and poor ratings used here. Specifically, low, moderate, or high risk of bias correlates with good, fair, and poor quality, respectively. Each study was dual-reviewed for quality by two team members. Any disagreements were resolved by consensus. Quality assessment tables are available in Appendix F.

## Data Synthesis

We constructed evidence tables identifying the study characteristics (as discussed above), results for outcomes of interest, and quality ratings for all included studies, and, when appropriate, summary tables to highlight the main findings. Good- and fair-quality systematic reviews and trials were the focus of the results for each key question. Results from systematic reviews were presented first, followed by synthesis of the findings from trials not included in the reviews. To the extent possible, meta-analyses in included systematic reviews were updated with data from trials not included in the reviews. For the remainder of the included trials (those not included in the included systematic reviews and with evidence not conducive to meta-analysis), we summarized the trials’ findings in the context of the included systematic review findings; we identified both consistent and discordant findings and evaluated reasons for any discordant findings.

Qualitative data was summarized as ranges and descriptive analysis, and interpretation of the results was provided. We compiled and summarized study characteristics and investigated whether there were important differences in the distribution in characteristics that modified the treatment effects.

Meta-analyses were conducted to summarize data and obtain more precise estimates on outcomes for which studies were homogeneous enough to provide a meaningful combined estimate. To determine whether meta-analysis could be meaningfully performed, we considered the quality of the studies and the heterogeneity among studies in design, patient population, interventions, and outcomes. We examined the possibility for conducting network meta-analyses to provide estimates of comparative effect across the interventions for specific outcomes, according to key question.

We conducted pairwise meta-analyses to calculate relative risks for dichotomous outcomes. For continuous outcomes, we used endpoint scores where baseline scores were similar between groups (within study), and changed scores where they were the only data provided. We used standard deviations where reported and performed calculations when standard errors or 95% confidence intervals (CIs) were reported instead. We used the DerSimonian and Laird random-effects model with Review Manager Version 5.3 software,^34^ StatsDirect, version 3.0.167,^35^ or Stata 14.^36^ Statistical heterogeneity was assessed using the I^2^ statistic for three or more studies and the Q-statistic chi square test where only two studies could be pooled.

Network meta-analyses were conducted for key effectiveness binary outcomes with adequate data to support a network using a Bayesian hierarchical model for exploratory purpose.^37,38^ The appropriateness of combining direct and indirect evidence and the consistency of the network was assessed by using the loop-specific approach to examine inconsistency separately in every closed loop of a network, the node-splitting method and overall comparison of consistency and inconsistency models.^39,40^ Inconsistency was explored if detected. We used vague priors in the Bayesian model, and posterior inference was based on Markov Chain Monte Carlo (MCMC) Sampling using two chains. Trace plot and the Gelman-Rubin statistic, as modified by Brooks and Gelman (1998) was used to check convergence of Markov Chains.^41^ Posterior point and interval estimates of model parameters were obtained based on 200,000 MCMC iterations thinned at every 100^th^ value after initial burn-in of 200,000 iterations (i.e., 2000 iterations per chain). Comparative effectiveness was measured by using odds ratio (OR), and estimated by controlling for variation in study duration, dose levels (low, medium, and high), and whether studies enrolled patients with a first episode of schizophrenia or whose symptoms were resistant to prior treatment in all models. For Response, the Bayesian model also included assessment of the definition of response, grouped into three categories: 20 percent improvement in Positive and Negative Syndrome Scale (PANSS); other scales (i.e., Clinical Global Impression - Improvement scale [CGI-I]) or thresholds; and combined 20 percent improvement in PANSS and other measures. Controlling the study-level variables also allowed us to evaluate whether the drug effectiveness varied by these variables. The construction of network plot and evaluation of inconsistency was done using Stata/SE 14.1 (StataCorp LP, College Station, TX 77845), and the Bayesian model was implemented using OpenBUGS 3.2.3 (http://www.openbugs.net/w/FrontPage). Forest plots for pooled analyses and matrixes of results for network analyses are available in Appendix G.

## Strength of the Body of Evidence

The SOE for each key outcome per intervention area was assessed by using the approach described in the AHRQ EPC Methods Guide.^26,42^ Key outcomes were clinical, patient-centered (i.e., health outcomes) and were selected based on input from the Technical Expert Panel (TEP), a panel of experts convened to review the appropriateness and relevance of the report at the scoping phase. The prioritized outcomes are listed below, per intervention area.

Pharmacological interventions:

1. Functional outcomes (e.g., social, occupational)
2. Health-related quality of life (including physical)
3. Rates of response and/or remission
4. Mortality (all-cause and/or specific)
5. Reductions in self-harm, suicide, and suicide attempts
6. Improvements in core illness symptoms scale score changes
7. Overall/any adverse events (rate or proportion)
8. Withdrawal due to adverse events

Psychosocial and other nonpharmacological interventions:

1. Functional (e.g., social, occupational)
2. Health-related quality of life
3. Reductions in self-harm, suicide, and suicide attempts
4. Rates of response and/or remission
5. Improvements in core illness symptoms scale score changes
6. Treatment discontinuation (typically reported as the number of patients lost to followup or leaving study early)
7. Rates of relapse
8. Outcomes reported as adverse events related to the intervention

SOE was initially assessed by one researcher, and to ensure consistency and validity of the evaluation, a senior reviewer reviewed the grades and any disagreements were resolved through consensus. SOE was based on the following domains^e^:

1. Study limitations (low, medium, or high level of study limitations based on the quality/risk of bias of individual studies)
2. Consistency (consistent, inconsistent, or unknown/not applicable)
3. Directness (direct or indirect)
4. Precision (precise or imprecise)

The SOE was assigned an overall grade of high, moderate, low, or insufficient according to a four-level scale by evaluating and weighing the combined results of the above domains:

- High — We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable (i.e., another study would not change the conclusions).
- Moderate — We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
- Low — We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient — We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

The details of the SOE are available in Appendix H. If the entire body of evidence was deemed insufficient for an intervention category, we presented tables of the main study characteristics and quality, descriptive summary of findings, funding source and reasons for being deemed insufficient. These bodies of evidence did not undergo further synthesis.

Similarly, the evidence for subgroups in Key Questions 1b and 2b was only assessed for SOE if an intervention was studied in a specific subgroup, but subgroup analyses of the larger evidence base were not assessed as they represent hypothesis generating research and would not meet the criteria for SOE.

## Applicability

Applicability was assessed according to the approach described in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^26^ We used the population, intervention, comparison, outcomes, timing, study design/setting (PICOTS) framework to consider the applicability of the evidence base for each key question and intervention area, for example examining the characteristics of the patient populations (e.g., age, severity and duration of illness).

## Peer Review and Public Commentary

Experts in treatments for schizophrenia were invited to provide external peer review of this systematic review; AHRQ and an associate editor also provided comments. In addition, the draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed the reviewer comments and revised the text as appropriate.

b “Older” SGAs; approved up through 2001 and included in the Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) trials.

c Limited to the most commonly-used interventions relevant to United States practices.

d Intervention patient-outcome targets are highlighted in the results; most are included among the prioritized outcomes listed above.

e Reporting bias is also a domain listed in the AHRQ EPC Methods guidance on SOE, but as none of the included reviews assessed this domain we were unable to fully assess this item. If obvious problems with reporting bias were found, they are noted under the study limitations domain.