# Introduction

## Background

### Condition

Schizophrenia is a chronic mental health condition that most often presents in early adulthood and can lead to disabling outcomes. The most recent version of the American Psychiatric Association’s Diagnostic and Statistical Manual of Mental Disorders, 5th Edition (DSM-5),^1^ has continued the trend of clarifying and simplifying the diagnostic criteria for schizophrenia from the American Psychiatric Association’s Diagnostic and Statistical Manual of Mental Disorders, 3rd Edition (DSM-III) through DSM-IV without changing the defined patient population among the editions.^2^ Currently, DSM-5 defines schizophrenia as: the presence of two or more of the five core symptoms (delusions, hallucinations, disorganized speech, grossly disorganized or catatonic behavior, and negative symptoms); at least one of the symptoms being delusions, hallucinations, or disorganized speech; and, symptoms being present for at least 6 months. Lifetime prevalence is approximately 0.3 to 0.7 percent, with onset most commonly between late adolescence through the third decade.^3^ Differential diagnosis is broad and includes delineation from mood disorders (bipolar disorder or major depressive disorder) with psychotic features and substance/medication-induced psychotic disorders. The course of schizophrenia varies. Approximately 20 percent of individuals may experience significant improvement including, in some cases, full recovery;^4^ however, the majority tend to experience some degree of social and occupational difficulty as well as need for daily living supports. That said, more recent research and practice has focused on early intervention with first episode psychosis, demonstrating promise toward improving outcomes sooner and reducing longer-term disability.^5,6^

### Treatment Strategies

Antipsychotic medications (primarily effective via dopaminergic antagonism) and nonpharmacological treatments are typically used together when treating individuals with schizophrenia. Both approaches can result in meaningful improvements in a variety of outcome areas, including psychiatric symptoms, functioning (e.g., employment, social), service utilization (e.g., hospitalization, crisis services), legal system involvement, quality of life, self-harm and aggressive behaviors, treatment engagement and retention, and co-occurring substance abuse. Ideally, improvements in symptoms translate to long-term, clinically relevant, positive changes in other outcome areas, with limited and manageable adverse effects. While pivotal trials of antipsychotic efficacy are limited to measurement of symptom reduction, measurement of other important recovery-oriented outcomes that reflect improvement in social and occupational functioning are necessary to describe benefits of treatments on overall quality of life and functional ability.

Historically, the wide array of antipsychotic drug treatments has had uncertain impact on long-term patient-centered outcomes, such as the ability to have consistent employment and successful interpersonal relationships, as well as maintenance in independent living, and includes serious concerns about adverse effects (e.g., tardive dyskinesia, weight gain, diabetes, and dyslipidemia) for some treatments. Many patients prescribed an antipsychotic discontinue it. Discontinuation rates and time to discontinuation vary by treatment and patient characteristics. Older, first-generation antipsychotics (FGAs), such as haloperidol, have proven efficacy but adverse effects such as extrapyramidal symptoms (EPS) and in some cases tardive dyskinesia, often limit long-term adherence. Second-generation antipsychotics (SGAs), beginning with clozapine, were introduced as having equal or better efficacy, specifically potentially better effects on negative symptoms, and the hope of fewer EPS and lower risk of tardive dyskinesia. But SGAs also have potentially serious adverse effects (e.g., cardiovascular and endocrinologic adverse effects) that make their overall risk/benefit profile less clear-cut than anticipated.

Although there are a large number of treatments for schizophrenia, it is not clear whether they afford long-term benefits on employment and social relationships and improve the likelihood of recovery, and the most effective duration of treatment is unclear. Equally important in selecting among competing interventions for a specific patient is consideration of patient-level characteristics that may affect the outcomes (including age, duration of symptoms, severity, and other psychiatric or medical comorbidities) across a diverse group of possible interventions. For example, treatment of negative symptoms (e.g., diminished emotional response and lack of interest) may differ from treatment of positive symptoms (e.g., hallucinations and delusions). Most psychosocial interventions have specific targets for the patient population and outcome measure. Patients and providers are also interested in other patient-centered health outcomes.

While the success of any given treatment depends on the balance of benefit and harm, specific treatment considerations will vary across the lifespan. Treating patients aggressively early in the disease is thought to improve long-term outcomes although overly aggressive treatments, particularly drug treatments, may result in adverse effects. Additionally, substance abuse (e.g., tobacco, alcohol, illicit drugs) may begin early on for individuals with schizophrenia, and in these patients successful treatment of schizophrenia involves consideration of this comorbidity as well.^7–10^ The metabolic effects related to both the disease and drug treatments are concerning across age groups, starting in adolescence or early adulthood.^11^ Epidemiologic studies have found an association with obesity, elevated lipids, and shorter lifespan, and several antipsychotic drugs are known to increase these risks.^12–18^ Older patients may have increased risk of mortality^19–22^ and require antipsychotic dosing changes with age.^23,24^ Across all age groups, primary goals include diminishing core illness symptoms and reducing relapses of acute psychosis; however, physical health comorbidities can present challenges requiring modification of the treatment plan.

## Scope and Key Questions

### Scope of the Review

In this systematic review, we evaluate the current evidence to inform treatment options for individuals with schizophrenia. The review synthesizes evidence on the comparative effectiveness of pharmacological treatments and the effectiveness of common psychosocial and other nonpharmacological treatment strategies for individuals with schizophrenia, points out areas of controversy, and highlights future research needed.

Due to a very large number of studies and interventions, the scope of the review focuses on specific types of evidence. For pharmacological interventions, we limited to the most commonly used FGA drugs (fluphenazine, haloperidol, and perphenazine), but included all United States Food and Drug Administration (FDA)-approved SGA drugs. For the pharmacological interventions, the focus was on comparative evidence, directly comparing drugs to each other. This decision was based in part on the availability of sufficient evidence on general efficacy of the drugs to treat schizophrenia in the form of studies used to gain FDA approval, that is, placebo-controlled trials. For psychosocial and nonpharmacological interventions, we limited to the most commonly-used interventions relevant to United States practices. In doing this, we excluded single studies of unique interventions, and studies conducted in countries with cultural, social, and health care environments that are very different from the United States. We limited to studies comparing a psychosocial or other nonpharmacological intervention to “usual care” as a common comparator. This decision was made largely due to the heterogeneity of interventions and comparators across studies, the existence of many studies comparing these interventions to usual care, and to provide a common comparator across the interventions.

We limited the outcomes to those that are patient centered health outcomes (rather than intermediate outcomes), which were arranged according to their priority from the perspective of the patient, their family, and their clinicians. We considered advice from our experts in selecting and prioritizing the outcomes. We did not include two outcomes that are sometimes evaluated. First, we excluded rehospitalization, because: (1) there is important variation in the indications for and length of psychiatric hospitalizations across time, in different localities, and with different financial contexts; and (2) there is important variation across trials in how rehospitalization is measured/evaluated, which may confound study interpretation. For assertive community treatment, where decreasing rehospitalization is the target of the intervention, we included rehospitalization as an outcome. Second, we excluded changes in neurocognitive test results, as these were viewed as an intermediate outcome. Instead, we have prioritized measures of functioning that include neurocognition as part of a set of broader patient-centered health outcomes. The Analytic Framework for the review appears in Figure 1.

Figure 1 Analytic framework

* Adults with a diagnosis of schizophrenia, including those with co-occurring substance use disorders, and including those experiencing a first episode of schizophrenia (including those with schizophreniform disorder).

1. Pharmacological treatments:
  a. At least 90 percent of patients must have been diagnosed with schizophrenia.
  b. For studies specifically on harms of antipsychotic drugs, populations can be mixed-diagnoses, as the harms are not diagnosis-specific
2. Psychosocial and other nonpharmacological treatments: 50 percent of patients must have been diagnosed with a schizophrenia spectrum disorder diagnosis (i.e., schizophrenia, schizoaffective disorder, or schizophreniform disorder)

† Pharmacological treatments include US Food and Drug Administration-approved second-generation and selected first-generation antipsychotics. Psychosocial and other nonpharmacological treatments include: assertive community treatment, cognitive adaptive training, cognitive behavioral therapy, cognitive remediation/training, co-occurring substance use and schizophrenia interventions, early interventions for first episode psychosis, family interventions, intensive case management, illness self-management training, psychoeducation, social skills training, supported employment, and supportive therapy.

This figure depicts the analytic framework which outlines the evidence areas covered in the review, including the population, interventions, and benefits and harms outcomes. The population includes adults with schizophrenia, defined as adults with a diagnosis of schizophrenia, including those with co-occurring substance use disorders, and including those experiencing a first episode of schizophrenia (including those with schizophreniform disorder). For pharmacological treatments: At least 90 percent of patients must have been diagnosed with schizophrenia. For studies specifically on harms of antipsychotic drugs, populations can be mixed-diagnoses, as the harms are not population-specific. For psychosocial and other nonpharmacological treatments: 50 percent of patients must have been diagnosed with a schizophrenia spectrum disorder diagnosis (i.e., schizophrenia, schizoaffective disorder, or schizophreniform disorder) An arrow from the population indicates pharmacological and psychosocial and other nonpharmacological treatments. Pharmacological treatments include FDA-approved 2nd generation and selected 1st generation antipsychotics. Psychosocial and other nonpharmacological treatments include: assertive community treatment, cognitive adaptive training, cognitive behavioral therapy, cognitive remediation/training, co-occurring substance use and schizophrenia interventions, early interventions for first episode psychosis, family interventions, intensive case management, illness self-management training, psychoeducation, social skills training, supported employment, and supportive therapy. The arrow leads to benefits outcomes, including: • Functional, including improvements in social and occupational functioning, enhanced ability to live independently/stability, and reductions in legal system encounters • Reductions in self-harm, including suicide and suicide attempts • Improvements in health-related quality of life (using validated scales and including mental and physical health) • Ability to maintain treatment (e.g., treatment discontinuation/switching rate, time to discontinuation) • Improvements in core illness symptoms (e.g., delusions, hallucinations, disorganized thinking), including rates of response, remission and relapse; speed and duration of response, total scale scores of positive (i.e., delusions and hallucinations) and negative (i.e., passive or apathetic social withdrawal and blunted affect) symptoms, and reductions in agitation symptoms or aggressive behaviors • Changes in the status of co-occurring substance use disorder A subsequent arrow from the interventions assesses harms outcomes, specifically: For pharmacological interventions: • Overall adverse events (frequency of any adverse events reported in trials) • Withdrawals due to adverse events, time to withdrawal due to adverse events • Mortality (all-cause and cause-specific as defined by studies) • Significant (major) adverse events. For psychosocial and other nonpharmacological interventions: • Overall adverse events (frequency of any adverse events reported in trials) • Withdrawals due to adverse events, time to withdrawal due to adverse events • Mortality (all-cause and cause-specific as defined by studies) • Worsening of symptoms or new symptoms • Other adverse events specific to intervention (e.g. negative effect on family or other relationships)

### Key Questions

1a What are the comparative benefits and harms of pharmacological treatments for adults with schizophrenia?
1b How do the benefits and harms of pharmacological treatments for adults with schizophrenia vary by patient characteristics?^a^
2a What are the benefits and harms of psychosocial and other nonpharmacological treatments for adults with schizophrenia?
2b How do the benefits and harms of psychosocial and other nonpharmacological treatments for adults with schizophrenia vary by patient characteristics?^a^

a Patient characteristics include age, sex, race, ethnicity, socioeconomic status, time since illness onset, prior treatment history, co-occurring psychiatric disorders, pregnancy, etc.