# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Austin R. Campbell, Pharm.D.
  University of Missouri
  Columbia, MO
- Lisa B. Dixon, M.D., M.P.H.^*^
  Columbia University
  New York, NY
- Laura J. Fochtmann, M.D., M.B.I^*^.
  Departments of Psychiatry, Pharmacological Sciences and Biomedical Informatics
  Stony Brook University School of Medicine
  Stony Brook, NY
- Eric Granholm, Ph.D.^*^
  Department of Psychiatry, University of California, San Diego
  VA San Diego Healthcare System
  San Diego, CA
- Lisa Hartling, M.D.
  Alberta Research Centre for Health Evidence
  Edmonton, Alberta, Canada
- Piper Meyer-Kalos, Ph.D., L.P.
  University of Minnesota
  Minneapolis, MN
- Matthew V. Rudorfer, M.D.^*^
  National Institutes of Health
  National Institute of Mental Health
  Bethesda, MD

* Provided input on Draft Report