# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Bob Correia, R.Ph., Pharm.D.
  New York Medicaid Pharmacy Agency
  New York State Department of Health
  New York, NY
- Lisa B. Dixon, M.D., M.P.H.^*^
  Columbia University
  New York, NY
- Laura J. Fochtmann, M.D., M.B.I.^*^
  Departments of Psychiatry, Pharmacological Sciences and Biomedical Informatics
  Stony Brook University School of Medicine
  Stony Brook, NY
- Anthony F. Lehman, M.D., M.S.P.H.
  University of Maryland
  College Park, MD
- Janie Marsh, M.P.H.:H.A.
  Mental Health America of Oregon
  Portland, OR
- Piper Meyer-Kalos, Ph.D., L.P.
  University of Minnesota
  Minneapolis, MN
- Joyce M. Shea, D.N.Sc., A.P.R.N., P.M.H.C.N.S.-B.C.
  American Psychiatric Nurses Association
  Falls Church, VA

* Provided input on Draft Report