# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elaine Graham, M.L.S.; Andrew Hamilton, M.L.S., M.S.; Leah Williams, B.S.; Ryan Stoner, Ph.D.; Liev Miller, B.S.; and Brittany H. Lazur, M.P.H.