# Discussion

## Key Findings and Strength of Evidence

This systematic review evaluated the evidence on treatments for schizophrenia, comparing drug treatments to each other and psychosocial and other nonpharmacological interventions to usual care. The purpose was to inform clinicians, patients and their families, and guideline authors with the ultimate goal of improving patient care. The key findings and strength of evidence (SOE) for these findings are summarized in the summary of evidence tables (Tables 10 and 11). The complete assessments of strength of the evidence, according to comparisons and outcomes, are in Appendix H. In this summary, we do not include findings where the evidence was insufficient to draw conclusions. Generally, these were situations where the evidence was limited to a single study, with inadequate sample size, and only fair quality. Unfortunately, even with the large volume of studies available, there were no instances of high-strength evidence. This was primarily due to specific intervention comparisons having only a few fair-quality trials with few studies contributing evidence for a particular outcome, resulting in moderate and low-strength evidence. The key findings are presented below by key question and prioritized outcomes. The findings are then discussed in relation to what is already known about these interventions, applicability of the findings, implications of the findings for policy and decisionmaking, limitations of the review and the evidence, and finally our research recommendations based on gaps in the evidence,

Table 10 Summary of evidence for pharmacological treatments

Comparison | Outcome | Strength of Evidence | Conclusions
SGA vs. SGA | Function | Low | No difference in social functioning was found between paliperidone palmitate LAI (monthly) and risperidone LAI (every two weeks) (PSP scale mean change from baseline 16.8 and 18.6, respectively; LSM difference 0,5, 95% CI −2.14 to 3.12) based on one RCT (N=452).^29^ A single study (N=666) found risperidone LAI to result in greater improvements in social function over 24 months compared with quetiapine (change at endpoint 6.6 vs. 1.1; p<0.0001). (1 RCT; N=666).^138^ Although both groups improved significantly from baseline, risperidone LAI resulted in greater improvements in SOFAS at 6 months (6.1 vs. 2.7; p=0.02), 12 months (9.5 vs. 6.1; p=0.009).^138^ CATIE Phase 1 found no significant differences in rates of employment between risperidone, olanzapine, quetiapine, and ziprasidone at 18 months.^29^ Global functioning was not different (based on the GAF) between olanzapine and either risperidone (4 cohort studies; Pooled WMD 0.61, 95% CI −1.78 to 2.99; I^2^=43%) or quetiapine (2 RCTs; pooled WMD 1.14, 95% CI −4.75 to 7.02; Q=3.99, df=1; p=0.045).^29^
SGA vs. SGA | Quality of life | Moderate | Olanzapine was not found significantly different than risperidone (2 RCTs) or ziprasidone (2 RCTs) at 12 months using the QLS scale (change in scores ranged from 0.19 to 0.26).^29^
SGA vs. SGA | Quality of life | Low | Olanzapine was not found significantly different than quetiapine (1 RCT) at 12 months using the QLS scale.^29^ Risperidone was not found significantly different from quetiapine or ziprasidone at 12 months using the QLS scale (1 RCT each; range of change in scores 0.19 to 0.26).^29^ Risperidone LAI was not found different from quetiapine on the SF-12 or SQLS-R4 at 24 months.^138^
SGA vs. SGA | Response/remission | Low | Response was significantly more likely with olanzapine (OR 1.71, 95% CI 1.11 to 2.68) and risperidone (OR 1.41, 5% CI 1.01 to 2.00) than quetiapine, based on a network meta-analysis of 46 head-to-head RCTs.
SGA vs. SGA | Mortality | Low | With incidence rates of 0 to 1.17%, significant differences in mortality were not found in two RCTs each (4 to 24 months duration) of asenapine with olanzapine (RR 2.49, 95% CI 0.54 to 11.5),^154,187^ quetiapine and risperidone (RR 3.24, 95% CI 0.72 to 14.6) ^184,186^ and paliperidone palmitate LAI (monthly) versus risperidone LAI (RR 1.26, 95% CI 0.21 to 7.49).^136,188^ Retrospective cohort studies found no significant difference in the risk of all-cause (1 study, N=48,595) or cardiovascular mortality (2 studies, N=55,582) between risperidone, olanzapine, and quetiapine.^29^
SGA vs. SGA | Reduction in self-harm | Low | Clozapine was found superior to olanzapine in preventing significant suicide attempts or hospitalization to prevent suicide (HR 0.76, 95% CI 0.58 to 0.97) and CGI-Suicide Severity (SS) ratings of “much worse” or “very much worse” (HR 0.78, 95% CI 0.61 to 0.99); NNT=12) among patients at high risk. Observational studies confirm these findings in broader populations.^29^
SGA vs. SGA | Core illness symptoms: Total symptoms | Low | Clozapine was found to improve core illness symptoms significantly more than the other SGAs, except for olanzapine (network meta-analysis of 212 RCTs; SMDs on PANSS or BPRS −0.32 to −0.55).^194^ All of the SGAs were superior to placebo (SMDs −0·33 to −0·88). Olanzapine and risperidone were found to improve symptoms more than the other SGAs, except for each other and paliperidone (SMDs −0.13 to −0.26).^194^ Paliperidone was found to improve symptoms more than lurasidone and iloperidone (SMDs=−0.17).^194^ In a separate network analysis of 40 RCTs of clozapine, risperidone, olanzapine, quetiapine, and ziprasidone in patients who were resistant to treatment, the only significant difference was that the mean change in the PANSS was greater with olanzapine than quetiapine (SMD −0.29, 95% CI −0.56 to −0.13).^183^
SGA vs. SGA | Overall/any adverse events | Moderate | There was no significant difference in overall adverse event reporting between asenapine and olanzapine in five RCTs (in 4 publications).^154,176,187,225^
SGA vs. SGA | Overall/any adverse events | Low | There was no difference between groups based on two to three trials each comparing: quetiapine ER versus quetiapine and risperidone; risperidone versus clozapine and aripiprazole; olanzapine versus paliperidone; risperidone LAI versus paliperidone and paliperidone palmitate monthly LAI; and aripiprazole versus aripiprazole monthly LAI.^45–47,49–51,54–56,61,123,125,133,136,148,150,151,154,155,161,163,167,169,171,172,174–178,184,186–188,196–227^
SGA vs. SGA | Withdrawal due to adverse events | Low | Risperidone LAI had significantly lower risk than clozapine (OR 0.27, 95% CI 0.10 to 0.71); lurasidone (OR 0.39, 95% CI 0.18 to 0.84); quetiapine ER (OR 0.43, 95% CI 0.22 to 0.81); risperidone (OR 0.50, 95% CI 0.25 to 0.99); and ziprasidone (OR 0.40, 95% CI 0.20 to 0.82) based on a network meta-analysis of 90 trials. Olanzapine had lower risk than clozapine (OR 0.39, 95% CI 0.19 to 0.79); lurasidone (OR 0.57, 95% CI 0.34 to 0.94); quetiapine (OR 0.62, 95% CI 0.44 to 0.87); risperidone (OR 0.72, 95% CI 0.55 to 0.96); and ziprasidone (OR 0.58, 95% CI 0.41 to 0.82) clozapine based on a network meta-analysis of 90 trials Aripiprazole had lower risk than clozapine (OR 0.43, 95% CI 0.21 to 0.88) and ziprasidone (OR 0.64, 95% CI 0.44 to 0.94). Cariprazine (OR 0.40, 95% CI 0.17 to 0.95) and iloperidone (OR 0.34, 95% CI 0.13 to 0.91) had lower risk than clozapine based on a network meta-analysis of 90 trials. Meta-regression examining the influence of study duration, dose-level, and either treatment-resistant or first-episode status did not result in any significant findings.
FGA vs. SGA | Quality of life | Moderate | There were no differences between haloperidol and olanzapine in quality of life scores. (SOE: Moderate); or perphenazine and olanzapine, quetiapine, risperidone or ziprasidone.^28^
FGA vs. SGA | Quality of life | Low | One trial comparing haloperidol with ziprasidone found a positive effect favoring ziprasidone (effect estimate −12.12; 95% CI −22.06 to −2.17) with no difference between groups in another trial.^28^ There were no differences between haloperidol and olanzapine; or perphenazine and quetiapine, risperidone or ziprasidone.^28^
FGA vs. SGA | Response/Remission | Moderate | There was no difference in response rates between haloperidol and risperidone (16 RCTs, N=3,452; RR 0.94; 95% CI 0.87 to 1.02).^28^
FGA vs. SGA | Response/Remission | Low | Pooled results from 14 RCTs comparing haloperidol with olanzapine found a significant effect on response rate favoring olanzapine (N=4,099; RR 0.86; 95% CI 0.78 to 0.96).^28^ Three trials comparing haloperidol with olanzapine found a significant difference in remission rates favoring olanzapine (pooled RR 0.65; 95% CI 0.45 to 0.94; I^2^=54%).^28^ There was no difference in response rates between haloperidol and aripiprazole (5 RCTs, N=2,185; RR 1.01; 95% CI 0.76 to 1.34), quetiapine (6 RCTs, N=1,421; RR 0.99; 95% CI 0.76 to 1.30) and ziprasidone (6 RCTs, N=1,283; RR 0.98; 95% CI 0.74 to 1.30).^28^ There was no difference in remission rates between haloperidol and ziprasidone based on three trials (RR 0.89; 95% CI 0.71 to 1.12).^28^
FGA vs. SGA | Core illness symptoms: Total symptom score | Moderate | There were significant difference in total PANSS between haloperidol and olanzapine (15 RCTs, N=4,209; mean difference 2.31; 95% 0.44 to 4.18) and risperidone (21 RCTs, N=4,020; mean difference 3.24; 95% CI 1.62 to 4.86), both favoring the SGA over haloperidol.^28^
FGA vs. SGA | Core illness symptoms: Total symptom score | Low | There were no differences in total PANSS, BPRS, CGI-S and CGI-I scores for other FGA versus SGA comparisons.^28^
FGA vs. SGA | Core illness symptoms: Negative symptom score | Moderate | Olanzapine was more effective than haloperidol at improving negative symptoms based on SANS scores (5 RCTs, N=535; mean difference 2.56; 95% CI 0.94 to 4.18).^28^
FGA vs. SGA | Core illness symptoms: Negative symptom score | Low | Using the negative symptoms subscale of the PANSS scale, mean differences (although small) between haloperidol and aripiprazole (3 RCTs, N=1,701; 0.80; 95% CI 0.14 to 1.46), olanzapine (14 RCTs, N=3,742; 1.06; 95% CI 0.46 to 1.67), and risperidone (22 RCTs, N=4,142; 0.80; 95% CI 0.14 to 1.46) all favored the SGA.^28^ There were no differences in negative PANSS or SANS scores for other FGA versus SGA comparisons.
FGA vs. SGA | Overall/any adverse events | Moderate | Overall adverse event rates favored SGAs when comparing haloperidol with aripiprazole (3 RCTs, N=1,713; RR 1.11; 95% CI 1.06 to 1.17; I^2^=0%), risperidone (8 RCTs, N=1313; RR 1.20; 95% CI 1.01 to 1.42; I^2^=84%), and ziprasidone (6 RCTs, N=1448; RR 1.13; 95% CI 1.03 to 1.23; I^2^=31%).^28^
FGA vs. SGA | Withdrawal due to adverse events | Moderate | When comparing haloperidol with specific SGAs, withdrawals due to adverse events were significantly higher with haloperidol use compared with aripiprazole (8 RCTs, N=3,232; RR 1.25; 1.07 to 1.47; I^2^=0%), olanzapine (24 RCTs, N=5,708; RR 1.89; 95% 1.57 to 2.27; I^2^=0%), risperidone (25 RCTs, N=4,581; RR 1.32; 95% CI 1.09 to 1.60; I^2^=0%), and ziprasidone (7 RCTs, N=1,597; RR 1.68; 95% 1.26 to 2.23; I^2^=0%).^28^

BPRS = Brief Psychiatric Rating Scale; CATIE = Clinical Antipsychotic Trials of Intervention Effectiveness; CGI = Clinical Global Impressions scale; CI = confidence interval; df = degrees of freedom; ER = extended release; FGA = first-generation antipsychotic; GAF = Global Assessment of Functioning; HR = hazard ratio; IR = immediate release; LAI = long-acting injectable; LSM = least squares mean; NNT = number needed to treat; OR = odds ratio; PANSS = Positive and Negative Syndrome Scale; PSP = Personal and Social Performance Scale; RCTs = randomized controlled trials; RR = risk ratio; SANS = Scale for the Assessment of Negative Symptoms; SF-12 = 12-item Short Form Health Survey; SGA = second-generation antipsychotic; SMD = standardized mean difference, SOE = strength of evidence; SOFAS = Social and Occupational Functioning Assessment Scale; SQLS-R4 = Schizophrenia Quality of Life Scale- Revision 4; WMD = weighted mean difference

Table 11 Summary of evidence for psychosocial and nonpharmacological interventions

Intervention vs. Usual Care | Outcome | Strength of Evidence | Conclusions
Assertive community treatment (ACT) | Social Function | Low | ACT did not improve improved social function more than usual care, based on pooled analysis of 3 studies (MD 0.03; 95% CI −0.28 to 0.34); an additional trial also found no difference.^71,72^ Compared with usual care, there were no significant differences in arrests (2 trials, total N=604; OR 1.17, 95% CI 0.60 to 2.29; I^2^=0%), imprisonment (4 trials, total N=471; OR 1.19, 95% CI 0.70 to 2.01; I^2^=27%), or police contacts (2 trials, total N=149; OR 0.76, 95% CI 0.32 to 1.79; I^2^=84%).^71^
ACT | Housing Function | Moderate | Patients receiving ACT had lower likelihood of not living independently (4 trials; OR 0.52, 95% CI 0.35 to 0.79),^71^ or being homeless (4 trials, OR 0.24, 95% CI 0.12 to 0.48) compared with usual care.^71,72^
ACT | Employment | Moderate | Patients receiving ACT had lower likelihood of being unemployed than those receiving usual care (3 trials; OR 0.46, 95% CI 0.21 to 0.99).^71^
ACT | Core illness symptoms: symptoms | Moderate | Core illness symptoms improved with both ACT and usual care, with no differences between groups (MD, −0.14; 95% CI −0.36 to 0.08); one additional trial also found no difference in symptom improvement.^71,72^
Cognitive behavioral therapy (CBT) | Global, Social and Occupational Function Short-term (≤ 6 months since initiation) | Moderate | CBT improved global function more than usual care in the short-term (GAF scale, 6 trials; MD 5.49; 95% CI 1.85 to 9.14). CBT improved social and occupational function more than usual care in the short-term (SOFAS scores, 2 trials; MD 9.11; 95% CI 6.31 to 11.91)^78,83,95,274,278,279^
Cognitive behavioral therapy (CBT) | Global, Social and Occupational Function Long-term (> 1 year since initiation) | Low | Global and social/occupational function were not different to usual care in longer-term followup (>1 year, GAF and SOFAS scores in one systematic review and three RCTs; one other RCT found a positive effect in favor of CBT).^76,78,93,276,279^
Cognitive behavioral therapy (CBT) | Quality of life | Low | CBT improved quality of life more than usual care in the short term (12 to 24 weeks followup) based on two trials,^80,83^ but this difference was not found in two trials with longer followup (18 to 24 months).^93,279^
Cognitive behavioral therapy (CBT) | Core Illness symptoms | Moderate | CBT had a greater effect on core illness symptoms than usual care during treatment (8 weeks to 5 years) based on a good-quality systematic review of 34 studies (SMD −0.33, 95% CI −0.47 to −0.19).^77^
Cognitive behavioral therapy (CBT) | Negative symptoms | Low | No meaningful difference between CBT and usual care in negative symptom improvement based on two systematic reviews.^77,79^ The target of the CBT was varied in the studies included, with few targeting negative symptoms.
Cognitive Remediation | Global, Social, Occupational Function | Low | Compared with usual care, cognitive remediation resulted in a small positive effect on social, occupational, living situation and global function, based six RCTs (effect sizes ranged from 0.16 to 0.40).^87–89^
Cognitive Remediation | Core Illness symptoms | Moderate | Cognitive remediation resulted in small improvements in core illness symptoms, based on 2 trials (SMD −0.62 (95% CI−1.01 to −0.24).^86,89^
Cognitive Remediation | Negative symptoms | Moderate | Negative symptoms were significantly improved with cognitive remediation compared with usual care (1SR of 18 RCTs, effect size −0.36, 95% CI −0.52 to −0.20).^85^
Early Interventions for First-Episode Psychosis | Global Function | Moderate | Pooled results found that the early team-based multi-component treatment programs resulted in higher functioning, based on GAF and GAS scores after up to 2 years of treatment (3 RCTs; WMD: 3.88; 95% CI 0.91 to 6.85; I^2^=64%).^111,113,114,296^
Early Interventions for First-Episode Psychosis | Social Function | Moderate | Early team-based multi-component treatment programs resulted in significantly more people (22%) working or in school after up to 2 years of treatment (3 RCTs; RR 1.22; 95% CI 1.01 to 1.47).^111,113,114,296^
Early Interventions for First-Episode Psychosis | Housing Function | Low | There was no significant differences between early team-based multi-component treatment programs and usual care on housing status for up to 2-year treatment duration based on two RCTs.^111,113,296^
Early Interventions for First-Episode Psychosis | Quality of life | Moderate | Two RCTs found significant differences between early team-based multi-component treatment programs and usual care on quality of life scores for up to 2-year treatment duration (pooled effect size 0.84; 95% CI 0.14 to 1.55).^113,117^
Early Interventions for First-Episode Psychosis | Reduction in self-harm | Low | There was no difference in reduction in self-harm in two trials of early team-based multi-component treatment programs versus usual care.
Early Interventions for First-Episode Psychosis | Core Illness symptoms | Low | There was no difference between early team-based multi-component treatment programs and usual care in core illness symptoms, based on three RCTs (WMD on PANSS −2.53; 95% CI −5.45 to 0.39; I^2^=55%).^113,114,117^
Early Interventions for First-Episode Psychosis | Relapse | Moderate | Early team-based multi-component treatment program participants were significantly less likely to relapse compared with those in usual care based on two RCTs (RR 0.64; 95% CI 0.52 to 0.79).^112,114^
Supported Employment | Occupational Function | Low | Supported employment, using the individual placement and support (IPS) model resulted in significantly better employment outcomes over 2 years compared with usual care (more patients were employed, competitive or any job, worked more hours, were employed longer, and earned more money). ^109^ Evidence with vocational training control groups supports these findings.
Family Interventions | Social Function | Low | There were no differences in social functioning scale scores or not being able to live independently between family intervention and usual care based on one RCT.^95^
Family Interventions | Occupational Function | Low | There were no differences in unemployment rates between participants in family interventions and usual care at 1 year based on one systematic review.^91^
Family Interventions | Reduction in self-harm | Low | Suicide rates were similar in family intervention participants and those who received usual care in one SR, but events were few.^91^
Family Interventions | Core Illness symptoms | Low | Family interventions reduced core illness symptoms based on 4 trials (SMD −0.46, 05% CI −0.73 to −0.20). ^91,93,96^ but there was no difference in core illness symptoms.
Family Interventions | Relapse | Moderate | Family interventions resulted in significantly lower relapse rates at 7 to12 months based on one systematic review^91^ and four additional studies^93,96,97,290^ (31% vs. 45%, RR 0.67; 95% CI 0.54 to 0.83).
Family Interventions | Relapse | Low | Family interventions resulted in lower relapse rates at 0 to 6 months compared with usual care based on one systematic review^91^ plus one additional trial^290^ (23% vs. 37%, RR0.62; 95% CI 0.41 to 0.92), at 13–24 months based on a systematic review^91^ (49% vs. 61%; RR 0.75, 95% CI 0.58 to 0.99) and at 5 years followup based on a systematic review^91^ plus one additional trial^289^ (78% vs. 94%, RR 0.82; 95% CI 0.72 to 0.94). The difference at 25 to 36 months was not significant.^91^
Intensive Case Management (ICM) | Global Function | Low | ICM did not differ significantly from usual care in change in global function, based on pooled analysis of 3 studies (MD 0.46; 95% CI −0.34 to 1.26).^98,99^ There was no difference in rates of imprisonment based on pooled analysis of 5 trials (OR 0.90, 95% CI 0.45 to 1.82).^98^
ICM | Core Illness symptoms | Low | ICM was not significantly different to usual care in improvement in core illness symptoms, based on pooled analysis of 2 studies (MD, 0.46; 95% CI −3.67 to 4.60). One subsequent trial also reported no difference in symptoms using a different scale.^98,99^
Illness self-management | Core Illness symptoms | Moderate | Participants receiving a self-management education intervention were significantly more likely to demonstrate a reduction in severity of core illness symptoms based on the BPRS (5 RCTs; pooled WMD=−4.19, 95% CI −5.84 to −2.54).^100^
Illness self-management | Negative symptoms | Low | There was no change in negative symptoms based PANSS – negative subscale based on five RCTs.^100^
Illness self-management | Relapse | Low | Patients receiving more than 10 self-management intervention sessions had a greater reduction in the likelihood of experiencing relapse compared with usual care (OR 0.41; 95% CI 0.21–0.79), whereas those receiving 10 or fewer sessions had a smaller, nonsignificant, reduction in the risk of relapse (OR 0.67, 95% CI 0.39 to 1.15) based on one SR.^100^
Psychoeducation | Global Function | Low | Psychoeducation had a greater effect than usual care on global functional outcomes at 1 year of followup based on one good-quality systematic review of three studies (MD −5.23, 95% CI −8.76 to −1.71; I^2^=79%).^102^
Psychoeducation | Relapse | Moderate | Psychoeducation had a greater effect than usual care on relapse rates (with or without readmission) at nine to 18 months of followup based on one good-quality systematic review of six studies (RR 0.80, 95% CI 0.70 to 0.92; I^2^=54%).^102^
Psychoeducation | Harms | Low | There was no difference between psychoeducation and usual care in rate of harms based on 10 RCTs.^102^
Social Skills Training | Social Function | Low | Social Function was significantly better in patients receiving 6 months (SMD 1.60; 95% CI 1.19 to 2.02), 1 year (SMD 2.02; 95% CI 1.53 to 2.52) and 2 years (SMD 0.65; 95% CI 0.36 to 0.95) of social skills training in three studies (in four publications).^97,103–105^
Social Skills Training | Core Illness symptoms | Low | Core illness symptoms improved more with social skills training vs. usual care at 6 months based on two RCTs (SMD on PANSS −1.50 (95% CI −1.92 to −1.09 and 2 years −0.81 (95% CI −1.22 to −0.40).^97,105^
Social Skills Training | Negative symptoms | Low | Negative symptoms were consistently and significantly improved with social skills training relative to usual care in three studies (SMD range −0.45 to −1.30; in four publications).^97,103–105^
Supportive Therapy | Global and Social Function | Low | There was no difference between supportive therapy and usual care for global or social function based on two studies in a systematic review.^110^

ACT = assertive community treatment; BPRS = Brief Psychiatric Rating Scale; CBT = cognitive behavioral therapy; CI = confidence interval; GAF = Global Assessment of Functioning; GAS = Global Assessment Scale; ICM = intensive case management; MD = mean difference; OR = odds ratio; PANSS = Positive and Negative Syndrome Scale; RCT = randomized controlled trial; RR = risk ratio; SMD = standardized mean difference; SOFAS = Social and Occupational Functioning Assessment Scale; SR = systematic review; WMD = weighted mean difference

### Key Questions 1a and 1b Comparative Evidence Regarding Antipsychotic Drugs

The findings on antipsychotic drugs come from two large systematic reviews^27–29^ and a total of 28 additional, newer trials^43–70^ (One trial is included in both the first-generation antipsychotic (FGA) versus second generation antipsychotic (SGA) and SGA versus SGA sections.^57^) The prioritized outcomes were function, quality of life, response and/or remission, mortality, self-harm, core illness symptoms, overall adverse events, and withdrawal from treatment due to adverse events. The evidence is divided into SGA versus SGA and FGA versus SGA according to traditional categorization of the drugs used in the two systematic reviews, although the drugs could be considered as one group with variations in effects associated with individual drugs.

#### Second-Generation Drugs: SGA Versus SGA

We found the most evidence about the older SGAs (clozapine, risperidone, olanzapine, quetiapine, and ziprasidone). We also found some evidence on the most commonly reported outcomes (e.g., core illness symptom improvement) for oral aripiprazole and paliperidone. Evidence for the newer drugs (asenapine, brexpiprazole, cariprazine, iloperidone, lurasidone, paliperidone, and long-acting injectable (LAI) formulations of aripiprazole and paliperidone) is limited, with few studies, none finding a newer drug superior to an older SGA on any outcome. Similarly, quetiapine and ziprasidone were not found superior to another SGA on any outcome (Table 10). Tables showing the summary results for each drug, indicating magnitude, direction, and strength of evidence for an effect across all seven prioritized outcomes are included in Appendix I.

##### Benefits Outcomes

Although functional outcomes were prioritized as most important, few studies of SGA versus SGA reported these outcomes. Very few differences were found among the older SGAs regarding effects on social, occupational, or global functioning. Low strength evidence from a single study found risperidone LAI to result in greater improvements in social function over 24 months compared with quetiapine. None of the studies of the newer SGAs reported on functional outcomes. Findings on quality of life show that there was no difference between olanzapine and risperidone or ziprasidone (moderate-strength evidence); olanzapine or risperidone oral or LAI and quetiapine; oral aripiprazole and aripiprazole monthly LAI (low-strength evidence) in studies with up to 2 years of followup.

Response and remission are dichotomous outcomes, which are measured as response or no response, remission or no remission. By definition, response and remission are outcomes that are meant to reflect clinically relevant improvement in core illness symptoms. However, response was defined in varying ways in the randomized controlled trials (RCTs), although the most common definition was 20 percent improvement on a core illness symptoms scale, such as the Positive and Negative Syndrome Scale (PANSS). Low-strength evidence from a network meta-analysis of 46 head-to-head trials found that olanzapine and risperidone were significantly more likely to result in response than quetiapine. Other comparisons and meta-regression examining the influence of study duration, dose-level, population (either treatment-resistant or first-episode status), and category of response definition did not result in any statistically significant differences between the SGAs (low-strength evidence). Remission was reported too infrequently to assess comparatively.

Improvement in core illness symptoms is a continuous outcome measured as the mean change in symptoms using a scale. A published network meta-analysis found that clozapine was superior to other oral SGAs except for olanzapine in improving core illness symptoms. Olanzapine and risperidone were not significantly different in treating core illness symptoms compared with each other, and both were superior to the other SGAs, except for paliperidone and clozapine. Paliperidone also improved core illness symptoms more than lurasidone and iloperidone. This network analysis also found that all of the drugs included were superior to placebo. These findings are low strength evidence. In treatment-resistant patients, olanzapine improved core illness symptoms more than quetiapine. These findings are based on two published network meta-analyses (low-strength evidence).

All-cause mortality is a rare event, but it is still an important outcome to evaluate as SGAs continue to be developed, approved, and marketed, and particularly as all SGAs carry a United States Food and Drug Administration (FDA) Boxed Warning against their use in older patients with dementia due to increased risk of mortality. Low-strength evidence suggests that the mortality rate is low in SGA trials and cohort studies (0 to 1.17%), and that there were no differences in mortality rates between olanzapine and risperidone or asenapine, risperidone and quetiapine, or paliperidone palmitate monthly LAI and risperidone LAI. There were also no differences in cardiovascular mortality among risperidone, olanzapine, and quetiapine. Comparative evidence on the risk of cardiovascular or all-cause mortality was not available for the other SGA drugs. Self-harm, including suicide deaths, while infrequent is a major cause of death among individuals with schizophrenia that antipsychotics, along with other interventions, are intended to help prevent. Although clozapine is often reserved for treatment-resistant patients, due to the serious adverse event profile and required monitoring, there is moderate strength evidence supporting its superiority over the other SGAs (primarily the older ones) in preventing self-harm (suicide-related outcomes) in both patients at risk for suicide-related outcomes (vs. olanzapine) and in patients with unknown or mixed risk for these outcomes (vs. olanzapine, risperidone, quetiapine, ziprasidone, and aripiprazole).

##### Harms Outcomes

Although SGAs have somewhat differing adverse event profiles, the evidence indicates no difference in the overall risk for adverse events between asenapine and olanzapine (moderate-strength evidence) or quetiapine extended release (ER) versus quetiapine and risperidone; risperidone versus clozapine and aripiprazole; olanzapine versus paliperidone; risperidone LAI versus paliperidone and paliperidone palmitate monthly LAI; and aripiprazole versus aripiprazole monthly LAI (all low strength evidence). Given the variation in specific adverse event profiles across the SGAs, withdrawals due to adverse events is an outcome measure that has the advantage of measuring the seriousness and tolerability of adverse events experienced, including those that might be treated with another drug or dose reduction. Network meta-analysis of 90 trials indicates that risperidone LAI had significantly lower risk of withdrawal due to adverse events than five other SGAs: clozapine, lurasidone, quetiapine ER, risperidone and ziprasidone. Olanzapine had lower risk than five other SGAs: clozapine, lurasidone, quetiapine, risperidone, and ziprasidone. Aripiprazole had lower risk than clozapine and ziprasidone, and cariprazine and iloperidone had lower risk than clozapine. Comparative evidence on extrapyramidal symptoms (EPS), cardiovascular events, diabetes, weight gain, metabolic syndrome, and sexual function is summarized in the Drug Effectiveness Review Project report.^29^ Although these were secondary outcomes in this report, in general the evidence is not able to identify differences between drugs studied in cardiovascular adverse events, metabolic syndrome, and sexual function. Risk of diabetes and weight gain is greater with olanzapine, with increased risk of weight gain also found with clozapine and quetiapine. Findings on EPS are more mixed.

##### Subgroups

Evidence in subgroups was sparse and low strength. In patients experiencing their first episode of schizophrenia, response and remission were not significantly different among olanzapine, quetiapine, risperidone, ziprasidone, aripiprazole, or paliperidone. Most studies also reported no difference in improvement in core illness symptoms, measured by symptoms scales. Although core illness symptoms were more improved with paliperidone than ziprasidone or aripiprazole, response rates did not differ significantly. Response rates with olanzapine and risperidone were similar in patients with first-episode schizophrenia compared with patients with multiple previous episodes. Findings on core illness symptoms or response did not differ according to the duration of study, the specific drugs compared, in women, or whether or not studies were blinded. Evidence on SGA treatment discontinuation was more limited, with conflicting findings from five trials. An included systematic review reports that the incidence of clinically important weight gain is significant in first episode patients, who have little previous exposure to antipsychotics, but differences among the SGA drugs has not been shown. These studies did not find a difference in benefits outcomes between risperidone and olanzapine over the first 3 years of treatment, but they found that that risperidone had higher risk of some specific adverse events (worsening akathisia, sexual dysfunction, or amenorrhea). Aripiprazole had either lower rates of or longer time to discontinuation due to adverse events than ziprasidone or quetiapine.

In treatment-resistant patients, a network meta-analysis of 40 RCTs indicated that olanzapine resulted in greater improvement in core illness symptoms, although the difference in mean change (−6 points) in the PANSS may not meet minimal clinically important difference criteria (−11.5 points for more severe symptoms), depending on the severity of the patients symptoms at baseline. A network meta-analysis of negative symptoms also found olanzapine significantly better than the other older SGAs, whereas response rates and all-cause treatment discontinuations indicated no significant differences among the older SGAs. Clozapine had fewer discontinuations due to lack of efficacy than risperidone and quetiapine.

Across the 46 trials reporting response, the rates ranged from 20 to 80 percent across SGA trial arms. The variation appears be associated with prior drug exposure of patients enrolled; patients resistant to previous treatment had lower rates of response and those with a first episode had greater rates.

The evidence on other subgroups of patients is limited. Analysis of age subgroups did not find differences for comparisons of olanzapine with risperidone. Women had greater improvements than men in core illness symptoms with clozapine and in quality of life with olanzapine. Improvement in core illness symptoms was similar in Asian patients, compared with overall study populations for comparisons of aripiprazole and paliperidone with olanzapine, quetiapine, and risperidone. Among illicit drug users, differences between older SGAs were not found in rate or time to drug discontinuation. Response rates with olanzapine and risperidone were similar in patients with a history of cannabis use disorders and in those without such history.

#### First-Generation Antipsychotic Versus Second-Generation Antipsychotic

Although the SGAs were initially marketed as having multiple advantages over the FGAs, there has been concern that the evidence on first-generation versus second-generation antipsychotics was biased toward the SGAs in various ways (e.g., using higher than typical doses of the first-generation drugs). The Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) trial included one FGA along with five SGAs to test this theory. The trial did not find perphenazine to be inferior to the other drugs, with the exception of olanzapine. However, the CATIE trial did not resolve the questions around the use of FGAs in current practice, such that a thorough review of the comparative evidence is still necessary. The findings of the comprehensive systematic review of FGAs versus SGAs published in 2012 are not substantially changed with the additional consideration of five newer studies (two good quality, three fair quality). The 111 trials included in the previously published systematic review were rated as mainly fair quality (70 studies), with 41 rated as poor quality, and none rated as good quality. The FGA evidence is largely about haloperidol, with 108 studies, and only 7 of perphenazine and 4 of fluphenazine. Olanzapine was the most commonly compared SGA.

##### Benefits Outcomes

Quality of life, a highly prioritized outcome, was not different between the FGAs and SGAs, based on low (quetiapine and risperidone) to moderate (olanzapine) strength evidence. Only ziprasidone was found better than haloperidol with low strength evidence. Evidence on functional outcomes was insufficient to draw conclusions. Moderate strength evidence suggests that risperidone is not different from haloperidol in response rates. Low strength evidence finds that response and remission were better with olanzapine than haloperidol, but no differences were found in response between haloperidol and aripiprazole, quetiapine and ziprasidone or in remission between haloperidol and ziprasidone.

Comparative evidence on core illness symptoms is only available for haloperidol versus older SGAs. Moderate strength evidence suggests that core illness symptoms were improved significantly more with olanzapine and risperidone than haloperidol, but evidence on other comparisons did not show significant differences (low strength evidence). Olanzapine improved negative symptoms significantly more than haloperidol (moderate strength evidence), and risperidone and aripiprazole improved negative symptoms significantly more than haloperidol (low strength evidence).

##### Harms Outcomes

Overall rates of patients reporting adverse events were 11 to 20 percent higher with haloperidol versus aripiprazole (moderate strength evidence), risperidone, and ziprasidone (low strength evidence). Similarly, moderate strength evidence indicates a higher rate of withdrawal from study (and treatment) due to adverse events with haloperidol, versus aripiprazole, olanzapine, risperidone, and ziprasidone. There were no differences in withdrawal due to adverse events between haloperidol and clozapine or quetiapine.

##### Subgroups

Evidence comparing FGAs to SGAs in population subgroups is fairly limited, with unclear implications. In general, differences in outcomes were not found between FGAs and SGAs in patients with a first episode of schizophrenia. In treatment-resistant patients the effects on total core illness symptoms and negative symptoms mirrored the findings in the overall population. Response and core illness symptom improvement was similar in Asian populations and the overall study populations. In patients with co-occurring substance use disorder, core illness symptoms were improved more with olanzapine than haloperidol, but improvement in core illness symptoms was comparable for risperidone and haloperidol.

Evidence on pharmacological treatments is summarized in Table 10.

### Key Questions 2a and 2b Evidence on Psychosocial and Other Nonpharmacological Interventions Versus Usual Care

The studies included in our review evaluated 13 discrete psychosocial interventions in comparison with usual care. The purpose was not to evaluate head-to-head comparisons of active interventions to each other. The evidence base is comprised of 13 systematic reviews (11 good quality, 2 fair quality) that included 271 trials relevant to this report. In addition, we included 27 trials that were not included in these reviews. Of these new trials, four were good, 20 were fair, and three were poor quality. The strength of the body of evidence for each intervention-outcome pair was moderate and low strength overall (Table 11).

#### Benefit Outcomes

Patients receiving assertive community treatment were more likely to be living independently and employed and were less likely to be homeless or to discontinue treatment compared with patients assigned to usual care (moderate SOE). There were no significant difference in the degree of improvement in core illness symptoms or social functioning, and there were no differences in arrests, imprisonment, or police contacts compared with usual care (low SOE). Rehospitalization, the target of this intervention, was also significantly lower with assertive community treatment than usual care, as well as the duration of hospital stay.

Cognitive behavioral therapy (CBT) resulted in improvements in global function and quality of life (low SOE), and overall core illness symptoms (moderate SOE) compared with usual care during treatment and with up to 6 months followup. In studies with longer-term followup after CBT ended, these differences were not significant, although there were few studies with a usual care control group. Low strength evidence suggests that improvement in negative symptoms was not different between CBT and usual care.

Cognitive remediation resulted in small positive effects on social, occupational, and global function, core illness symptoms (low SOE) and negative symptoms (moderate SOE) compared with usual care over 15 to 16 weeks of treatment.

Family interventions resulted in significantly lower relapse rates than usual care at up to 24 months treatment and at 5 years followup, although differences were not found from 25 to 36 months. Family interventions were also associated with improved core illness symptoms. Differences were not noted in social function, including employment and housing situation, reduction in self-harm (moderate SOE for reduced relapse from 7 to 12 months, low SOE for all others).

Intensive case management (ICM) was not found to improve global function, quality of life, or core illness symptoms more than usual care (low SOE).

Illness self-management training interventions reduced symptom severity (moderate SOE) and relapse rates (low SOE). No significant difference was found for negative symptoms (low SOE). Greater fidelity to intervention was associated with better effects.

Psychoeducation had a greater effect than usual care on global function at 1 year and resulted in lower relapse rates at nine to 18 months (moderate SOE).

Social skills training improved social function at 6 months, 1 year, and 2 years, compared with usual care. Core illness symptoms and negative symptoms were also improved more with social skills training than usual care.

Supported employment, specifically the individual placement and support (IPS) model intervention, resulted in significantly better employment outcomes over 2 years compared with usual care. More patients gained either employment (competitive or any job), had worked more hours, were employed longer, and earned more money than those receiving usual care. Evidence with comparisons with other vocational training confirmed these findings (moderate SOE).

Supportive therapy was not significantly different from usual care in improving global or social function (low SOE).

#### Subgroups

##### Demographic Subgroups

We found limited subgroup analyses across psychosocial interventions to identify potential patient characteristics that might predict outcomes. Limited evidence on social skills training from one RCT of a mixed population (about 50% diagnosed with schizophrenia or schizoaffective disorder) suggested that the intervention may be more effective in men than women for improving social function and core illness symptoms.

##### Clinical Subgroups

Early team-based multi-component treatment programs for first-episode psychosis resulted in significant improvements in global function with up to 2 years of treatment compared with usual care; participants were more likely to be working or in school, but there were no significant differences in housing status (moderate SOE). Quality of life was improved and participants in team-based multi-component treatment programs were less likely to relapse (moderate SOE), but there was no difference in total PANSS scores or rates of self-harm compared with usual care (low SOE).

In patients with co-occurring substance use disorder and schizophrenia, long-term integrated models of care did not result in different improvements in function, mortality, or substance abuse than usual care.

#### Harms Outcomes

Four trials and seven systematic reviews assessed or reported any type of harms associated with psychosocial or other nondrug interventions. The few that did (e.g., studies of family interventions) resulted in insufficient evidence.

Evidence for Key Question 2 is summarized in Table 11.

## Findings in Relationship to What Is Already Known

With regard to drug therapy, the findings of our review are generally consistent with prior systematic reviews that make comparisons among the SGAs and between SGAs and FGAs.^183,194,263,264,297,298^ Although we incorporated the most relevant of these systematic reviews in our report, our findings differ to some extent from previous reviews because we consider outcomes prioritized by technical experts, incorporate newer evidence and the most recently approved drugs, and include three updated network meta-analyses. For example, in comparing SGAs, our network meta-analyses of response, withdrawal due to adverse events, and all-cause treatment discontinuation of treatment incorporate evidence on brexpiprazole and cariprazine, the two most recently approved oral drugs, and all of the long-acting injection SGAs, whereas the previously published network meta-analyses are limited to older oral drugs, included drugs not approved in the United States, and did not control for important potential effect modifiers.^183,194,297–301^ Therefore, there are no existing reviews that cover the same scope as this report.

Our review is consistent with other reviews in the findings on the older SGAs. Clozapine, risperidone, and olanzapine have the most consistent evidence of superiority for specific outcomes (e.g., symptom improvement, response, self-harm, all-cause treatment discontinuations, and time to discontinuation), or populations (first-episode and treatment-resistant).^263,300,302–304^ Other findings in this review are new; such as the finding that risperidone LAI and olanzapine result in significantly lower withdrawals due to adverse events than several other SGAs. Previous reviews did not assess key effectiveness outcomes, such as function, quality of life, and mortality.

A single comprehensive review on FGAs versus SGAs is available and serves as the basis of our report, with nine new trials included.^27,28^ Our findings are generally consistent with this review, which concluded that there were few differences of clinical importance for effectiveness outcomes, and that evidence on patient-important outcomes and adverse events were not well studied. In adding new evidence, we found moderate-strength evidence of specific SGAs resulting in better symptom improvement (olanzapine and risperidone) and lower rates of overall adverse events (aripiprazole) and withdrawal due to adverse events (aripiprazole, olanzapine, risperidone, and ziprasidone) than haloperidol.

For the psychosocial interventions, our findings are consistent with some prior review findings, and discordant with others. Key reasons for differing findings can be attributed to study eligibility criteria, outcomes included, inclusion of additional, newer, studies, and review methodology. For example, we included only trials with a usual care comparison group and excluded studies with sample sizes <50 patients and studies conducted in countries that were not United States relevant (in this case, primarily studies conducted in China). Each of these criterion eliminated studies that were included in some other reviews.

The decision to focus our review of psychosocial interventions on comparisons with usual care was made as part of a set of decisions required to reduce the scope of the project. After identifying a large body of evidence for Key Question 2, we determined that the funding and timeline required a reduction in scope. We first decided to use systematic reviews as the primary evidence, with subsequently published trials included as well. Examining those, we saw a large amount of heterogeneity in how control groups were defined and handled. In some reviews, all controls were lumped together, while in others “active” and usual care controls were assessed separately. Controls described as “active” varied widely, from competing interventions to attention controls, and were not handled consistently across reviews. For example, interventions categorized as “active” in one review were evaluated separately as “passive” in another review. Many, however, reviewed usual care comparisons separately, or exclusively. Therefore, within the systematic reviews, usual care was the most commonly reported comparison group. In the end we included well over 200 studies of psychosocial interventions that made comparisons to usual care. The implications of this choice certainly have been contemplated in the literature before^77,305–307^ with no clear conclusion, although some have found little difference in analyses limiting to usual care comparisons and those including other comparisons.^77^ The potential bias introduced by this decision depends on the usual care actually received by patients in the control group. For example, if no difference was found between an intervention and usual care controls, it could be attributed to better usual care; but where a difference was found it could be due to the intervention, lower quality usual care, or a combination of factors. In addition, the magnitude of difference could be affected. The difference in usual care received could occur at the patient level, the study level or at the body of evidence level for a given intervention.

The decision to eliminate studies conducted in China mainly affected the body of studies for family interventions. In this case, both a prior Cochrane review and our own analysis indicate that the studies from China very likely overestimate treatment effects, which is consistent with the findings of other researchers in other clinical areas.^308^ Our decision to exclude rehospitalization as one of the prioritized outcomes was made after considering input from our technical expert panel, reflecting the lack of confidence that the findings are meaningful across time and different healthcare systems or settings. While studies of a few interventions regularly report this outcome, primarily as a proxy for relapse, we found that only assertive community treatment formally targets reducing rehospitalization. Hence, we reported rehospitalization as an outcome only for that intervention in the full report.

The other potential reasons for differences are to be expected – our searches are more recent, adding new evidence that could alter the prior findings, and we used the most up-to-date systematic review methodology, including assessing the strength of the body of evidence, based on domains including study methodological limitations, directness and consistency of evidence, and precision of estimates of effect. Our finding that the SOE for psychosocial interventions was moderate and low is consistent with our findings for antipsychotic drugs, and with numerous reviews across other populations and interventions. This system helps to make clear where future studies could alter findings, either in direction or magnitude, inform future research, and identify outcomes for which a given intervention is not effective. It does not, however, determine whether the intervention is useful or not in a broader sense, since the ratings are made on an outcome-by-outcome basis.

Below we summarize our findings in the context of key prior reviews for selected interventions, where there may be concern over how our and why findings differ. Because The Schizophrenia Patient Outcomes Research Team (PORT) 2009 publication is a highly regarded resource that assessed evidence and made recommendations on using several psychosocial interventions, we include their findings as well as individual reviews of these specific interventions.^295^

### Cognitive Behavioral Therapy

Overall, our findings are consistent with prior findings, except that we find additional outcomes where CBT showed benefit over usual care, and we did not find strong evidence regarding duration of effects. The use of CBT in schizophrenia has historically been focused on reducing positive symptoms.^309,310^ Consistent with other reviews, we found CBT to be effective at improving core illness symptoms with treatment durations of 8 weeks to 5 years and additionally for outcomes other than symptoms, even when those outcomes were not the focus of the CBT.^78,309^ Specifically, we found short-term measures of global, social and occupational function, quality of life and relapse requiring hospitalization to be significantly better with CBT based on low to moderate SOE. These findings build on the findings of prior reviews and the PORT publication, which noted that there was evidence that CBT improved symptoms (positive, negative, and overall) and social function - but that there were also studies that did not find these effects, and that there was no good evidence on relapse and suicidality.^295^ With respect to the durability of these effects after CBT ends, there is less clarity. A 2011 meta-analysis finds that the effects on symptoms were greater at followup that at the end of treatment, but only with comparisons to a diverse group of comparators, and with no specified duration of followup. Their findings for CBT compared with usual care are not statistically significant, so are similar to ours.^311^ Results related to durability of treatment from individual trials with longer post-treatment followup have been mixed. One trial^312^ of 9 months of CBT versus befriending found sustained benefit on overall and negative symptoms at 5-year followup with CBT, while a second trial^313^ of 6 months of intensive CBT versus leisure activities found no difference between groups in negative symptoms after 5 years. Both studies had methodological limitations which makes generalizable interpretation of these results difficult.

As with a previous meta-analysis,^309^ the studies we included rarely targeted negative symptoms. Our findings regarding negative symptoms, based on two good-quality systematic reviews,^77,79^ are somewhat in contrast with a 2008 review by Wykes et al. that found CBT resulted in significant improvements in negative symptoms.^309^ The Velthorst 2015 review found study year to be correlated with effect size, in that studies published prior to 2003 reported larger and more positive effect sizes than studies published in 2004 and later. Although based on limited evidence, this may partially explain the disparity in negative symptom pooled effect sizes between the two more recent reviews and the older review. All three reviews found higher study quality to be associated with lower effect sizes, and when limited to high quality studies (based on established risk of bias measures), they were in accord in finding a nonsignificant effect on negative symptoms in favor of CBT.

Evidence assessing how individual versus group CBT effects outcomes was limited. One review^79^ found individual CBT more effective than group CBT on negative symptom reduction, but Wykes^309^ reported no difference in effectiveness between individual and group CBT directed at symptoms as the primary outcome. The reason for this disparity may be due to the focus of the CBT. The Velthorst review noted that of 30 included trials, only two had negative symptoms as the primary treatment target, whereas the Wykes review assessed the effect of individual and group CBT only on studies’ primary treatment target.

### Cognitive Remediation

The direct focus of cognitive remediation is on improving cognitive functioning, an outcome that is outside the scope of our review. There is some evidence that improvements in cognition can lead to improved global functioning,^85^ and outcomes related to function and symptoms were commonly reported in trials of cognitive remediation. Our review found that cognitive remediation improved functional outcomes, overall symptoms and negative symptoms. Our findings on function and total symptoms are based on the 2011 Wykes review^84^ that combined both passive and active control groups. This review was an update and expansion of an older review, which also found cognitive remediation had a positive effect on function and symptoms.^314^ Our findings on negative symptoms are based on the Cella review^85^ and limited to studies with a passive usual care control group. These findings differ from the conclusions of the 2009 PORT publication, which determined that the evidence base was inadequate to make recommendations, primarily due to a paucity of good-quality RCTs. Our findings are based on more than 39 trials included in two good-quality systematic reviews.^295^

### Family Interventions

Previous systematic reviews^315^ and other reviews^316^ and the 2009 PORT publication.^295^ report findings similar to our review. The 2001 systematic review by Pitschel-Walz and colleagues found that both short- and long-term family interventions are superior to usual care in prevention of relapse.^315^ They also found that the effect remained regardless of the length of the followup period, but that the type of intervention (psychoeducation or therapeutic) made little difference in treatment effect, both better than usual care. These results are largely consistent with our findings. The Dixon update on family psychoeducation^316^ concludes that family psychoeducation should be included as part of best practice guidelines for schizophrenia. The 2009 PORT publication recommends that family interventions should last between 6 and 9 months to reduce rates of relapse and hospitalization.^317^ Similarly, we found the strongest evidence for interventions lasting seven to 12 months. In addition, we found that the number of sessions was more predictive of reduction in relapse than duration of treatment. The two studies with family interventions consisting of 10 or fewer sessions at 7 to 12 months were not different from usual care on risk of relapse. Pooled estimates for relapse in trials of 11 to 20 sessions, 21 to 50 sessions, and greater than 50 sessions were all statistically superior to treatment as usual. One difference between our review and others is that we excluded trials conducted in China as we are not confident that the findings from Chinese studies are applicable to a United States population. Two reviews have conducted sensitivity analyses removing Chinese studies and found pooled effect estimates were reduced when Chinese studies were excluded.^91,318^

### Social Skills Training

Our inclusion criteria were considerably stricter than those of other recent reviews^293,294^ in that we limited to larger trials (N>50), with longer duration (>12 weeks) that utilized a usual care control group. Still, our findings for function, one of the primary targets of social skills training, were consistent with other reviews that found significant improvements in measures of function with social skills training.^293,294,319^ Our findings for relapse, another target of social skills training, were also consistent with other reviews^293,319^ that found social skills training reduced relapse, although our estimates did not reach statistical significance, likely due to the low number of events and because the analysis in the other reviews included rehospitalizations as a surrogate for relapse. Our review also found social skills training significantly reduced negative symptoms, a finding that is consistent with one of these other reviews.^293^ The addition of new trials provided information on additional outcomes or durations of followup, but did not change the prior findings. In 2009, the PORT publication reported that evidence for skills training supported benefits in community functioning, but that the studies were not adequate to show positive effects on symptoms or relapse.^295^ Our findings are consistent with these findings.

### Supported Employment

Our findings on supported employment are consistent with other reviews, such as the 2009 PORT recommendations and a review by Marshall, et al.^295,320^ We found that supported employment, specifically the IPS model intervention, resulted in significantly better employment outcomes over 2 years compared with usual care. More patients gained either employment (competitive or any job), had worked more hours, were employed longer, and earned more money than those receiving usual care. Because we found only one RCT that met our criteria for this review, we included other evidence; a review and a study that included other comparison groups.^106,108^ In using this evidence, our findings are similar to PORT and Marshall, with the exception that our SOE rating is moderate, while the Marshall rating is high. Our lower SOE rating is due to our comparison group, i.e. usual care, where Marshall did not specify a comparison group. We note also that the good quality Cochrane review^106^ that we included in our evidence rated the evidence as very low quality (according to the Grading of Recommendations Assessment, Development and Evaluation [GRADE]^321–327^ criteria) for multiple reasons, including large amounts of missing data due to higher dropout rates in the control groups, skewed data for some outcomes, and concerns over the lack of blinding of outcome assessors.

## Applicability

### Key Question 1 Comparative Effectiveness of Pharmacological Treatments

The applicability of the evidence in this review is limited in part by the scope of the criteria we set (e.g., adults, outpatients, etc.), and the studies themselves. As a result the evidence in our report is applicable to the following:

- Populations: Adults; mean age 25 to 50 years with mainly moderate and moderate to severe disease. There is heterogeneity in the relative predominance of specific symptoms of patients enrolled. For comparisons of SGAs, there is fairly robust evidence on first-episode patients, but less on treatment-resistant patients.
  ○ The evidence is not clearly applicable to adolescents, older adults, patients with severe disease, or patients with multiple comorbidities.
- Interventions/Comparisons: For the SGAs versus each other, the majority of the evidence is relevant to comparisons of the older SGAs, with very little evidence regarding newer drugs (those approved in the last 10 years). For the FGAs versus the SGAs, the evidence is almost entirely applicable to comparisons of the older SGAs and haloperidol, with a wide range of dosing.
  ○ The evidence is less applicable to the newest SGAs (i.e., brexpiprazole, cariprazine, iloperidone, lurasidone, and the newest LAIs of paliperidone and aripiprazole).
  ○ Evidence on clozapine may be less generalizable due to the potential effects of the required monitoring, which in essence insures adherence to treatment and may provide nonspecific support, encouragement, and even structure to the daily or weekly schedule, through consistent interaction with a provider.
- Outcomes: The evidence is less applicable to long-term effectiveness outcomes, such as function, long-term quality of life, self-harm, and mortality, particularly for the comparison of FGAs versus SGAs and newer SGAs.
- Timing: For all of the drug interventions, more studies were short-term (6 to 12 weeks) than longer-term (1 to 2 years). The evidence is not applicable to long-term followup (greater than 3 years).
- Setting: For SGAs versus each other, the evidence only applies to outpatients, whereas in the systematic review we included on FGAs versus SGAs almost half of the studies were in inpatients.

### Key Question 2 Psychosocial and Other Nonpharmacological Interventions Versus Usual Care

Similar to the issues noted in Key Question 1, the evidence base is limited in part by the scope identified for this review. For example, for Key Question 2 we added criteria that studies had to have at least 50 percent of patients diagnosed with schizophrenia, to reflect the fact that many of these interventions are aimed at patients with serious mental illness, as a group, rather than at specific diagnoses. We also applied sample size, duration, country, and comparison group (usual care) limits. As a result the evidence in our report is applicable to the following:

- Populations: Adults; age range 16 to 80 (teens to older adults), mostly with a diagnosis of schizophrenia or related disorder. The specific characteristics of patients varied somewhat by intervention category, for example:
  ○ Evidence on supportive therapy is most applicable to middle aged men with schizophrenia and related diseases, who were experiencing long-standing hallucinations and/or delusions.
  ○ Evidence on assertive community treatment is most applicable to patients with a history of severe mental illness and frequent hospitalizations over the past 2 to 5 years (e.g., 2 to 5 instances).
  ○ The evidence is not clearly applicable to patients with treatment resistance, or multiple comorbidities. Across the interventions, the severity of the disease of the patients included in the studies is unclear.
- Interventions/Comparisons: The evidence in this review, by prespecified design, applies to comparisons with usual care, and the 13 intervention categories identified here. The purpose was not to evaluate head-to-head comparisons of active interventions to each other.
  ○ Interventions were poorly defined or described for some intervention categories, such as family interventions and supportive therapy, seriously limiting the generalizability.
  ○ Similarly, what was considered usual care and what specific interventions or services patients received as part of usual care was infrequently described. As a result, the evidence is less applicable to variations in level or quality of these interventions, or emerging interventions.
  ○ The evidence is not applicable to comparative effectiveness questions and the review findings apply only to comparisons with usual care. The evidence may apply to other comparisons, as our analysis of evidence for supported employment indicated little difference in findings or conclusions between usual care and active control-group evidence.
- Outcomes: The evidence is applicable only to a select group of outcomes that vary by intervention. Not all prioritized outcomes were reported consistently across studies.
- Timing: Most of the interventions do not have evidence that is applicable to long-term followup (greater than 3 years).
- Setting: The settings were mostly applicable to the United States, as evidence clearly not applicable was excluded from our review.
- Although applicability is separate from the strength of the evidence, the overall SOE does impact why applicability of the included studies may be limited. Importantly, the heterogeneity of interventions and treatment effects, including both clinical and methodological heterogeneity, detracts from the overall applicability of the findings.

## Implications for Clinical and Policy Decisionmaking

Our findings have implications for clinical and policy decisionmaking. The American Psychiatric Association’s (APA’s) most recent guideline for treating adults with schizophrenia was published in 2004,^328^ with a focused update in 2009.^329^ Also from 2009, are the Schizophrenia PORT recommendations for psychosocial treatments for individuals with schizophrenia.^295^ Since these publications, important developments have occurred both in the pharmacological and nonpharmacological treatment interventions for schizophrenia. There are five new antipsychotics and five new LAI formulations approved in the United States since the 2009 APA guideline update. Similarly, many psychosocial and other nonpharmacological treatments have been developed, refined or expanded in recent years.^295,329,330^ Given the ever-evolving nature of schizophrenia treatments and their potential for meaningful benefits and significant harms, this review will allow the APA to update their guideline, and for clinicians and patients to have a single source to access up-to-date evidence synthesis. Similarly, the review may allow policymakers to use the evidence in making decisions, depending on their priorities.

## Limitations of the Systematic Review Process

As with other types of research, the limitations of this systematic review are important to recognize. The generalizability of the results is limited by the scope of the review, based on the inclusion criteria, which determines the studies included and the specific methodology we applied to the review process. In terms of the review process, potential limitations are that we limited inclusion to studies with at least an abstract published in English (i.e., publications not available in an English form were not included) and had limitations on the number of databases we searched (Ovid MEDLINE^®^, the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and PsycINFO^®^). As we were limiting the study characteristics to those relevant to a United States setting, and because we reviewed English-language abstracts of studies whose full publication was in another language, we feel that the risk of this limitation is low. We have found that searching these key databases has been adequate, and in this case we also have the advantage of using systematic reviews in our review that had access to other sources to search for literature, and also depend on the scientific information packet (SIP) process and involvement of our Technical Expert Panel (TEP) to help identify any missing literature.

With respect to the limitations of the scope identified a priori for this review, there are several potential limitations. For pharmacologic interventions, the scope of this review is on direct, head-to-head comparisons of the drugs and did not evaluate comparisons to placebo, no treatment or older antipsychotic drugs. This may have introduced some biases or gaps in the conclusions particularly for newer drugs that have minimal or no comparative evidence.

For psychosocial interventions, due to the large volume and heterogeneous nature of studies, we made inclusion decisions to narrow the scope to the most commonly used interventions and to the most common control (usual care). These scope restrictions were made based on the evidence available and consultation with experts and were intended to allow us to review the most pertinent evidence as in-depth as possible, within the given time frame and budget. Clearly they could have impacted some of the findings and conclusions. We excluded, for example, assisted outpatient treatment (also known as outpatient commitment therapy and compulsory community treatment orders), because our clinical expert advisors felt these were mechanisms to get patients into treatment, rather than a treatment themselves. There is a review of these and other interventions aimed at reducing hospitalization in patients with serious mental illness.^331^

For both key questions, we limited our review to RCTs with a followup of at least 12 weeks, and for Key Question 2 we also required a patient population of at least 50 participants. For Key Question 2 on psychosocial interventions, these criteria resulted in excluding 35 trials (Figure 3). Limiting to usual care controls resulted in excluding 74 studies (compared with 271 studies included with usual care controls). These were primarily comparisons to other competing interventions (i.e. head to head comparisons) and comparisons of different intensities of the same intervention. In reviewing our findings in comparison with findings of reviews including active comparators, however, we did not find strong differences in direction or magnitude of effect. For example, our own findings on supported employment were consistent between usual care and the active comparator of pre-vocational training.

We limited the outcomes to those that are patient centered health outcomes (rather than intermediate outcomes), which were arranged according to their priority from the perspective of the patient, their family, and their clinicians. We considered advice from our experts in selecting and prioritizing this list of outcomes, and as a result outcomes such as positive symptoms, rehospitalization and cognitive outcomes were generally not included in our review. For Key Question 2, we ultimately excluded 96 studies because no included outcome was reported. Rehospitalization was excluded because there is important variation in the indications for and length of psychiatric hospitalizations across time, in different localities, and with different financial contexts, and there is important variation across trials in how rehospitalization is measured/evaluated, which may confound study interpretation. However, it should be noted that other outcomes may also suffer from similar issues. For example, employment may be influenced by local economic conditions, and outcomes related to interactions with law enforcement can also vary over time and by location. Most of the psychosocial interventions have target patient-outcome pairs, for example family interventions were targeted at patients with a history of, or at high risk of, frequent relapses. These targeted outcomes were generally included in our list of included outcomes, but were not prioritized on an intervention-by-intervention basis. In the example of family interventions, the target outcome of relapse prevention is outcome number seven in priority order. Certainly some highly prioritized, and patient-important, outcomes such as function and quality of life (outcomes number one and two in priority order) were not the target of most interventions and may not be greatly improved by these interventions. However, across the interventions, it is important to consider the evidence for both of these highly prioritized outcomes, as well as the targeted outcomes.

A final potential limitation is that we considered any intervention for schizophrenia without explicit consideration of the patient characteristics that the intervention focuses on. Because several interventions have a specific population and outcome focus, this may have limited our ability to determine for whom each intervention is best.

## Limitations of the Evidence Base

For the pharmacological interventions, the limitations of the evidence base are fairly clear; there are few studies of the newer SGAs, few studies reporting the most important outcomes (i.e., function and quality of life), inadequate information on key subgroups such as older patients and those with multiple or serious comorbidities, and patients with severe illness, including treatment-resistance, clearly separated out. Study quality was not a key limitation, but funding source may have been, given that over 80 percent of studies were funded by the manufacturer of one of the drugs in the trial.

Other issues making it more difficult to draw firm conclusions were the variability in which drugs compared across studies, outcomes reported and how they are measured, and of course, variability in patient characteristics, that are often poorly reported on. Consensus is needed regarding outcomes and measures used to assess outcomes; for example the primary outcome measure in the CATIE trials, which was well publicized as to how and why it was selected, was not given high priority by our TEP. Although many of the older studies suffered from problems with generalizability to the real-life practice setting because either they used doses that were higher or lower than those used in practice today or made unfair dose-comparisons (e.g., low dose of one drug versus high dose of a comparator drug); our analysis of these issues as part of our network analyses indicates that more recent studies have fewer issues with dosing. In the drug comparisons, an important limitation is the change in dosing over time, particularly with lower doses in more recent studies for several older drugs, and the prior treatment experience of patients enrolled (fewer patients with prior FGA exposure or resistance in more recent studies). The systematic review we included on this comparison attempted multiple sensitivity analyses to explore these issues, but no clear conclusions were drawn.

Although we excluded individual RCTs that enrolled inpatient populations, we included systematic reviews that included some studies conducted in inpatients. A few reviews conducted sensitivity analysis and found similar results regardless of setting.

Limitations for studies of psychosocial and nonpharmacological interventions included problems with reporting definitions of interventions and usual care groups, poor description of treatment versus followup periods, and variability in outcome reporting and methodological issues relating to small sample sizes, lack of power calculations, blinding of outcome assessors, post-treatment followup, and inadequate handling of missing data.

Many interventions were not clearly defined or described in the manuscripts and therefore difficult to categorize. In many studies the exact period of the intervention was unclear. Some reported a specific number of sessions but not the duration in weeks or months, while reporting outcomes at a specific time (e.g., 6 months). This was apparent in the CBT and family intervention studies, for example. There was also considerable variation in which how outcomes are reported, even when the same outcome measure was used. This was particularly true for symptom, functional and other outcomes measured using continuous scale scores. In many studies, there were small but significant improvements in scale scores with use of psychosocial interventions, but the clinical importance of these changes is largely unclear. This is an important limitation and is also related to the previous point about method of outcome reporting and to the small sample sizes in the majority of studies. For example, for those scales with known thresholds for clinical significance, we could not adequately assess if the threshold for clinical significance has been met if a study only reported effect size. For this review, the outcome of treatment discontinuation was included as a high priority outcome, but it was difficult to operationalize, and unclear what the meaning was for some interventions. In terms of study participant dropout, while only about a quarter of studies had rates higher than 30 percent, approximately 40 percent either did not conduct, or were unclear on conducting, an intention to treat analysis.

Few studies of psychosocial interventions reported on the effects of treatment after treatment cessation, while none of the included studies of antipsychotic drugs did so. For those studies that did report posttreatment followup, there tended to be a loss of effect after treatment withdrawal, but this evidence is insufficient to draw conclusions. Evidence to inform the best duration or schedule of treatment is not available for either category of intervention. For many intervention–outcome pairs, evidence was too limited to draw conclusions about the effect of treatment, resulting in insufficient SOE (Appendix H). For both key questions, evidence on subgroups is limited by sample sizes and that most are post hoc subgroup analyses of trials rather than either preplanned analyses or trials designed to address these questions as the primary objective.

## Research Recommendations

Based on the gaps and limitations identified in this review, we recommend the following future research on comparative effectiveness of pharmacological interventions and general effectiveness of psychosocial and other nonpharmacological interventions. In general, these recommendations are for RCTs.

### Pharmacological Interventions Versus Each Other

Trials should:

- Involve multiple newer SGA drugs (approved in the last 10 years), in comparison with one of the older SGAs (e.g., clozapine, olanzapine, risperidone LAI) and haloperidol and compare fluphenazine and perphenazine with both older and newer SGAs.
- Ensure comparable dosing with the best dosing titration methods for all drugs included.
- Measure key health outcomes, using agreed-upon direct measures. For example, measuring functional outcomes using not only valid and reliable scales, but also direct, objective measures of patient functioning. These measures need to be agreed upon by clinical and research experts and then used consistently across trials.
- Study durations must reflect real-life practice. Minimum study duration should be 1 year, with 3- to 5-year followup in order to measure the durability of effects, and truly long-term outcomes, including harms (e.g., metabolic changes and tardive dyskinesia). Long-term harms are not assessable in short-term studies, and relying on observational evidence has limitations.
- The concept of recovery should be incorporated into study designs, with testing of duration of effect and discontinuation of drug treatment following remission.
- Enroll subjects who reflect real populations. Studies exclusively of older patients, with multiple comorbidities and concomitant medications, and patients with severe disease, including treatment-resistance are needed. To better study other subgroups, such as minorities and women, specification and planning of subgroup analyses a priori and use of randomization methods that insure adequate distribution of these characteristics are needed to examine differences.
- Clearly inpatients need to be studied separately from outpatients, but future reviews should evaluate treatments for inpatients.

### Psychosocial and Other Nonpharmacological Interventions Versus Usual Care

Issues may vary by the specific intervention, but there are several key recommendations that are relevant to all of the interventions:

- Trials should have adequate sample sizes to address important health outcomes, rather than intermediate or surrogate outcomes, and should adhere to the current standards for reporting, such as the Consolidated Standards of Reporting Trials (CONSORT) criteria.^332^
- Studies need to be conducted in broader, but better-defined populations, with either separate studies of subpopulations or large enough sample sizes to allow meaningful subgroup analysis.
  ○ Future studies might consider using the National Institutes of Mental Health Research Domain Criteria approach to categorizing patients.
  ○ Future reviews should evaluate treatments for inpatients.
- Interventions should be clearly defined and described, including required components. Some interventions, such as cognitive remediation, have used expert groups to refine definitions and required components of interventions. Measurements of fidelity to the intervention model should be undertaken where possible.
- Trials need to evaluate and report patient-important health outcomes such as function, quality of life, self-harm, and adverse effects using standardized and easily interpretable methods. Studies should identify what constitutes clinically meaningful change in scale scores.
- Studies are needed to address the heterogeneity in usual care control groups. Usual care is highly variable, so studies using a usual care control group must report on the specific services and treatments received, and standardize the comparison or control for attention effects.
- Studies should measure both the intensity and duration of the intervention required to achieve the best results.
- Additional, well-designed long-term studies are needed. The long-term benefits versus risks and costs of treatments remain unclear, in particular for individuals whose illness is resistant or only partially responsive to treatment.
- Future systematic review research should:
  ○ Include other nonpharmacological treatments, such as device-based somatic treatments (e.g., electroconvulsive therapy and transcranial magnetic stimulation).
  ○ Include an evaluation of comparative effectiveness of psychosocial interventions compared with each other.
  ○ Incorporate the concepts of complex interventions into the methods for reviewing the evidence for some of the psychosocial interventions.^333,334^
  ○ Organize the evidence according to the patient characteristics that the intervention focuses on.