# Conclusions

The majority of the comparative evidence on pharmacotherapy to treat schizophrenia relates to the older SGAs (mainly clozapine, olanzapine, risperidone, quetiapine, and ziprasidone), with some evidence on paliperidone and aripiprazole, and the LAIs of risperidone, aripiprazole, and paliperidone. There is very little comparative evidence on newer SGAs (drugs approved in the last 10 years; asenapine, brexpiprazole, cariprazine, iloperidone, and lurasidone). Although there are some differences among the older SGA on specific outcomes, no single drug was superior on multiple high-priority outcomes. However, clozapine, olanzapine, and risperidone oral and LAI, did have superiority on more outcomes than other SGAs and quetiapine and ziprasidone were not superior to other SGAs on any outcome. No evidence found a newer SGA superior to older SGAs on any outcome. Evidence on FGAs versus SGAs indicates that olanzapine, risperidone, ziprasidone, and aripiprazole were similar to haloperidol on some outcomes of benefit, and were superior on overall adverse events and withdrawal due to adverse events.

In comparison with usual care, most of the psychosocial interventions to treat schizophrenia reviewed were more effective in improving two or more outcomes, including nontargeted but patient-important outcomes. Various functional outcomes were improved more with assertive community treatment, CBT, psychoeducation, social skills training, supported employment, and early team-based multi-component treatment programs for first episode psychosis than with usual care. Quality of life was improved more with CBT and early team-based multi-component treatment programs for first episode psychosis than usual care. Core illness symptoms were improved with assertive community treatment, CBT, cognitive remediation, illness self-management, psychoeducation, social skills training, and early team-based multi-component treatment programs for first episode psychosis. Relapse was reduced with psychoeducation, illness self-management, family interventions, and early team-based multi-component treatment programs for first episode psychosis. Self harm, response and/or remission, and adverse events were rarely reported.