# Appendix I Strength of Evidence—Drug Comparisons

Appendix Table I-1 Summary of findings for aripiprazole LAI-1 versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Aripiprazole LAI-1 | Aripiprazole | – | No difference^*^ | No difference^*^ | – | – | – | No difference^*^ | No difference^*^
Aripiprazole LAI-1 | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Aripiprazole LAI-1 | Asenapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Brexpiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Cariprazine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Clozapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Iloperidone | – | – | – | – | – | – | – | Moderate (2)^*^
Aripiprazole LAI-1 | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Olanzapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Paliperidone | – | – | No difference^*^ | – | – | – | Insufficient | No difference^*^
Aripiprazole LAI-1 | Paliperidone LAI-1 | – | Insufficient | – | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Quetiapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Risperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Risperidone LAI | – | – | – | – | – | – | – | No difference^*^
Aripiprazole LAI-1 | Ziprasidone | – | – | No difference^*^ | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-2 Summary of findings for aripiprazole LAI 4–6w versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Aripiprazole LAI-6w | Aripiprazole | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Aripiprazole LAI-1 | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Asenapine | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Brexpiprazole | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Cariprazine | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Clozapine | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Iloperidone | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Lurasidone | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Olanzapine | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Olanzapine LAI | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Paliperidone | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Paliperidone LAI-1 | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Paliperidone LAI-3 | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Quetiapine | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Quetiapine ER | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Risperidone | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Risperidone LAI | – | – | – | – | – | – | – | –
Aripiprazole LAI-6w | Ziprasidone | – | – | – | – | – | – | – | –

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-3 Summary of findings for aripiprazole versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Aripiprazole | Aripiprazole LAI-1 | – | No difference^*^ | No difference^*^ | – | – | – | No difference^*^ | No difference^*^
Aripiprazole | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Aripiprazole | Asenapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole | Brexpiprazole | – | – | No difference^*^ | Insufficient | – | Insufficient | Insufficient | No difference^*^
Aripiprazole | Cariprazine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole | Clozapine | – | – | No difference^*^ | – | Insufficient | – | – | No difference^*^
Aripiprazole | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Aripiprazole | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Aripiprazole | Olanzapine | – | – | No difference^*^ | – | Insufficient | – | – | No difference^*^
Aripiprazole | Olanzapine LAI | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole | Paliperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole | Paliperidone LAI-1 | – | Insufficient | – | – | – | – | – | No difference^*^
Aripiprazole | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Aripiprazole | Quetiapine | – | – | No difference^*^ | – | Insufficient | – | – | No difference^*^
Aripiprazole | Quetiapine ER | – | – | No difference^*^ | – | – | – | – | No difference^*^
Aripiprazole | Risperidone | – | – | No difference^*^ | – | Insufficient | – | No difference^*^ | No difference^*^
Aripiprazole | Risperidone LAI | – | – | – | – | Insufficient | – | – | No difference^*^
Aripiprazole | Ziprasidone | – | – | No difference^*^ | – | Insufficient | – | – | Medium^*^ (1)
| | | | | | | Possibly data out there

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-4 Summary of findings for asenapine versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Asenapine | Aripiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Asenapine | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | – | No difference^*^
Asenapine | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Asenapine | Brexpiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Asenapine | Cariprazine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Asenapine | Clozapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Asenapine | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Asenapine | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Asenapine | Olanzapine | – | – | No difference^*^ | No difference^*^ | Insufficient | – | No difference^**^ | No difference^*^
Asenapine | Olanzapine LAI | – | – | – | – | – | – | – | –
Asenapine | Paliperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Asenapine | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Asenapine | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Asenapine | Quetiapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Asenapine | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Asenapine | Risperidone | – | – | No difference^*^ | – | – | – | Insufficient | No difference^*^
Asenapine | Risperidone LAI | – | – | – | – | – | – | – | No difference^*^
Asenapine | Ziprasidone | – | – | No difference^*^ | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-5 Summary of findings for brexpiprazole versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Brexpiprazole | Aripiprazole | – | – | No difference^*^ | Insufficient | – | Insufficient | Insufficient | No difference^*^
Brexpiprazole | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Brexpiprazole | Asenapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Cariprazine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Clozapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Brexpiprazole | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Brexpiprazole | Olanzapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Brexpiprazole | Paliperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Brexpiprazole | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Brexpiprazole | Quetiapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Brexpiprazole | Risperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Brexpiprazole | Risperidone LAI | – | – | – | – | – | – | – | No difference^*^
Brexpiprazole | Ziprasidone | – | – | No difference^*^ | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-6 Summary of findings for cariprazine versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Cariprazine | Aripiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Cariprazine | Asenapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Brexpiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Clozapine | – | – | No difference^*^ | – | – | – | – | Moderate (2)^*^
Cariprazine | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Cariprazine | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Cariprazine | Olanzapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Cariprazine | Paliperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Cariprazine | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Cariprazine | Quetiapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Cariprazine | Risperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Cariprazine | Risperidone LAI | – | – | – | – | – | – | Insufficient | No difference^*^
Cariprazine | Ziprasidone | – | – | No difference^*^ | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-7 Summary of findings for clozapine versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Clozapine | Aripiprazole | – | – | No difference^*^ | – | – | Small (1)^*^ | No difference^*^ | Moderate (2)^*^
Clozapine | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Aripiprazole LAI-6w | – | – | – | – | – | Small (1)^*^ | – | –
Clozapine | Asenapine | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Brexpiprazole | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Cariprazine | – | – | No difference^*^ | – | – | Small (1)^*^ | – | Moderate (2)^*^
Clozapine | Iloperidone | – | – | – | – | – | Small (1)^*^ | Insufficient | Large (2)^*^
Clozapine | Lurasidone | – | – | – | – | – | Small (1)^*^ | Insufficient | No difference^*^
Clozapine | Olanzapine | Insufficient | – | No difference^*^ | Insufficient | Small (1)^*^ | No difference^*^ | – | Moderate (2)^*^
Clozapine | Olanzapine LAI | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Paliperidone | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Paliperidone LAI-1 | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Paliperidone LAI-3 | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Quetiapine | – | – | No difference^*^ | Insufficient | Insufficient | Small (1)^*^ | Insufficient | No difference^*^
Clozapine | Quetiapine ER | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Clozapine | Risperidone | No difference^*^ | – | No difference^*^ | Insufficient | Insufficient | Small (1)^*^ | No difference^*^ | No difference^*^
Clozapine | Risperidone LAI | – | – | – | – | – | Small (1)^*^ | – | Large (2)^*^
Clozapine | Ziprasidone | – | – | No difference^*^ | – | – | Small (1)^*^ | Insufficient | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-8 Summary of findings for iloperidone versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Iloperidone | Aripiprazole | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Aripiprazole LAI-1 | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Iloperidone | Asenapine | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Brexpiprazole | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Cariprazine | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Clozapine | – | – | – | – | – | – | Insufficient | Moderate (1)^*^
Iloperidone | Lurasidone | – | – | – | – | – | – | Insufficient | No difference^*^
Iloperidone | Olanzapine | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Paliperidone | – | – | – | – | – | Small (2)^*^ | – | No difference^*^
Iloperidone | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Quetiapine | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Risperidone | – | – | – | – | – | – | Insufficient | No difference^*^
Iloperidone | Risperidone LAI | – | – | – | – | – | – | – | No difference^*^
Iloperidone | Ziprasidone | – | – | – | – | – | – | Insufficient | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-9 Summary of findings for lurasidone versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Lurasidone | Aripiprazole | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Aripiprazole LAI-1 | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Lurasidone | Asenapine | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Brexpiprazole | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Cariprazine | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Clozapine | – | – | – | – | – | – | Insufficient | No difference^*^
Lurasidone | Iloperidone | – | – | – | – | – | – | Insufficient | No difference^*^
Lurasidone | Olanzapine | – | – | – | – | – | – | Insufficient | Moderate (2)^*^
Lurasidone | Olanzapine LAI | – | – | – | – | – | – | Insufficient | No difference^*^
Lurasidone | Paliperidone | – | – | – | – | – | – | – | Small (2)^*^
Lurasidone | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Paliperidone LAI-3 | – | – | – | _ | _ | Moderate (2)^*^ | – | No difference^*^
Lurasidone | Quetiapine | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Lurasidone | Risperidone | – | – | – | – | – | – | Insufficient | No difference^*^
Lurasidone | Risperidone LAI | – | – | – | – | – | – | – | Moderate (2)^*^
Lurasidone | Ziprasidone | – | – | – | – | – | – | Insufficient | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-10 Summary of findings for olanzapine LAI versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Olanzapine LAI | Aripiprazole | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Aripiprazole LAI-1 | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Olanzapine LAI | Asenapine | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Brexpiprazole | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Cariprazine | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Clozapine | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Lurasidone | – | – | – | – | – | – | Insufficient | No difference^*^
Olanzapine LAI | Olanzapine | – | – | – | – | – | – | Insufficient | No difference^*^
Olanzapine LAI | Paliperidone | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Quetiapine | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Risperidone | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Risperidone LAI | – | – | – | – | – | – | – | No difference^*^
Olanzapine LAI | Ziprasidone | – | – | – | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-11 Summary of findings for olanzapine versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Olanzapine | Aripiprazole | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Olanzapine | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | – | No difference^*^
Olanzapine | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Olanzapine | Asenapine | – | – | No difference^*^ | No difference^*^ | Insufficient | Small (1)^*^ | No difference^**^ | No difference^*^
Olanzapine | Brexpiprazole | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Olanzapine | Cariprazine | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Olanzapine | Clozapine | No difference^*^ | No difference^*^ | No difference^*^ | – | Small (2)^*^ | No difference^*^ | – | Moderate (1)^*^
Olanzapine | Iloperidone | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Olanzapine | Lurasidone | – | – | – | – | – | Small (1)^*^ | Insufficient | Moderate (1)^*^
Olanzapine | Olanzapine LAI | – | – | – | – | – | – | Insufficient | No difference^*^
Olanzapine | Paliperidone | Insufficient | – | No difference^*^ | – | – | No difference^*^ | No difference^*^ | No difference^*^
Olanzapine | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Olanzapine | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Olanzapine | Quetiapine | No difference^*^ | No difference^**^ | Moderate (1)^*^ | No difference^*^ | – | Small (1)^*^ | – | Moderate (1)^*^
Olanzapine | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Olanzapine | Risperidone | No difference^*^ | No difference^**^ | No difference^*^ | No difference^*^ | – | No difference^*^ | – | Moderate (1)^*^
Olanzapine | Risperidone LAI | – | No difference^*^ | – | – | – | – | – | No difference^*^
Olanzapine | Ziprasidone | – | No difference^**^ | No difference^*^ | – | – | Small (1)^*^ | – | Moderate (1)^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-12 Summary of findings for paliperidone LAI-1 versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Paliperidone LAI-1 | Aripiprazole | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Aripiprazole LAI-1 | – | Insufficient | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Paliperidone LAI-1 | Asenapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Brexpiprazole | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Cariprazine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Clozapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Olanzapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Paliperidone | – | – | – | Insufficient | – | – | – | No difference^*^
Paliperidone LAI-1 | Paliperidone LAI-3 | – | – | – | Insufficient | – | – | Insufficient | No difference^*^
Paliperidone LAI-1 | Quetiapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Risperidone | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-1 | Risperidone LAI | No difference^*^ | – | – | No difference^*^ | Insufficient | – | No difference^*^ | Moderate (2)^*^
Paliperidone LAI-1 | Ziprasidone | – | – | – | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-13 Summary of findings for paliperidone LAI-3 versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Paliperidone LAI-3 | Aripiprazole | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Aripiprazole LAI-1 | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Paliperidone LAI-3 | Asenapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Brexpiprazole | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Cariprazine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Clozapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Olanzapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Paliperidone | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Paliperidone LAI-1 | – | – | – | Insufficient | – | – | Insufficient | No difference^*^
Paliperidone LAI-3 | Quetiapine | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Risperidone | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Risperidone LAI | – | – | – | – | – | – | – | No difference^*^
Paliperidone LAI-3 | Ziprasidone | – | – | – | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-14 Summary of findings for paliperidone versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Paliperidone | Aripiprazole | – | – | No difference^*^ | – | – | – | Insufficient | No difference^*^
Paliperidone | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | Insufficient | No difference^*^
Paliperidone | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Paliperidone | Asenapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Paliperidone | Brexpiprazole | – | – | No difference^*^ | – | – | – | Insufficient | No difference^*^
Paliperidone | Cariprazine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Paliperidone | Clozapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Paliperidone | Iloperidone | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Paliperidone | Lurasidone | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Paliperidone | Olanzapine | Insufficient | – | No difference^*^ | – | – | No difference^*^ | No difference^*^ | No difference^*^
Paliperidone | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Paliperidone | Paliperidone LAI-1 | – | – | – | Insufficient | – | – | – | No difference^*^
Paliperidone | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Paliperidone | Quetiapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Paliperidone | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Paliperidone | Risperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Paliperidone | Risperidone LAI | – | – | – | – | – | – | Insufficient | No difference^*^
Paliperidone | Ziprasidone | – | – | No difference^*^ | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-15 Summary of findings for quetiapine ER versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Quetiapine ER | Aripiprazole | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Aripiprazole LAI-1 | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Aripiprazole LAI-6w | – | – | – | – | – | – | –
Quetiapine ER | Asenapine | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Brexpiprazole | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Cariprazine | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Clozapine | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Olanzapine | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Paliperidone | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Quetiapine | – | – | – | Insufficient | – | – | No difference^*^ | No difference^*^
Quetiapine ER | Risperidone | – | Insufficient | – | – | – | – | No difference^*^ | No difference^*^
Quetiapine ER | Risperidone LAI | – | – | – | – | – | – | – | No difference^*^
Quetiapine ER | Ziprasidone | – | – | – | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-16 Summary of findings for quetiapine versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Quetiapine | Aripiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Quetiapine | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | – | No difference^*^
Quetiapine | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Quetiapine | Asenapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Quetiapine | Brexpiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Quetiapine | Cariprazine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Quetiapine | Clozapine | – | No difference^*^ | No difference^*^ | – | – | – | Insufficient | No difference^*^
Quetiapine | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Quetiapine | Lurasidone | – | – | – | – | – | – | – | No difference^*^
Quetiapine | Olanzapine | No difference^*^ | No difference^*^ | Moderate (2)^*^ | – | – | – | – | Moderate (1)^*^
Quetiapine | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Quetiapine | Paliperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Quetiapine | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Quetiapine | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Quetiapine | Quetiapine ER | – | – | – | Insufficient | – | – | No difference^*^ | No difference^*^
Quetiapine | Risperidone | Insufficient | No difference^*^ | Moderate (2)^*^ | No difference^*^ | Insufficient | – | No difference^**^ | No difference^*^
Quetiapine | Risperidone LAI | Small (2)^*^ | No difference^*^ | – | – | – | – | Insufficient | Moderate (2)^*^
Quetiapine | Ziprasidone | – | No difference^*^ | No difference^*^ | – | – | – | – | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-17 Summary of findings for risperidone LAI versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Risperidone LAI | Aripiprazole | – | – | – | – | – | – | Insufficient | No difference^*^
Risperidone LAI | Aripiprazole LAI-1 | – | – | – | – | – | – | – | No difference^*^
Risperidone LAI | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Risperidone LAI | Asenapine | – | – | – | – | – | – | – | Moderate (1)^*^
Risperidone LAI | Brexpiprazole | – | – | – | – | – | – | – | No difference^*^
Risperidone LAI | Cariprazine | – | – | – | – | – | – | – | No difference^*^
Risperidone LAI | Clozapine | – | – | – | – | – | – | Insufficient | Large (1)^*^
Risperidone LAI | Iloperidone | – | – | – | – | – | – | – | No difference^*^
Risperidone LAI | Lurasidone | – | – | – | – | – | – | – | Moderate (1)^*^
Risperidone LAI | Olanzapine | – | – | – | – | – | – | – | No difference^*^
Risperidone LAI | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Risperidone LAI | Paliperidone | No difference^*^ | – | – | – | – | – | No difference^*^ | Moderate (1)^*^
Risperidone LAI | Paliperidone LAI-1 | No difference^*^ | – | – | No difference^*^ | – | – | No difference^*^ | Moderate (1)^*^
Risperidone LAI | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Risperidone LAI | Quetiapine | Small (1)^*^ | No difference^*^ | – | – | – | – | – | No difference^*^
Risperidone LAI | Quetiapine ER | – | – | – | – | – | – | – | Moderate (1)^*^
Risperidone LAI | Risperidone | – | – | – | – | – | – | Insufficient | Moderate (1)^*^
Risperidone LAI | Ziprasidone | – | – | – | – | – | – | – | Moderate (1)^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-18 Summary of findings for risperidone versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Risperidone | Aripiprazole | – | – | No difference^*^ | – | – | Small (1)^*^ | No difference^*^ | No difference^*^
Risperidone | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | – | No difference^*^
Risperidone | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Risperidone | Asenapine | – | – | No difference^*^ | No difference^*^ | – | Small (1)^*^ | Insufficient | No difference^*^
Risperidone | Brexpiprazole | – | – | No difference^*^ | – | – | Small (1)^*^ | – | No difference^*^
Risperidone | Cariprazine | – | – | No difference^*^ | – | – | – | Insufficient | No difference^*^
Risperidone | Clozapine | – | – | No difference^*^ | – | – | – | No difference^*^ | No difference^*^
Risperidone | Iloperidone | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Risperidone | Lurasidone | – | – | – | – | – | Small (1)^*^ | – | No difference^*^
Risperidone | Olanzapine | No difference^**^ | No difference^**^ | No difference^*^ | – | – | No difference^*^ | – | Small (2)^*^
Risperidone | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Risperidone | Paliperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Risperidone | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Risperidone | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Risperidone | Quetiapine | Insufficient | No difference^*^ | Moderate (1)^*^ | No difference^*^ | – | – | No difference^**^ | No difference^*^
Risperidone | Quetiapine ER | – | – | – | Insufficient | – | – | No difference^*^ | No difference^*^
Risperidone | Risperidone LAI | – | – | – | – | – | – | Insufficient | Moderate (2)^*^
Risperidone | Ziprasidone | – | No difference^*^ | No difference^*^ | – | – | – | Insufficient | No difference^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2

Appendix Table I-19 Summary of findings for ziprasidone versus other SGAs

Drug | Comparator | Function | QOL | Response | Mortality | Self-harm | Symptoms | Any AE | W/D AEs
Ziprasidone | Aripiprazole | – | – | No difference^*^ | – | – | – | – | Moderate (2)^*^
Ziprasidone | Aripiprazole LAI-1 | – | – | No difference^*^ | – | – | – | – | No difference^*^
Ziprasidone | Aripiprazole LAI-6w | – | – | – | – | – | – | – | –
Ziprasidone | Asenapine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Ziprasidone | Brexpiprazole | – | – | No difference^*^ | – | – | – | – | No difference^*^
Ziprasidone | Cariprazine | – | – | No difference^*^ | – | – | – | – | No difference^*^
Ziprasidone | Clozapine | – | No difference^*^ | No difference^*^ | – | – | – | Insufficient | No difference^*^
Ziprasidone | Iloperidone | – | – | – | – | – | – | Insufficient | No difference^*^
Ziprasidone | Lurasidone | – | – | – | – | – | – | Insufficient | No difference^*^
Ziprasidone | Olanzapine | Insufficient | No difference^**^ | No difference^*^ | – | – | – | – | Moderate (2)^*^
Ziprasidone | Olanzapine LAI | – | – | – | – | – | – | – | No difference^*^
Ziprasidone | Paliperidone | – | – | No difference^*^ | – | – | – | – | No difference^*^
Ziprasidone | Paliperidone LAI-1 | – | – | – | – | – | – | – | No difference^*^
Ziprasidone | Paliperidone LAI-3 | – | – | – | – | – | – | – | No difference^*^
Ziprasidone | Quetiapine | – | No difference^*^ | No difference^*^ | – | – | – | – | No difference^*^
Ziprasidone | Quetiapine ER | – | – | – | – | – | – | – | No difference^*^
Ziprasidone | Risperidone | – | No difference^*^ | No difference^*^ | – | – | – | Insufficient | No difference^*^
Ziprasidone | Risperidone LAI | – | – | – | – | – | – | – | Moderate (2)^*^

* = Low SOE, ** = Moderate SOE, *** = High SOE, – = No data, (1) = Estimate favors Drug 1, (2) = Estimate favors Drug 2