# Appendix H Strength of Evidence

Appendix Table H-1 Strength of evidence: second-generation antipsychotic versus second-generation antipsychotic

Outcome | Comparators | Number of Studies Number of Subjects | Study Limitations | Consistency | : Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Social Functioning | Olanzapine, risperidone, quetiapine immediate-release | 1 SR^1^ (2 RCTs; N =358;) (1 observational study; N = 9028) | Moderate Observational evidence: Moderate | Inconsistent Observational evidence: Unknown | Direct Observational evidence: Direct | Imprecise Observational evidence: Precise | Inconclusive: RCT 1: no significant differences on RFS or the SAS-SMI RCT 2: Change on SFS greater with App H olanzapine (+7.75) than risperidone (−0.92; P=0.0028) (Socially active: OR 1.27, 95% CI 1.05 to 1.54 olanzapine 84.6% vs. risperidone 82.4%). | Insufficient
Social Functioning | Paliperidone monthly LAI vs. risperidone q 2 wks LAI | 1 SR^1^ (2 RCTs; N = 452) | Moderate | Inconsistent | Direct | Precise | No statistically significant differences in PSP scale: mean change from baseline 16.8 paliperidone and 18.6 risperidone; (LSM difference 0.5, 95% CI −2.14 to 3.12) | Low
Social Functioning | Paliperidone extended release vs. olanzapine | 1 Meta-analysis of selected studies^2^ | High | Unknown | Direct | Precise | No significant difference in PSP scale (change 7.8 to 12.2 in paliperidone dose u vs. 8.7 in olanzapine group). | Insufficient
Social Functioning | Risperidone LAI vs. Quetiapine immediate release | 1 RCT^3^ (N = 666) | Moderate | Unknown | Direct | Precise | Risperidone LAI resulted in greater improvements in SOFA at 6 months (6.1 vs. 2.7; P = 0.02), 12 months (9.5 vs. 6.1; P = 0.009), and endpoint (6.6 vs. 1.1; P < 0.0001). | Low
Employment Outcomes | Older SGAs (olanzapine, risperidone, quetiapine, ziprasidone) | 1 SR^1^ (2 RCTs, 3 observational N = 1,379) | Low Observational evidence: Moderate | Inconsistent Observational evidence: Consistent | Direct Observational evidence: Direct | Imprecise Observational evidence: Imprecise | No significant differences in rates of employment (mean 18% in CATIE Phase I) | Low
Occupation and Residential Status | Older SGAs (olanzapine, risperidone, quetiapine, ziprasidone) | 1 SR^1^ (21 RCT, N = 771) | Moderate | Unknown | Direct | Imprecise | Inconclusive: 75.5% and 75.3% had stable status, 3.8% and 3.1% improved status (NS) | Insufficient
Global Functioning (GAF) | Olanzapine vs. Risperidone | 1 SR^1^ (4 cohort studies; N = 3211) | High | Inconsistent | Direct | Precise | No difference: Pooled WMD 0.61, 95% CI, −1.78 – 2.99; I^2^ = 43% | Low
Global Functioning (GAF) | Olanzapine vs. Quetiapine | 1 SR^1^ (2 RCTs; N = 363) | Moderate | Consistent | Direct | Imprecise | Pooled WMD 1.14, 95% CI −4.75 to 7.02; Q = 3.99, df = 1; P = 0.045 | Low
Quality of Life | Olanzapine vs. risperidone | 1 SR^1^ (2 RCTs; N = 492) | Moderate | Consistent | Direct | Precise | QLS Change = 12 months 0.19 v 0.26 (P = 0.53); 7 months 13.4 vs. 8.8 (P >0.074) | Moderate
Quality of Life | Olanzapine vs. ziprasidone | 1 SR^1^ (2 RCTs; N = 740) | Moderate | Consistent | Direct | Precise | QLS Change = 12 months 0.19 v 0.26 (P NR); 6–7 months Endpoint 61.3 vs. 58.9 (P = 0.36 using mixed-effect modeling) | Moderate
Quality of Life | Olanzapine vs. quetiapine immediate release | 1 SR^1^ (1 RCT; N = 227) | Low | Unknown | Direct | Imprecise | QLS Change = 12 months 0.19 v 0.09 (P >0.05) | Low
Quality of Life | Olanzapine vs. asenapine | 1 SR^1^ (1 RCT; N = 464) | Moderate | Unknown | Direct | Imprecise | QLS Change =12 months 11.7 vs. 11.8 and 11.1 vs. 7.1 (multi-country study reported by hemisphere) P = NS | Insufficient
Quality of Life | Olanzapine vs. clozapine | 1 SR^1^ (1 RCT; N = 114) | Moderate | Unknown | Direct | Imprecise | SWN: 26 weeks O found non-inferior to C (difference 3.2, 95% CI: 4.2 to 10.5) | Insufficient
Quality of Life | Risperidone vs. ziprasidone | 1 SR^1^ (N = 154) | Low | Unknown | Direct | Imprecise | QLS Change = 12 months 0.19 v 0.26 (P >0.05) | Low
Quality of Life | Risperidone vs. Quetiapine | 1 SR^1^ (1 RCT; N = 189) | Low | Unknown | Direct | Imprecise | QLS Change = 12 months 0.26 v 0.26 (P >0.05); | Low
Quality of Life | Quetiapine-ER vs. Risperidone | 1 RCT; N = 798^4^ | Moderate | Unknown | Direct | Imprecise | SWN 20% Response 12 months: 65% vs. 68%, adjusted difference (−5.7, 95% CI −15.1 to 3.7) but not meet non-inferiority criteria | Insufficient
Quality of Life | Aripiprazole oral vs. aripiprazole LAI (monthly) | 1 RCT; N = 724^5^ | Moderate | Unknown | Direct | Precise | SF-36 12 months: mental component scores (0.82 vs. 0.38; difference 0.44, 95% Cl −1.24 to 2.12) and physical component scores (0.23 vs. −0.27; difference 0.50, 95% Cl −1.11 to 2.11) | Low
Quality of Life | Aripiprazole LAI vs. paliperidone palmitate LAI (monthly) | 1 RCT; N = 295^6^ | Moderate | Unknown | Direct | Imprecise | QLS: 28 weeks change = 7.47 vs. 2.80 (least squares mean difference 4.67, 95% Cl 0.32 to 9.02). Meets non-inferiority criteria; not meet MCID | Insufficient
Quality of Life | Risperidone LAI vs. quetiapine | 1 RCT; N = 666^3^ | Moderate | Unknown | Direct | Precise | SF-12 physical and mental component scores and SQLS-R4 scores improved from baseline in both groups but were not significantly different at endpoint (24 months; SF-12 physical P= 0.09; SF-12 mental and SQLS-R4 P = NR). | Low
Response | | Network meta-analysis of olanzapine, risperidone, quetiapine IR, aripiprazole, clozapine, ziprasidone> asenapine, paliperidone, aripiprazole LAI monthly, carpipramine, brexpiprazole, lurasidone 46 RCTs (N = 12,536) | Moderate | Consistent | Indirect | Precise | There were 2 statistically significant differences between the drugs; both olanzapine (OR 1.71. 95% CI 1.11,2.68) and risperidone (OR 1.41, 95% CI 1.01,2.00) were significantly more likely to result in response than quetiapine IR. | Low
Mortality (All-Cause) | Olanzapine vs. risperidone vs. quetiapine | 1 SR^1^ (1 retrospective cohort study; N = 48, 595) | Low | Unknown | Direct | Precise | No difference in all-cause mortality between risperidone and olanzapine (HR 1.09, 95% Cl 0.79 to 1.49) or quetiapine (HR 0.75, 95% Cl 0.53 to 1.07). | Low
Mortality (All-Cause) | Clozapine, risperidone, olanzapine and quetiapine vs. no treatment | 1 SR^1^ (1retrospective cohort study; N = 6, 987) | Low | Unknown | Direct | Imprecise | Clozapine and quetiapine had significantly lower risk of all-cause mortality (adjusted ORs 0.35, 95% CI 0.21 to 0.58 and 0.46, 95% CI 0.30 to 0.72), risperidone and olanzapine not statistically significantly different from control | Insufficient
Mortality (All-Cause) | Asenapine vs. Olanzapine | 2 RCTs^7,8^ | Moderate | Consistent | Direct | Imprecise | Inconclusive: 0.41% vs. 0.42%, 0% vs. 0%, 0.77% vs. 0.32%; RR 2.49 (95% CI 0.54 to 11.5) | Low
Mortality (All-Cause) | Paliperidone palmitate LAI (monthly) vs. Risperidone LAI | 2 RCTs^9,10^ | Moderate | Consistent | Direct | Imprecise | Inconclusive: 0.79% vs. 0.27%, 0% vs. 0.45%; RR 1.26 (95% CI 0.21 to 7.49) | Low
Mortality (All-Cause) | Quetiapine vs. Risperidone | 2 RCTs^11,12^ | Moderate | Consistent | Direct | Imprecise | Inconclusive: 1.17% vs. 0.40% and 0.72% vs. 0%; RR 3.24 (95% CI 0.72 to 14.6) | Low
Cardiovascular Mortality | Olanzapine vs. risperidone vs. quetiapine | 1 SR^1^ (2 retrospective cohort study; N = 55,582) | Low | Consistent | Direct | Precise | No significant differences between the drugs (HRs 0.99, 95% Cl 0.37 to 2.67 and 0.76, 95% Cl 0.25 to 2.28, respectively). | Low
Cardiovascular Mortality | Clozapine vs. risperidone | 1 SR^1^ (2 retrospective cohort studies; N =1,686) | Moderate | Unknown | Direct | Imprecise | Inconclusive: No significant differences between drugs 4.8% and 2.5%; RR 1.39, 95% CI 0.61 to 2.53 | Insufficient
Self-Harm: Suicidal Behavior, Suicide | Clozapine versus olanzapine in high-risk patients | 1 SR^1^ (1 RCT; N = 980) | Low | Unknown | Direct | Imprecise | Suicidal behavior: HR 0.76, 95% CI 0.58 to 0.97; | Low
Self-Harm: Suicidal Behavior, Suicide | Clozapine vs. olanzapine in high-risk patients | 1 SR^1^ (1 RCT; N = 980) | Low | Unknown | Direct | Precise | Worsening on CGI-Suicide Severity: HR 0.78, 95% CI 0.61 to 0.99 | Moderate
Self-Harm: Suicidal Behavior, Suicide | Clozapine vs. olanzapine in high-risk patients | 1 SR^1^ (1 RCT; N = 980) | Low | Unknown | Direct | Imprecise | Suicide deaths: No significant differences ( 5 clozapine, 3 olanzapine) | Low
Self-Harm: Suicidal Behavior, Suicide | Clozapine, risperidone, olanzapine, quetiapine, ziprasidone, aripiprazole | 1 SR^1^ (2 retrospective cohorts; N = 16,584) | Moderate | Consistent | Direct | Precise | Death by suicide lower with clozapine: OR 0.29 (0.14 to 0.63) compared with no treatment at 6 months and clozapine (1.1%) lower than baseline (2.2%) or other drugs (range 2.1% to 3.7%) at 1 year. | Low
Self-Harm: Suicidal Behavior, Suicide | Clozapine, risperidone, olanzapine, quetiapine, ziprasidone, aripiprazole | 1 SR^1^ (1 prospective cohort; N = 10,204) | High | Unknown | Direct | Precise | Suicide attempts (6 months: No statistically significant difference between drugs | Insufficient
Self-Harm: Suicidal Behavior, Suicide | Clozapine, risperidone, olanzapine, quetiapine, ziprasidone, aripiprazole | 1 SR^1^ (1 prospective cohort; N = 20,489) | High | Unknown | Direct | Precise | Inconclusive: Suicide attempts or death by suicide: aripiprazole vs. others combined HR 0.69, 95% CI 0.42 to 1.14 | Insufficient
Core Illness Symptoms | Oral SGAs (except carpipramine) | (212 RCTs)^13^ | Moderate | Consistent | Indirect | Precise | Clozapine had significantly better improvement than the other drugs except olanzapine (SMDs on PANSS or BPRS −0.32 to −0.55. Olanzapine and risperidone superior to the other drugs, except for each other and paliperidone (SMDs −0.13 to −0.26). Paliperidone superior to lurasidone and iloperidone (SMD −0.17). All drugs superior to placebo (SMDs −0·33 to −0·88). | Low
Core Illness Symptoms | Treatment resistant patients: clozapine, risperidone, olanzapine, quetiapine, and ziprasidone | (40 RCTs)^14^ | Moderate | Consistent | Indirect | Precise | The only significant difference was that the mean change in the PANSS greater with olanzapine than quetiapine (SMD −0.29, 95% CI −0.56 to −0.13). | Low
Core Illness Symptoms | Brexpiprazole vs. aripiprazole | (N=97)^15^ | Moderate | Unknown | Indirect | Imprecise | Inconclusive: PANSS scale −22.9 vs. −19.4 from baseline; direct comparison not reported. | Insufficient
Overall/Any Adverse Events
Overall/Any Adverse Events | Asenapine vs. olanzapine | 5 RCTs (4 publications); N = 2189)^7,8,16,17^ | Moderate | Consistent | Direct | Precise | Pooled RR 1.00 (95% CI 0.96 – 1.05); I^2^ 9% | Moderate
Overall/Any Adverse Events | Quetiapine vs. risperidone | 7 RCTs (N = 3254)^11,12,18–22^ | Moderate | Consistent | Direct | Precise | Pooled 1.04 (95% CI 0.97 to 1.12); I^2^ 56% | Moderate
Overall/Any Adverse Events | Clozapine vs. olanzapine | 2 RCTs (N = 182)^6,20^ | Moderate | Consistent | Direct | Imprecise | Pooled RR 1.15 (95% CI = 1.00 to 1.33); I^2^ 0% | Low
Overall/Any Adverse Events | Risperidone vs. olanzapine | 5 RCTs (N = 873)^20–24^ | Moderate | Inconsistent | Direct | Precise | Pooled = RR 1.02 (95% CI = 0.81 to 1.29); I^2^ = 77% | Low
Overall/Any Adverse Events | Olanzapine vs. ziprasidone | 5 RCTs (N = 1097; 6 weeks to 6 months durations)^25–29^ | Moderate | Inconsistent | Direct | Precise | Pooled RR 1.00 (95% CI = 0.86 to 1.16); I^2^ = 80% | Low
Overall/Any Adverse Events | Olanzapine vs. quetiapine | 3 RCTs (N = 448)^20–22^ | Moderate | Consistent | Direct | Imprecise | Pooled RR 0.90 (95% CI 0.74 to 1.11); I^2^ = 30% | Low
Overall/Any Adverse Events | Quetiapine ER versus quetiapine IR and risperidone; risperidone versus clozapine and aripiprazole; olanzapine versus paliperidone; risperidone LAI versus paliperidone and paliperidone palmitate monthly LAI; and aripiprazole versus aripiprazole monthly LAI. Additionally there were six trials comparing asenapine and olanzapine | 1 SR (28 RCTs; N = 7810) | Moderate | Consistent | Direct | Imprecise | No statistically significant differences were found in each comparison. | Low
Overall/Any Adverse Events | Oral aripiprazole versus brexpiprazole, olanzapine, paliperidone, and risperidone LAI; ziprasidone versus clozapine, risperidone, iloperidone and lurasidone; risperidone versus asenapine, carpipramine and risperidone LAI; clozapine versus quetiapine, quetiapine versus risperidone LAI; olanzapine versus olanzapine LAI and lurasidone; aripiprazole monthly LAI versus paliperidone; and paliperidone palmitate monthly LAI versus 3-monthly LAI. | 1 SR (31 RCTs; N = 6700) | Moderate | Unknown | Direct | Imprecise | No statistically significant differences were found in single studies of each comparison. | Insufficient
Discontinuation Due to Adverse Events | Network meta-analysis of aripiprazole, aripiprazole monthly LAI, asenapine, brexipiprazole, cariprazine, clozapine, iloperidone, lurasidone10, olanzapine, olanzapine LAI, paliperidone 3-month LAI, paliperidone, paliperidone Monthly LAI, quetiapine ER, quetiapine IR, risperidone, risperidone LAI, ziprasidone | 89 RCTs (N = 29,678) | Moderate | Consistent | Indirect | Precise | LAI risperidone had statistically significantly lower risk of withdrawals due to adverse events than asenapine (OR 0.50, 95% CI 0.23,0.97); clozapine (OR 0.26, 95% CI 0.10,0.67); lurasidone (OR 0.38, 95% CI 0.17,0.79); paliperidone (OR 0.43, 95% CI 0.17,0.98); paliperidone LAI monthly (OR 0.51, 95% CI 0.26,0.98); quetiapine ER (OR 0.42, 95% CI 0.21,0.78); risperidone (OR 0.48, 95% CI 0.23,0.92); and ziprasidone (OR 0.39, 95% CI 0.18,0.76). Olanzapine had lower risk than clozapine (OR 0.40, 95% CI 0.21,0.79); lurasidone (OR 0.58, 95% CI 0.36,0.98); quetiapine IR (OR 0.64, 95% CI 0.45,0.93); risperidone (OR 0.74, 95% CI 0.55,0.98); and ziprasidone (OR 0.59, 95% CI 0.43,0.84). Aripiprazole had lower risk than ziprasidone (OR 0.65, 95% CI 0.44,0.95) and iloperidone had lower risk than clozapine (OR 0.35, 95% CI 0.13,0.91). | Low

BPRS=Brief Psychiatric Rating Scale, CATIE=clinical Antipsychotic Trials of Intervention Effectiveness, CGI-S=Clinical Global Impression - Severity, CI=confidence interval, ER=efficacy ratio, GAF=global assessment of functioning, HR=hazard ratio, LAI=long acting injectable, NR=normal range, NS=not significant, NSD=no significant difference, OR=odds ratio, PSP=, Q=Cochran’s Q test, QLS=quality of life scale, RCT=randomized controlled trial, RR=relative risk, SF=short form, SFS=Social Functioning Scale, SGA=second-generation antipsychotic, SMD=standard mean difference, SOFA=Social and Occupational Functioning Assessment, SQLS=Schizophrenia Quality of Life Scale, SR=systematic review, WMD=weighted mean difference

Appendix Table H-2 Strength of evidence: first-generation antipsychotic versus second-generation antipsychotic

Outcome | Comparators | Number of Studies Number of Subjects | Study Limitations | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function: General | Haloperidol vs. olanzapine | 1 SR (1 RCT)^30^ N=208 | Moderate | Unknown | Direct | Imprecise | Inconclusive: GAF effect estimate: −4.00; 95% CI −13.70 to 5.70 | Insufficient
Function: Encounters with Legal System | Haloperidol vs. olanzapine | 1 SR (1 RCTs)^30^ N=31 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Encounters with legal system: RR 3.20, 95% CI 0.76 to 13.46 | Insufficient
Function: Employment | Haloperidol vs. risperidone | 1 SR^30^ (1 RCT) N=100 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Proportion of patients with economic independence: RR 0.94; 95% CI 0.68 to 1.29 | Insufficient
Function: Employment | Perphenazine vs. olanzapine | 1 SR^30^ (1 RCT) N=597 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Proportion with paid employment: RR 1.29; 95% CI 0.70 to 2.38 | Insufficient
Function: Employment | Perphenazine vs. quetiapine | 1 SR^30^ (1 RCT) N=598 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Proportion with paid employment: RR 1.75; 95% CI 0.90 to 3.43 | Insufficient
Function: Employment | Perphenazine vs. risperidone | 1 SR^30^ (1 RCT) N=602 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Proportion with paid employment: RR 1.38; 95% CI 0.74 to 2.57 | Insufficient
Function: Employment | Perphenazine vs. ziprasidone | 1 SR^30^ (1 RCT) N=446 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Proportion with paid employment: RR 1.22; 95% CI 0.60 to 2.51 | Insufficient
Quality of Life | Haloperidol vs. olanzapine | 1 SR^30^ (5 RCTs) N=816 | Moderate | Consistent | Direct | Precise | Inconclusive: Effect sizes ranged from −3.62 to 0 using different measures; CIs were not significant | Moderate
Quality of Life | Haloperidol vs. quetiapine | 1 SR^30^ (1 RCT) N=207 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Effect estimate 0.00; 95% CI −1.38 to 1.38 | Insufficient
Quality of Life | Haloperidol vs. risperidone | 1 SR^30^ (2 RCTs) N=352 | Moderate | Inconsistent | Direct | Imprecise | Inconclusive: Effect estimates ranged from −0.10 to 0.10; CIs were not significant | Insufficient
Quality of Life | Haloperidol vs. ziprasidone | 1 SR^30^ (2 RCTs) N=784 | High | Inconsistent | Direct | Imprecise | Studies favored ziprasidone in quality of life measures. One trial found effect favoring ziprasidone based on QLS (effect estimate 12.12; 95% CI −22.06 to −2.17); there was no difference in another trial in MANSA (effect estimate −0.10; 95% CI −1.48 to 1.28) | Low
Quality of Life | Perphenazine vs. aripiprazole | 1 SR^30^ (1 RCT) N=300 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Proportion with 20% improvement: RR 4.74; 95% CI 2.58 to 8.69 | Insufficient
Quality of Life | Perphenazine vs. olanzapine | 1 SR^30^ (1 RCT) N=597 | Moderate | Unknown | Direct | Precise | No difference: Effect estimate 0.00; 95% CI −0.16 to 0.16 | Low
Quality of Life | Perphenazine vs. quetiapine | 1 SR^30^ (1 RCT) N=598 | Moderate | Unknown | Direct | Precise | No difference: Effect estimate 0.10; 95% CI −0.07 to 0.27 | Low
Quality of Life | Perphenazine vs. risperidone | 1 SR^30^ (1 RCT) N=602 | Moderate | Unknown | Direct | Precise | No difference: Effect estimate −0.07; 95% CI −0.24 to 0.10 | Low
Quality of Life | Perphenazine vs. ziprasidone | 1 SR^30^ (1 RCT) N=446 | Moderate | Unknown | Direct | Precise | No difference: Effect estimate −0.07; 95% CI −0.27 to 0.13 | Low
Response | Fluphenazine vs. olanzapine | 1 SR^30^ (1 RCT) N=60 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.74 (95% CI 0.51 to 1.07) | Insufficient
Response | Fluphenazine vs. quetiapine | 1 SR^30^ (1 RCT) N=25 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.62 (95% CI 0.12 to 3.07) | Insufficient
Response | Fluphenazine vs. risperidone | 1 SR^30^ (1 RCT) N=26 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.67 (95% CI 0.13 to 3.35) | Insufficient
Response | Haloperidol vs. aripiprazole | 1 SR^30^ (5 RCTs) N=2,185 | Moderate | Inconsistent | Direct | Precise | No difference: RR 1.01 (95% CI 0.76 to 1.34; I^2^=83%) | Low
Response | Haloperidol vs. asenapine | 1 SR^30^ (1 RCT) N=335 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.82 (95% CI 0.64 to 1.04) | Insufficient
Response | Haloperidol vs. clozapine | 1 SR^30^ (2 RCTs) N=144 | Moderate | Inconsistent | Direct | Imprecise | Inconclusive: RR 0.64 (95% CI 0.28 to 1.47; I^2^= 72%) | Insufficient
Response | Haloperidol vs. olanzapine | 1 SR^30^ (14 RCTs) N=4,099 | Moderate | Inconsistent | Direct | Precise | RR 0.86 (95% CI 0.78 to 0.96; I^2^=55%); favors olanzapine | Low
Response | Haloperidol vs. quetiapine | 1 SR^30^ (6 RCTs) N=1,421 | Moderate | Inconsistent | Direct | Precise | No difference: RR 0.99 (95% CI 0.76 to 1.30; I^2^=77%) | Low
Response | Haloperidol vs. risperidone | 1 SR^30^ (16 RCTs) N=3,452) | Moderate | Consistent | Direct | Precise | No difference: RR 0.94 (95% CI 0.87 to 1.02; I^2^=29%) | Moderate
Response | Haloperidol vs. ziprasidone | 1 SR^30^ (6 RCTs) N=1,283 | Moderate | Inconsistent | Direct | Imprecise | Inconclusive: RR 0.98 (95% CI 0.74 to 1.30; I^2^=80%) | Low
Response | Perphenazine vs. aripiprazole | 1 SR^30^ (1 RCT) N=300 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.95 (95% CI 0.64 to 1.40) | Insufficient
Remission | Haloperidol vs. clozapine | 1 SR^30^ (1 RCT) N=71 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.16 (95% CI 0.02 to 1.20) | Insufficient
Remission | Haloperidol vs. olanzapine | 1 SR^30^ (3 RCTs) N=582 | Moderate | Consistent | Direct | Imprecise | RR 0.65 (95% CI 0.45 to 0.94; I^2^=54%); favors olanzapine | Low
Remission | Haloperidol vs. quetiapine | 1 SR^30^ (1 RCT) N=207 | High | Unknown | Direct | Imprecise | Inconclusive: RR 0.72 (95% CI 0.41 to 1.25) | Insufficient
Remission | Haloperidol vs. risperidone | 1 SR^30^ (2 RCTs) N=179 | Moderate | Consistent | Direct | Imprecise | Inconclusive: RR 0.84 (95% CI 0.56 to 1.24; I^2^=0%) | Low
Remission | Haloperidol vs. ziprasidone | 1 SR^30^ (3 RCTs) N=1,085 | High | Consistent | Direct | Precise | No difference: RR 0.89 (95% CI 0.71 to 1.12; I^2^= 12%) | Low
Reduction in Self Harm | Haloperidol vs. olanzapine | 1 SR^30^ (1 RCT) N=182 | Moderate | Unknown | Indirect | Imprecise | Inconclusive: Attempted suicide: RR 3.13; 95% CI 0.13 to 76 and 0.64 Completed suicide: RR 3.13; 95% CI 0.13 to 76 and 3.86 | Insufficient
Reduction in Self Harm | Perphenazine and olanzapine | 1 SR^30^ (1 RCT) N=597 | Moderate | Unknown | Indirect | Imprecise | Inconclusive: Attempted suicide: RR 0.64; 95% CI 0.06 to 7.06 Completed suicide: RR 3.86; 95% CI 0.40 to 37 | Insufficient
Overall Adverse Events | Haloperidol vs. aripiprazole | 1 SR^30^ (3 RCTS) N=1,713 | Moderate | Consistent | Direct | Precise | RR 1.11; 95% CI 1.06 to 1.17; I^2^=0%; less with aripiprazole | Moderate
Overall Adverse Events | Haloperidol vs. risperidone | 1 SR^30^ (8 RCTs) N=1,313 | Moderate | Consistent | Direct | Precise | RR 1.20; 95% CI 1.01 to 1.42; I^2^= 84%; less with risperidone | Moderate
Overall Adverse Events | Haloperidol vs. ziprasidone | 1 SR^30^ (6 RCTs) N=1,448 | Moderate | Consistent | Direct | Precise | RR 1.13; 95% CI 1.03 to 1.23; I^2^=31%; less with ziprasidone | Moderate
Withdrawal Due to Adverse Events | Fluphenazine vs. olanzapine | 1 SR^30^ (1 RCT) N=60 | Moderate | Unknown | Indirect | Imprecise | Inconclusive: RR 0.74; 95% CI 0.51 to 1.07 | Insufficient
| Fluphenazine vs. quetiapine | 1 SR^30^ (1 RCT) N=25 | Moderate | Unknown | Indirect | Imprecise | Inconclusive: RR 0.19; 95% CI 0.01 to 3.52 | Insufficient
Withdrawal Due to Adverse Events | Haloperidol vs. asenapine | 1 SR^30^ (1 RCT) N=335 | Moderate | Unknown | Indirect | Imprecise | Inconclusive: RR 1.53; 95% 0.74 to 3.16 | Insufficient
Withdrawal Due to Adverse Events | Haloperidol vs. aripiprazole | 1 SR^30^ (7 RCTs) + 1 additional RCT N= 3,232 | Moderate | Consistent | Direct | Precise | RR 1.25; 1.07 to 1.47; I^2^=0% | Moderate
Withdrawal Due to Adverse Events | Haloperidol vs. clozapine | 1 SR^30^ (5 RCTs) N=719 | Moderate | Consistent | Direct | Imprecise | Inconclusive: RR 1.00; 95% CI 0.66 to 1.50; I^2^=0% | Low
Withdrawal Due to Adverse Events | Haloperidol vs. olanzapine | 1 SR^30^ (21 RCTs) + 3 RCTs N= 5,708 | Moderate | Consistent | Direct | Precise | RR 1.89; 95% CI 1.57 to 2.27; I^2^=0% | Moderate
Withdrawal Due to Adverse Events | Haloperidol vs. quetiapine | 1 SR^30^ (8 RCTs) + 2 RCTs N=1,759 | Moderate | Consistent | Direct | Imprecise | Inconclusive: RR 1.97; 95% CI 0.96 to 4.01; I^2^=62% | Low
Withdrawal Due to Adverse Events | Haloperidol vs. risperidone | 1 SR^30^ (23 RCTs) + 2 RCTs N=4,581 | Moderate | Consistent | Direct | Precise | RR 1.32; 95% CI 1.09 to 1.60; I^2^=0% | Moderate
Withdrawal Due to Adverse Events | Haloperidol vs. ziprasidone | 1 SR^30^ (6 RCTs) + 1 RCT N=1597 | Moderate | Consistent | Direct | Precise | RR 1.68; 95% CI 1.26 to 2.23; I^2^=0% | Moderate
Withdrawal Due to Adverse Events | Perphenazine vs. aripiprazole | 1 SR^30^ (1 RCT) N=300 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.53; 95% CI 0.27 to 1.05 | Insufficient
Withdrawal Due to Adverse Events | Perphenazine vs. olanzapine | 1 SR^30^ (1 RCT) N=597 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.83; 95% CI 0.58 to 1.19 | Insufficient
Withdrawal Due to Adverse Events | Perphenazine vs. quetiapine | 1 SR^30^ (1 RCT) N=598 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 1.05; 95% CI 0.72 to 1.55 | Insufficient
Withdrawal Due to Adverse Events | Perphenazine vs. risperidone | 1 SR^30^ (1 RCT) N=602 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 1.54; 95% CI 1.00 to 2.36 | Insufficient
Withdrawal Due to Adverse Events | Perphenazine vs. ziprasidone | 1 SR^30^ (1 RCT) N=446 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 1.01; 95% CI 0.65 to1.58 | Insufficient

CI=confidence interval, OR=odds ratio, RCT=randomized controlled trial, SR=systematic review

Appendix Table H-3 Strength of evidence: assertive community treatment

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function | Assertive community treatment vs. usual care | 1 SR^31^ (3 RCTs) 1 RCT^32^ N=118 | Moderate | Consistent | Direct | Imprecise | No difference in social function compared with usual care. Social function, mean difference 0.03 (95% CI −0.28 to 0.34) | Low
Trouble With Police | Assertive community treatment vs. usual care | 1 SR^31^ (4 RCTs) | Moderate | Consistent | Direct | Imprecise | No differences in arrests (2 trials; OR 1.17, 95% CI 0.60 to 2.29), imprisonment (4 trials; OR 1.19, 95% CI 0.70 to 2.01), or police contacts (2 trials; OR 0.76, 95% CI 0.32 to 1.79) | Low
Housing and Independent Living | Assertive community treatment vs. usual care | 1 SR^31^ (3 RCTs) 1 RCT^32^ N=118 | Moderate | Consistent | Direct | Precise | Less likely to be not living independently (4 trials; OR 0.52, 95% CI 0.35 to 0.79), to be homeless (4 trials; OR 0.20, 95% CI 0.09 to 0.47). Less likely to be homeless (4 trials, OR 0.24, 95% CI 0.12 to 0.48). | Moderate
Employment | Assertive community treatment vs. usual care | 1 SR^31^ (3 RCTs) | Moderate | Consistent | Direct | Precise | Less likely to be unemployed (3 trials; OR 0.46, 95% CI 0.21 to 0.99) | Moderate
Quality of Life | Assertive community treatment vs. usual care | 1 SR^31^ (1 RCT) N=125 1 RCT^32^ N=118 | Moderate | Inconsistent | Direct | Imprecise | Quality of life was slightly better with assertive community treatment (mean difference, −0.52, 95% CI −0.99 to −0.05) in one trial, but no differences found in the other trial. | Insufficient
Overall Symptoms | Assertive community treatment vs. usual care | 1 SR^31^ (3 RCTs) 1 RCT^32^ N=118 | Moderate | Consistent | Direct | Precise | No differences were found in 4 trials. Mean difference, −0.14 (95% CI −0.36 to 0.08). | Moderate
Treatment Maintenance (Loss to Followup) | Assertive community treatment vs. usual care | 1 SR^31^ (10 RCTs) 1 RCT^32^ N=118 | Moderate | Consistent | Direct | Precise | Significantly less loss to followup with assertive community treatment (OR 0.51, 95% CI 0.40 to 0.65) based on 10 trials in SR; and significantly fewer patients “out-of-care” in the other trial (OR 0.10, 95% CI 0.03 – 0.33) | Moderate

CI=confidence interval, N=number, OR=odds ratio, RCT=randomized controlled trial, SR=systematic review

Appendix Table H-4 Strength of evidence: cognitive behavioral therapy

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function: Global Function – Short term (≤6 months since CBT initiation) | CBT vs. usual care | 1 SR^33^ (3 RCTs) 5 RCTs^34–38^ N=701 | Moderate | Consistent | Direct | Precise | GAF (6 RCTs): mean difference 5.49 (95% CI 1.85 to 9.14; I^2^=75%); excluding one outlier: 6.62 (95% CI 4.68 to 8.56; I^2^=0%) SOFAS (2 RCTs): mean difference 9.11 (95% CI 6.31 to 11.91) Proportion with normal function (1 RCT): RR 2.21 (95% CI 1.25 to 3.93) | Moderate
Function: Global Function – Medium term (>6 months to 1 year since CBT initiation) | CBT vs. usual care | 3 RCTs^34,36,39^ N=465 | Moderate | Inconsistent | Direct | Imprecise | Inconclusive: GAF: One trial found with 6 months posttreatment followup found no difference; another trial found effect favoring CBT SOFAS, SFS: No difference between groups | Insufficient
Function: Global Function – Long term (>1 year since CBT initiation) | CBT vs. usual care | 1 SR^33^ (4 RCTs) 4 RCTs^37,39–41^ n=851 | Moderate | Consistent | Direct | Imprecise | Inconclusive: GAF: 1 SR found mean difference 4.20 (95% CI −0.63 to 9.03). One other RCT found positive effect of CBT. 3 RCTs found no difference in SOFAS, global function (scale not reported) and proportion of patients with normal function. | Low
Function: Basic Living Skills | CBT vs. usual care | 1 RCT^42^ N=76 | Moderate | Unknown | Direct | Imprecise | No difference between groups. | Insufficient
Function: Employment Outcomes | CBT vs. usual care | 2 RCTs^43,44^ N=522 | Moderate | Inconsistent | Direct | Imprecise | Inconclusive: One RCT of vocational-focused CBT favored CBT for hours worked and WBI score; another trial found no difference in proportion of patients with occupational recovery | Insufficient
Quality of Life | CBT vs. usual care | 12–24 weeks followup; 2 RCTs^38,45^ N = 216 | Moderate | Consistent | Direct | Imprecise | CBT led to improved quality of life 0 and 16 weeks after cessation of treatment based on CHOICE, WEMWEBS and WHOQoL-BREF scales. | Low
Quality of Life | CBT vs. usual care | 18 to 24 months followup; 2 RCTs^37,39^ N=489 | Moderate | Consistent | Direct | Imprecise | CBT not different from usual care based on WHOQoL and EROQOL scales | Low
Suicide and Suicidality | CBT vs. usual care | 2 RCTs^45,46^ N=307 | Moderate | Consistent | Direct | Imprecise | Inconclusive: RR 0.68 (95% CI 0.12 to 3.93) and RR 0.53 (95% CI 0.12 to 2.79) | Insufficient
Core Illness Symptoms | CBT vs. usual care | 1 SR (34 RCTs)^47^ N=2,989 | Moderate | Consistent | Direct | Precise | SMD −0.33, 95% CI −0.47 to −0.19); subgroup with outcome assessment blinding SMD −0.15, 95% CI −0.27 to −0.03), | Moderate
Negative Symptoms | CBT vs. usual care | 2 SRs (34 RCTs)^47,48^ N=3,393 | Moderate | Inconsistent | Direct | Precise | Standardized mean difference −0.13, 95% CI −0.25 to −0.01; I^2^=48% [in this review a negative estimate favors CBT]; and SMD 0.09, 95% CI −0.03 to 0.21; I^2^=63% [in this review, a positive estimate favors CBT]) | Low
Ability to Maintain Treatment | CBT vs. usual care | 13 RCTs ^34–42,44,45,49,50^ N=1,847 | Moderate | Inconsistent | Direct | Precise | No difference: Relative risk 1.03, 95% CI 0.96 to 1.10; I^2^=64%. | Low
Relapse | CBT vs. usual care | 6 RCTs^34,36,39,44,49,51^ N=1,090 | Moderate | Inconsistent | Direct | Imprecise | Inconclusive: Relative Risk: 0.80, 95% CI 0.51 to 1.25; I^2^=77%) Subanalysis limited to relapse defined as “hospitalization” (3 RCTs): 0.70, 95% CI 0.54 to 0.91; I^2^=0% | Insufficient
Harms | CBT vs. usual care | 1 RCT^45^ | | | | | | Insufficient

CBT=cognitive behavioral therapy, CI=confidence interval, EROQOL= European Quality of Life scale, GAF=global assessment of functioning, OR=odds ratio, RCT=randomized controlled trial, RR=relative risk, SMD=standard mean difference, SOFAS=Social and Occupational Functioning Assessment Scale, SR=systematic review, WHOQOL= World Health Organization Quality of Life

Appendix Table H-5 Strength of evidence: cognitive remediation

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function | Cognitive remediation vs. usual care | 1 SR^52^ (19 RCTs) 3 RCTs^53–55^ N=1,323 | Moderate | Consistent | Direct | Imprecise | In studies comparing with usual care, cognitive remediation resulted in a small positive effect on function that was not consistently statistically significant. (effect size 0.16, 95% CI −0.16 to 0.49; SMD 0.56, 95% CI 0.34 to 0.88, and SMD 0.41, 95% CI −.10 to 0.91). | Low
Quality of life | Cognitive remediation vs. usual care | 1 RCT^55^ N=69 | Moderate | Unknown | Direct | Imprecise | Quality of life was only reported in one trial, with no difference between cognitive remediation and usual care. | Insufficient
Overall symptoms | Cognitive remediation vs. usual care | 2 RCTs^55,56^ N=153 | Moderate | Consistent | Direct | Imprecise | Cognitive remediation improved total symptoms, based on 2 trials (N=153, SMD −0.62 (95% CI −1.01 to −0.24). Four trials included in the Wykes review reported effect sizes ranging from 0.05 to 0.45 (95% CIs were not reported). | Moderate
Negative symptoms | Cognitive remediation vs. usual care | 1 SR^57^ (18 RCTs; N=781) | Moderate | Consistent | Direct | Precise | Negative symptoms improved more in CR groups (effect size −0.36 (95% CI −0.52 to −0.20; a negative effect size favors cognitive remediation). | Moderate
Ability to maintain treatment | Cognitive remediation vs. usual care | 3 RCTs^53,54,56,58^ N=302 | Moderate | Consistent | Direct | Imprecise | There was no difference in ability to maintain treatment in three RCTs of cognitive remediation | Low

CI=confidence interval, CR=cognitive remediation, RCT=randomized controlled trial, QLS= quality of life survey, QOL=quality of life, SR=systematic review, WBI=Work Behavior Inventory

Appendix Table H-6 Strength of evidence: family interventions

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function: Occupational (Unemployed) -1 year | Family intervention vs. usual care | 1 SR^59^ (4 RCTs; N=230) | Moderate | Consistent | Direct | Imprecise | RR 1.09 (0.92 to 1.29) | Low
Function: Occupational (Unemployed) – 2 years | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=51) | Moderate | Unknown | Direct | Imprecise | RR 1.33 (0.84 to 2.10) | Insufficient
Function: Occupational (Unemployed) – 3 years | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=99) | Moderate | Unknown | Direct | Imprecise | RR 1.19 (0.92 to 1.55) | Insufficient
Function: Living situation (cannot live independently) – 1 year | Family intervention vs. usual care | 1 SR^59^ (3 RCTs; N=164) | Moderate | Consistent | Direct | Imprecise | RR 0.83 (0.66 to 1.03) | Low
Function: Living situation (cannot live independently) - 3 years | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=99) | Moderate | Unknown | Direct | Imprecise | RR 0.82 (0.59 to 1.14) | Insufficient
Function: Living situation (cannot live independently, months in psychiatric facility) - 5 years | Family intervention vs. usual care | 1 RCT^60^; N=63) | Moderate | Unknown | Direct | Imprecise | 10.87 vs. 21.18 months, p=0.04) | Insufficient
Social Functioning | Family intervention vs. usual care | 1 RCT^36^ N=69 | Moderate | Unknown | Direct | Imprecise | | Insufficient
Quality of Life | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=50) plus one RCT not in SR;^39^ N=55 | Moderate | Unknown | Direct | Imprecise | Heinrichs scale: MD −5.05 (−15.44 to 5.34) EuroQol: MD −7.38 (−22.07 to 7.31) | Insufficient
Depression | Family intervention vs. usual care | 2 RCTs;^36,39^ N=124 | Moderate | Consistent | Direct | Imprecise | 1 RCT, 6 months: −1.0 (−12, 22) vs. 0 (−15, 17) 1 RCTs 12 months: 3.0 (−15, 17) vs. 0 (−14 to 17) 1 RCT 12 months; 3.35 (−2.64 to 9.34) 1 RCT 24 months: −0.11 (−6.91 to 6.68) | Low
Anxiety | Family intervention vs. usual care | 1 RCT;^39^ N=55 | Low | Unknown | Direct | Imprecise | 12 months: −0.42 (−6.97 to 6.13) 24 months: −2.36 (−9.13 to 4.40) | Insufficient
Suicide | Family intervention vs. usual care | 1 SR^59^ (6 RCTs; N=314) | Moderate | Consistent | Direct | Imprecise | RR 0.85 (0.24 to 3.02) | Low
Core Illness Symptoms: | Family intervention vs. usual care | 1 SR^59^ (2 RCTs;^39,61^ N=223) | Moderate | Consistent | Direct | Imprecise | SMD −0.46 (−0.73 to −0.20) | Low
Negative Symptoms | Family intervention vs. usual care | 3 RCTs; ^36,39,61^ N=163 | Moderate | Consistent | Direct | Imprecise | SMD −0.38, 95% CI −0.69 to −0.07 | Low
Leaving the study early (3–6 months) | Family intervention vs. usual care | 1 SR^59^ (6 RCTs; N=504) | Moderate | Consistent | Indirect | Imprecise | RR 0.86 (0.50 to 1.47) | Low
Leaving the study early (7–12 months) | Family intervention vs. usual care | 1 SR^59^ (9 RCTs; N=487) plus 4 RCTs;^39,61–63^ N=466 | Moderate | Consistent | Indirect | Imprecise | RR 0.77 (0.64 to 0.93) | Low
Leaving the study early (13–24 months) | Family intervention vs. usual care | 1 SR^59^ (6 RCTs; N=362) | Moderate | Consistent | Indirect | Imprecise | RR 0.82 (0.57 to 1.16) | Low
Leaving the study early (25–36 months) | Family intervention vs. usual care | 1 SR^59^ (2 RCTs; N=90) | High | Consistent | Indirect | Imprecise | RR 0.59 (0.24 to 1.49) | Insufficient
Leaving the study early after 3 years | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=63) | Moderate | Unknown | Indirect | Imprecise | RR 1.72 (0.71 to 4.16) | Insufficient
Poor compliance with medication | Family intervention vs. usual care | 1 SR^59^ (4 RCTs; N=174) plus 2 RCTs^62,63^ N=256 | Moderate | Consistent | Indirect | Imprecise | RR 0.78 (0.65 to 0.92) | Low
Relapse 0–6 months | Family intervention vs. usual care | 1 SR^59^ (2 RCTs; N=167) | Moderate | Consistent | Direct | Imprecise | RR 0.62 (0.41 to 0.92) | Low
Relapse (7–12 months) | Family intervention vs. usual care | 1 SR^59^ (16 RCTs; N=861) plus 4 RCTs;^39,61,63,64^ N=314 | Moderate | Consistent | Direct | Imprecise | RR 0.67 (0.54 to 0.83) | Moderate
Relapse (13–24 months) | Family intervention vs. usual care | 1 SR^59^ (9 RCTs; N=517) | Moderate | Consistent | Direct | Imprecise | RR 0.75 (0.58 to 0.99) | Low
Relapse (25–36 months) | Family intervention vs. usual care | 1 SR^59^ (2 RCTs; N=147) | Moderate | Inconsistent | Direct | Imprecise | RR 1.05 (0.80 to 1.39) | Low
Relapse (5 years) | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=63) plus 1 RCT;^64^ N=77 | Moderate | Consistent | Direct | Imprecise | RR 0.82 (0.72 to 0.94) | Low
Relapse (8 years) | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=62) | Moderate | Unknown | Direct | Imprecise | RR 0.86 (0.71 to 1.05) | Insufficient
Family Burden Not Improved or Worse | Family intervention vs. usual care | 1 SR^59^ (1 RCT; N=51) | Moderate | Unknown | Direct | Imprecise | Social functioning: RR 2.40 (0.51 to 11.27) at 1 year RR 2.88 (0.64 to 12.97) at 2 years Subjective burden: RR 1.44 (0.60 to 3.46) at 1 year RR 0.58 (0.15 to 2.16) at 2 years | Insufficient
Nonsuicide mortality | Family intervention vs. usual care | 1 SR^59^ (3 RCTs; N=113) | Moderate | Consistent | Direct | Imprecise | RR 0.96 (0.17 to 5.33) | Insufficient

BPRS=Brief Psychiatric Rating Scale, MD=mean difference, RR=relative risk, RCT=randomized controlled trial, SR=systematic review

Appendix Table H-7 Strength of evidence: intensive case management

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function | Intensive case management vs. usual care | 1 SR^65^ (3 RCTs) 1 RCT^66^ (n=77) | Moderate | Consistent | Direct | Imprecise | Inconclusive: Pooled mean difference, 0.46 (95% CI −0.34 to 0.1.26); one subsequent trial also found no difference using a different scale | Low
Quality of Life | Intensive case management vs. usual care | 1 SR^65^(2 RCTs) 1 RCT^66^ (n=77) | Moderate | Consistent | Direct | Imprecise | Inconclusive: Pooled mean difference, 0.09 (95% CI −0.23 to 0.42); One subsequent trial also found no difference between groups in quality of life using a different scale. | Insufficient
Overall Symptoms | Intensive case management vs. usual care | 1 SR^65^ (2 RCTs) 1 RCT^66^ (n=77) | Moderate | Consistent | Direct | Imprecise | Inconclusive: Pooled mean difference, 0.46 (95% CI −3.67 to 4.60); one subsequent trial also reported no difference. | Low
Loss to Followup | Intensive case management vs. usual care | 1 SR^65^ (7 RCTs) 1 RCT^66^ (n=77) | Moderate | Consistent | Direct | Precise | Less loss to followup with intensive case management compared to usual care (OR 0.70, 95% CI 0.54 to 0.90) | Moderate
Imprisonment | Intensive case management vs. usual care | 1 SR^65^ (5 RCTs) | Moderate | Consistent | Direct | Imprecise | No significant differences in imprisonment (OR 0.90, 95% CI 0.45 to 1.82) | Low

CI=confidence interval, RCT=randomized controlled trial, OR=odds ratio, SR=systematic review

Appendix Table H-8 Strength of evidence: illness management and recovery

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Functioning | Illness self-management/self-management education intervention vs. usual care | 1 SR of 10 RCTs (N = 409)^67^+ 1 RCT; N = 210 | Moderate | Inconsistent | Direct | Imprecise | Inconclusive: Heterogeneous methods for measuring various types of functioning were used, with 5 finding benefit ad 6 not. | Insufficient
Symptoms | Illness self-management/self-management education intervention vs. usual care | 1 SR^67^ 5 RCTs n=409 | Moderate | Consistent | Direct | Precise | BPRS (n=409), WMD: −4.19 (−5.84 to −2.54) | Moderate
Negative Symptoms | Illness self-management/self-management education intervention vs. usual care | 1 SR,^67^ 3 RCTs; N = 257 | Moderate | Consistent | Direct | Imprecise | PANSS negative −4.01 (−5.23 to −2.79) | Low
Relapse | Illness self-management/self-management education intervention vs. usual care | 1 SR,^67^ 3 RCTs; N=534 | Moderate | Consistent | Direct | Imprecise | Relapse (>10 interventions), n=233 OR= 0.41 (0.21–0.79), p=0.008 Relapse (<10 interventions), n=269 OR= 0.67 (0.39–1.15), p=0.014 | Low

BPRS=Brief Psychiatric Rating Scale, CI=confidence interval, IMR=illness management and recovery, RCT=randomized controlled trial, SR=systematic review, WMD=weighted mean difference

Appendix Table H-9 Strength of evidence: psychoeducation

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Global Functioning (GAF/GAS) at end of intervention | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 41) | Medium | Unknown | Direct | Imprecise | Inconclusive: Mean Difference −2.64 CI −12.74 to 7.46 | Insufficient
Global Functioning (GAS) at 6 Months | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 92) | Medium | Unknown | Direct | Imprecise | Inconclusive: Risk Ratio 0.83 CI 0.50 to 1.38 | Insufficient
Global Functioning (GAF/GAS) at 1 Year | Psychoeducation vs. standard care | 1 SR^68^ (3 RCTs; N = 260) | Medium | Consistent | Direct | Imprecise | Mean Difference −5.23 CI −8.76 to −1.71 I^2^ 79% | Low
Global Functioning (GAS) at 18 Months | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 92) | Medium | Unknown | Direct | Imprecise | Inconclusive: Risk Ratio 0.90 CI 0.58 to 1.39 | Insufficient
Global Functioning (GAF/GAS) at 2 Years | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 59) | Medium | Unknown | Direct | Imprecise | Mean Difference −6.70 CI −13.38 to −0.02 | Insufficient
Global Functioning (GAF/GAS) at 5 Years | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 60) | Medium | Unknown | Direct | Imprecise | Inconclusive: Mean Difference −3.80 CI −8.04 to 0.44 | Insufficient
Social Functioning (SAS-II) at End of Intervention | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 19) | Medium | Unknown | Direct | Imprecise | Inconclusive: Mean Difference −0.10 CI −0.37 to 0.17 | Insufficient
Quality of Life (Heinrich’s Scale) at End of Intervention | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 114) | Medium | Unknown | Direct | Imprecise | Mean Difference −8.20 CI −14.78 to −1.62 | Insufficient
Quality of Life (Heinrich’s Scale) at 3 Months | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 108) | Medium | Unknown | Direct | Imprecise | Mean Difference −9.70 CI −17.22 to −2.18 | Insufficient
BPRS at 3 Months | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 19) | Medium | Unknown | Direct | Imprecise | Inconclusive: Mean Difference −0.06 CI −0.53 to 0.41 | Insufficient
BPRS at 1 Year | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 159) | Medium | Unknown | Direct | Imprecise | Mean Difference −6.0 CI −9.15 to −2.85 | Insufficient
Relapse With or Without Readmission: 9 to 18 Months | | 1 SR^68^ (6 RCTs; N = 720) | Medium | Consistent | Direct | Precise | Risk Ratio 0.80 CI 0.70 to 0.92 I^2^ 54% | Moderate
Relapse Without Readmission: Total | Psychoeducation vs. standard care | 1 SR^68^ (3 RCTs; N = 385) | Medium | Consistent | Direct | Imprecise | Inconclusive: Risk Ratio 1.05 CI 0.84 to 1.31 I^2^ 60% | Low
Relapse Without Readmission: 1 Year | Psychoeducation vs. standard care | 1 SR^68^ (2 RCTs; N = 303) | Medium | Consistent | Direct | Imprecise | Inconclusive: Risk Ratio 1.16 CI 0.92 to 1.46 I^2^ 0.0% | Low
Relapse Without Readmission: 18 Months | Psychoeducation vs. standard care | 1 SR^68^ (1 RCT; N = 382) | Medium | Unknown | Direct | Imprecise | Inconclusive: Risk Ratio 0.5 CI 0.23 to 1.11 | Insufficient
Harms: Mortality | Psychoeducation vs. standard care | 1 SR^68^ (2 RCTs; N = 170) | Medium | Consistent | Direct | Imprecise | Inconclusive: Risk Ratio 0.53 CI 0.07 to 3.95 I^2^ 0.0% | Low

BPRS=Brief Psychiatric Rating Scale, CI=confidence interval, GAF =global assessment functioning, GAS=global assessment scale, RCT=randomized controlled trial, SAS=social adjustment score, SR=systematic review

Appendix Table H-10 Strength of evidence: social skills training

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function | Social skills training vs. usual care | 3 RCTs (4 publications) ^63,69–71^ N = 384 | Moderate | Consistent | Direct | Imprecise | Significant improvement in scale scores during treatment for 6 months to 2 years (SMD 0.65 to 1.60) | Low
Function | Social skills training vs. usual care | 1 RCT^69,70^ N = 183 | Moderate | Unknown | Direct | Imprecise | Social function not different from control after treatment cessation (1 study; SMD 0.24; 95% CI −0.05 to 0.53) | Insufficient
Overall Symptoms | Social skills training vs. usual care | 2 RCTs^63,71^ N = 201 | Moderate | Consistent | Direct | Imprecise | Inconclusive: PANSS: SMD −1.50 (95% CI −1.92 to −1.09 and −0.81 (95% CI −1.22 to −0.40) BPRS (mixed population): SMD −0.04 (95% CI −0.33 to 0.25) | Low
Overall Symptoms | Social skills training vs. usual care | 1 RCT^69,70^ N = 183 | Moderate | Unknown | Direct | Imprecise | Inconclusive: Mixed population (55% schizophrenia): no significant effect on symptoms (BPRS) SMD −0.04; 95% CI −0.33 to 0.25. | Insufficient
Negative Symptoms | Social skills training vs. usual care | 3 RCTs (4 publications) ^63,69–71^ N = 384 | Moderate | Consistent | Direct | Imprecise | Negative symptoms improved with SST versus usual care based on PANSS-negative and SANS SMD range −0.45 to −1.30) at 6 months to 2 years | Low
Negative Symptoms | Social skills training vs. usual care | 1 RCT^69,70^ N = 183 | Moderate | Unknown | Direct | Imprecise | Negative symptoms were better with SST than usual care 1 year after treatment discontinuation (SMD −0.45; 95% CI −0.74 to −0.15 | Insufficient
Ability to Maintain Treatment | Social skills training vs. usual care | 2 RCTs^63,70^ N = 384 | Moderate | Consistent | Direct | Imprecise | No difference: One year: RR 1.10 (95% CI 0.92 to 1.31) Two-year: RR 1.01; 95% CI 0.88 to 1.16 | Low
Relapse | Social skills training vs. usual care | 1 RCT^63^ N = 82 | Moderate | Unknown | Direct | Imprecise | Inconclusive: RR 0.50; 95% CI 0.18 to 1.36 | Insufficient

BPRS=Brief Psychiatric Rating Scale, CI=confidence interval, RCT=randomized controlled trial, RR=relative risk, SANS=scale for assessment of negative symptoms, SMD=standard mean difference, SST=social skills training

Appendix Table H-11 Strength of evidence: supported employment

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Functional (occupational) - # in competitive employment | Individual placement and support (IPS) vs. standard services | 1 trial^72^ N=204 | Moderate | Unknown | Direct | Imprecise | IPS vs. standard services: 75% vs 27.5% (p<0.001) | Low
| Supported Employment (primarily IPS) vs. vocational training or usual care | 1 RCT^73,74^ (N = 1,273) | Moderate | Consistent | Indirect for this review question | Precise | IPS vs. vocational training or usual care 55% vs 34% (P<0.001) Subgroup analysis of sonly patients with schizophrenia: 22% vs. 12% (from figure) P< 0.001 with mixed effects logistic regression | Moderate
Combined SOE | | | | | | | | Moderate
Functional (occupational) - Days to first competitive employment | Individual placement and support (IPS) vs. standard services | 1 trial^72^ N=204 | Moderate | Unknown | Direct | Imprecise | IPS vs. standard services: Days to first job, 196.63 vs. 218.84; P = 0.019 | Low
Functional (occupational) – Worked more than 20 hours per week | Individual placement and support (IPS) vs. standard services | 1 trial^72^ N=204 | Moderate | Unknown | Direct | Imprecise | IPS vs. standard services: Worked > 20 hrs per week33.8% vs 13%; P=0.001 | Low
| Supported Employment (primarily IPS) vs. vocational training or usual care | 1 RCT^73,74^ (N = 1,273) | Moderate | Consistent | Indirect for this review question | Precise | IPS vs. vocational training or usual care # working ≥40 hours per month 51% vs 39%; P <0.001 | Moderate
Combined SOE | | | | | | | | Moderate
Functional (occupational) – Wages earned | Individual placement and support (IPS) vs. standard services | 1 trial^72^ N=204 | Moderate | Unknown | Direct | Imprecise | IPS vs. standard services: $2,078/mo vs $617.59/mo; P< 0.001 | Low
| Supported Employment (primarily IPS) vs. vocational training or usual care | 1 RCT^73,74^ (N = 1,273) | Moderate | Consistent | Indirect for this review question | Precise | IPS vs. vocational training or usual care $122/mo vs $99/mo; P=.04 | Moderate
Combined SOE | | | | | | | | Moderate
Functional (occupational) – Weeks worked (mean) | Individual placement and support (IPS) vs. standard services | 1 trial^72^ N=204 | Moderate | Unknown | Direct | Imprecise | IPS vs. standard services: Total weeks worked 29.72 vs 5.45; P<0.001 | Low
| Supported Employment (primarily IPS) vs. vocational training | 1 SR^75^ (N = 2,265) | Moderate | Consistent | Indirect for this review question | Precise | Supported Employment vs. vocational training Days employed Mean Difference 70.63 (95% CI 43.22, 98.04) | Moderate
Combined SOE | | | | | | | | Moderate

BPRS=Brief Psychiatric Rating Scale, CI=confidence interval, NNT=number needed to treat, OR=odds ratio, PANSS=positive and negative syndrome scale, QOL=quality of life, RCT=randomized controlled trial, RR=relative risk, SR=systematic review, WBI=Work Behavior Inventory

Appendix Table H-12 Strength of evidence: supportive therapy

Outcome | Comparators | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Global Functioning | Supportive therapy vs. standard care | 1 SR^76^ (2 RCTs; N =289) | Moderate | Consistent | Direct | Imprecise | Inconclusive: GAF-M, n = 29, mean difference 1.40 CI −5.09 to 7.89; GAS, n = 260, mean difference −2.66 CI −6.20 to 0.88. | Low
Social Functioning | Supportive therapy vs. standard care | 1 SR^76^ (1 RCT; N = 260) | Moderate | Unknown | Direct | Imprecise | Inconclusive: SFS: n = 260, mean difference −0.67 CI −7.05 to 5.71. | Insufficient
Quality of Life | Supportive therapy vs. standard care | 1 SR^76^ (1 RCT; N = 260) | Moderate | Unknown | Direct | Imprecise | Inconclusive: Rosenberg Self-Esteem Scale (RSES) n = 260, MD −1.21 CI −2.85 to 0.43. Well-being scale (WBS) score = 260,MD−2.73 CI −6.04 to 0.58. Global health quotient (GHQ) n = 260, MD −2.45 CI −2.41 to 7.31. | Insufficient
Relapse | Supportive therapy vs. standard care | 1 SR^76^ (1 RCT, N = 54) | Moderate | Unknown | Direct | Imprecise | Inconclusive: Medium term followup (13 to 26 weeks, N= 54, RR 0.12 CI 0.01 to 2.11s), or long term followup (more than 26 weeks, n = 54, RR 0.96 CI 0.44 to 2.11) | Insufficient
Core Symptoms | Supportive therapy vs. standard care | 1 SR^76^ (2 RCTs, N = 167) | Moderate | Unknown | Direct | Imprecise | Inconclusive: PANSS: Short term (13 to 26 weeks; N = 131 Mean Difference −4.42 (95% CI −10.13, 1.29). Long term (more than 26 weeks, n = 36, Mean Difference 4.70 (95% CI −6.71, 16.11). | Insufficient
Negative Symptoms | Supportive therapy vs. standard care | 1 SR^76^ (1 RCT, N = 47) | Moderate | Unknown | Direct | Imprecise | Inconclusive: Short term: 10.19 and 10.73; long-term: 9.90 and 11.46 (no statistical analysis because of skewed data). | Insufficient
Discontinuing Treatment | Supportive therapy vs. standard care | 1 SR^76^ (4 RCTs, N = 354) | Moderate | Consistent | Direct | Imprecise | Inconclusive: Relative Risk 0.86 (95% CI 0.53, 1.40) | Low

CI=confidence interval, GAF=global assessment functioning, GAS=global assessment scale, GHQ=global health quotient, MD=mean difference, PANSS=positive and negative syndrome scale, RCT=randomized controlled trial, RR=relative risk, RSES=Rosenberg Self-Esteem Scale, SR=systematic review

Appendix Table H-13 Strength of evidence: early interventions for patients with first-episode psychosis

Outcome | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Functional: Global (GAS, GAF) | 1 SR^77^, 1 RCT^78^ N=369 (two-year data only) 2 RCTs N=744^79^ N=98^80^ | Moderate | Consistent | Direct | Precise | GAS and GAF results only Team-based CSC result in higher functioning scores. Pooled WMD: 3.88 (95% CI = 0.91 to 6.85) I^2^ = 64% | Moderate
Functional: Working or School | 1 SR^77^, 1 RCT^78^ (OPUS-Scandinavia) N=547) 2 RCTs N=125^80^ N=744^79^ | Moderate | Consistent | Direct | Precise | Significantly more people (22%) are working or in school with team-based CSC Pooled RR 1.22 (95% CI = 1.01 to 1.47) | Moderate
Functional: Housing Status | 1 SR^77^ 1 RCT N=547^78^) 1 RCT N=128^80^ | Moderate | Consistent | Direct | Imprecise | No significant difference between groups Pooled RR 1.06 (95% CI = 0.86 to 1.30) | Low
Health-Related Quality of Life | 2 RCTs N=92^80^ N=403^81^ | Moderate | Consistent | Direct | Precise | Team-based CSC results in greater quality of life ratings as endpoint. Pooled effect size 0.84 (95% CI = 0.14 to 1.55); P = 0.02. Cochrane Q for heterogeneity = 7.43, p = 0.0064 (significant heterogeneity) | Moderate
Core Illness Symptoms (PANSS) | 3 RCTs N=99^80^ N=403^81^ N=1,184^79^ | Moderate | Inconsistent | Direct | Precise | No clinically important difference between groups in endpoint scores. Pooled WMD of all 3 RCTs = −2.53 (95% CI −5.45 to 0.39; I^2^ = 55%). Sensitivity analysis removing a study with a 5.9-point difference at baseline results in a very small but statistically significant difference and no heterogeneity. Pooled WMD of 2 RCTs = −1.40 (95% CI −2.25 to −0.55; Cochran Q for heterogeneity = 0.0014 (df = 1) P = 0.97) | Low
Core Illness Symptoms (Calgary Depression Scale) | 2 RCTs N=99^80^ N=205^82^ | Moderate | Consistent | Direct | Precise | No significant difference between groups in endpoint scores. Pooled WMD −0.44 (95% CI −1.08 to 0.20). Heterogeneity: Cochran Q = 0.528157 (df = 1) P = 0.4674 | Moderate
Discontinuation of Treatment | 2 RCTs N=1239^79^ N=136^83^ | Moderate | Consistent | Direct | Precise | Team-based CSC had a significantly greater rate of treatment retention compared to standard care Pooled relative risk = 1.27 (95% CI 1.16 to 1.38); Cochran Q = 0.03 (df = 1) P = 0.86 | High
Rates of Relapse | 2 RCTs N=1239^79^ N=122^83^ | Moderate | Consistent | Direct | Imprecise | Participants in team-based CSC were significantly less likely to relapse than those in standard care. Pooled relative risk = 0.64 (95% CI 0.52 to 0.79) Cochran Q = 0.024 (df = 1) P = 0.88 | Moderate

CI=confidence interval, FEP=first episode psychosis, GAF=global assessment functioning, GAS=global assessment scale, GAF=Global Assessment of Functioning, GAS=Global Assessment Scale, PANSS=Positive and Negative Syndrome Scale, RCT=randomized controlled trial, RR=relative risk, SR=systematic review, WMD=weighted mean difference

Appendix Table H-14 Strength of evidence: co-occurring substance use and schizophrenia

Outcome | Number of Studies Number of Subjects | Strength of Evidence Domain: Study Limitations | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence (High, Moderate, Low, Insufficient)
Function: Global Function (Integrated: GAF; 6 months) | 1 SR^84^(1 RCT; N=162) | Moderate | Unknown | Direct | Imprecise | Inconclusive: MD 1.10 (−1.58 to 3.78) | Low
Function: Global Function (Integrated: GAF; 18 months) | 1 SR^84^ (1 RCT; N=176) | Moderate | Unknown | Direct | Imprecise | Inconclusive: MD 1.00 (−1.58 to 3.58) | Low
Function: Global Function (Integrated: GAF; 24 months) | 1 SR^84^ (1 RCT; N=166) | Moderate | Unknown | Direct | Imprecise | Inconclusive: MD 1.70 (−1.18 to 4.58) | Low
Function: Global Function (Integrated: GAF: 30 months) | 1 SR^84^ (1 RCT; N=164) | Moderate | Unknown | Direct | Imprecise | Inconclusive: MD −0.60 (−3.56 to 2.36) | Low
Function: Global Function (Integrated: GAF: 36 months) | 1 SR^84^ (1 RCT; N=170) | Moderate | Unknown | Direct | Imprecise | Inconclusive: MD 0.40 (−2.47 to 3.27) | Low
Function: Global Function (Non-Integrated: mean RFS score; 6 months) | 1 SR^84^ (1 RCT; N=50) | Moderate | Unknown | Direct | Imprecise | Inconclusive: MD −0.78 (−2.91 to 1.35) | Insufficient
Function: Global Function (Non-Integrated: mean RFS score; 6 months) | 1 SR^84^ (1 RCT; N=29) | Moderate | Unknown | Direct | Imprecise | MD −2.67 (−5.28 to −0.06) | Insufficient
Ability to maintain treatment (6 months) | 1 SR^84^ (3 RCTs; N=134) | Moderate | Consistent | Direct | Imprecise | Inconclusive: RR 1.23 (0.73 to 2.06) | Insufficient
Ability to maintain treatment (18 months) | 1 SR^84^ (3 RCTs; N=134) | Moderate | Consistent | Direct | Imprecise | Inconclusive: RR 1.35 (0.83 to 2.19) | Insufficient

GAF=global assessment functioning, MD=mean difference, RCT=randomized controlled trial, RFS=role functioning score, SR=systematic review

## Appendix H References

1 McDonagh M, Peterson K, Fu R, . Second Generation Antipsychotic Drugs. Final Update 4 Report prepared by the Pacific Northwest Evidence-based Practice Center for the Drug Effectiveness Review Project. Oregon Health & Science University, Portland, Oregon, November 2013. 2013. Available with membership in the Drug Effectiveness Review Project. http://www.ohsu.edu/xd/research/centers-institutes/evidence-based-practice-center/drug-effectiveness-review-project/upload/SGA_final-update-4-report_Nov-2013_version-2.pdf. Accessed May 23, 2017.
2 Meltzer HY, Bobo WV, Nuamah IF, . Efficacy and tolerability of oral paliperidone extended-release tablets in the treatment of acute schizophrenia: pooled data from three 6-week, placebo-controlled studies. J Clin Psychiatry. 2008 May;69(5):817–29. PMID: 18466043.18466043
3 Rouillon F, Eriksson L, Burba B, . Functional recovery results from the risperidone long-acting injectable versus quetiapine relapse prevention trial (ConstaTRE). Acta Neuropsychiatr. 2013;25(5):297–306. doi: 10.1017/neu.2013.7 PMID: 25287730.25287730
4 Naber D, Peuskens J, Schwarzmann N, . Subjective well-being in schizophrenia: a randomised controlled open-label 12-month non-inferiority study comparing quetiapine XR with risperidone (RECOVER). Eur Neuropsychopharmacol. 2013 Oct;23(10):1257–69. doi: 10.1016/j.euroneuro.2013.07.006. PMID: 23953270.23953270
5 Ishigooka J, Nakamura J, Fujii Y, . Efficacy and safety of aripiprazole once-monthly in Asian patients with schizophrenia: a multicenter, randomized, double-blind, non-inferiority study versus oral aripiprazole. Schizophr Res. 2015 Feb;161(2–3):421–8. doi: 10.1016/j.schres.2014.12.013. PMID: 25556976.25556976
6 Naber D, Hansen K, Forray C, . Qualify: a randomized head-to-head study of aripiprazole once-monthly and paliperidone palmitate in the treatment of schizophrenia. Schizophr Res. 2015;168(1–2):498–504. PMID: 2623224126232241
7 Schoemaker J, Naber D, Vrijland P, . Long-term assessment of asenapine vs. olanzapine in patients with schizophrenia or schizoaffective disorder. Pharmacopsychiatry. 2010 Jun;43(4):138–46. doi: 10.1055/s-0030-1248313. PMID: 20205074.20205074
8 Buchanan RW, Panagides J, Zhao J, . Asenapine versus olanzapine in people with persistent negative symptoms of schizophrenia. J Clin Psychopharmacol. 2012 Feb;32(1):36–45. doi: 10.1097/JCP.0b013e31823f880a. PMID: 22198451.22198451
9 Fleischhacker W, Gopal S, Lane R, . A randomized trial of paliperidone palmitate and risperidone long-acting injectable in schizophrenia. Int J Neuropsychopharmacology. 2012 Feb;15(1):107–18. doi: 10.1017/S1461145711001076. PMID: 21777507.21777507
10 Li H, Rui Q, Ning X, . A comparative study of paliperidone palmitate and risperidone long-acting injectable therapy in schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2011 Jun 1;35(4):1002–8. doi: 10.1016/j.pnpbp.2011.02.001. PMID: 21315787.21315787
11 AstraZeneca. A multicenter, open-label, flexible-dose, parallel-group evaluation of the cataractogenic potential of quetiapine fumarate (Seroquel) and risperidone (Risperdal) in the Long-term treatment of patients with schizophrenia or schizoaffective disorder [CLEARS]. Clinical Study Report Synopsis. 2010.
12 Mullen J, Jibson MD, Sweitzer D. A comparison of the relative safety, efficacy, and tolerability of quetiapine and risperidone in outpatients with schizophrenia and other psychotic disorders: the quetiapine experience with safety and tolerability (QUEST) study. Clin Ther. 2001;23(11):1839–54. PMID: 11768836.11768836
13 Leucht S, Cipriani A, Spineli L, . Comparative efficacy and tolerability of 15 antipsychotic drugs in schizophrenia: a multiple-treatments meta-analysis. Lancet. 2013 Sep 14;382(9896):951–62. doi: 10.1016/S0140-6736(13)60733-3. PMID: 23810019.23810019
14 Samara MT, Dold M, Gianatsi M, . Efficacy, acceptability, and tolerability of antipsychotics in treatment-resistant schizophrenia: a network meta-analysis. JAMA Psychiatry. 2016 Mar;73(3):199–210. doi: 10.1001/jamapsychiatry.2015.2955. PMID: 26842482.26842482
15 Citrome L, Ota A, Nagamizu K, . The effect of brexpiprazole (OPC-34712) and aripiprazole in adult patients with acute schizophrenia: results from a randomized, exploratory study. Int Clin Psychopharmacol. 2016 Jul;31(4):192–201. doi: 10.1097/yic.0000000000000123. PMID: 26963842.26963842
16 Schering Plough. (Study 041022) A multicenter, randomized, double-blind, flexible-dose, 6-week trial of the efficacy and safety of asenapine compared with placebo using olanzapine positive control in subjects with an acute exacerbation of schizophrenia. 2006.
17 Schoemaker J, Stet L, Vrijland P, . Long-term efficacy and safety of asenapine or olanzapine in patients with schizophrenia or schizoaffective disorder: an extension study. Pharmacopsychiatry. 2012 Jul;45(5):196–203. doi: 10.1055/s-0031-1301310. PMID: 22454251.22454251
18 Potkin SG, Gharabawi GM, Greenspan AJ, . A double-blind comparison of risperidone, quetiapine and placebo in patients with schizophrenia experiencing an acute exacerbation requiring hospitalization. Schizophr Res. 2006 Jul;85(1–3):254–65. PMID: 16797162.16797162
19 Zhong KX, Sweitzer DE, Hamer RM, . Comparison of quetiapine and risperidone in the treatment of schizophrenia: a randomized, double-blind, flexible-dose, 8-week study. J Clin Psychiatry. 2006 Jul;67(7):1093–103. PMID: 16889453.16889453
20 McEvoy JP, Lieberman JA, Perkins DO, . Efficacy and tolerability of olanzapine, quetiapine, and risperidone in the treatment of early psychosis: a randomized, double-blind 52-week comparison. Am J Psychiatry. 2007 Jul;164(7):1050–60. PMID: 17606657.17606657
21 Newcomer JW, Ratner RE, Eriksson JW, . A 24-week, multicenter, open-label, randomized study to compare changes in glucose metabolism in patients with schizophrenia receiving treatment with olanzapine, quetiapine, or risperidone. J Clin Psychiatry. 2009 Apr;70(4):487–99. PMID: 19358783.19358783
22 Stroup TS, Lieberman JA, McEvoy JP, . Effectiveness of olanzapine, quetiapine, and risperidone in patients with chronic schizophrenia after discontinuing perphenazine: a CATIE study. Am J Psychiatry. 2007 Mar;164(3):415–27. PMID: 17329466.17329466
23 Jeste DV, Barak Y, Madhusoodanan S, . International multisite double-blind trial of the atypical antipsychotics risperidone and olanzapine in 175 elderly patients with chronic schizophrenia. Am J Geriatr Psychiatry. 2003;11(6):638–47. PMID: 14609804.14609804
24 Alvarez E, Ciudad A, Olivares JM, . A randomized, 1-year follow-up study of olanzapine and risperidone in the treatment of negative symptoms in outpatients with schizophrenia. J Clin Psychopharmacol. 2006 Jun;26(3):238–49. PMID: 16702888.16702888
25 Li YM, Zhao JP, Ou JJ, . Efficacy and tolerability of ziprasidone vs. olanzapine in naive first-episode schizophrenia: a 6-week, randomized, open-label, flexible-dose study. Pharmacopsychiatry. 2012 Jul;45(5):177–81. doi: 10.1055/s-0031-1299769. PMID: 22290206.22290206
26 Simpson GM, Glick ID, Weiden PJ, . Randomized, controlled, double-blind multicenter comparison of the efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. Am J Psychiatry. 2004 Oct;161(10):1837–47. doi: 10.1176/ajp.161.10.1837 PMID: 15465981.15465981
27 Grootens KP, van Veelen NMJ, Peuskens J, . Ziprasidone vs olanzapine in recent-onset schizophrenia and schizoaffective disorder: results of an 8-week double-blind randomized controlled trial. Schizophr Res. 2011 Mar;37(2):352–61. doi: 10.1093/schbul/sbp037. PMID: 19542525.19542525
28 Breier A, . Olanzapine versus ziprasidone: results of a 28-week double-blind study in patients with schizophrenia. Am J Psychiatry. 2005 Oct;162:1879–87. doi: 10.1176/appi.ajp.162.10.1879 PMID: 16199834.16199834
29 Simpson G, . Six-month, blinded, multicenter continuation study of ziprasidone versus olanzapine in schizophrenia. Am J Psychiatry. 2005 Aug;162:1535–8. doi: 10.1176/appi.ajp.162.8.1535 PMID: 16055779.16055779
30 Abou-Setta AM, Mousavi SS, Spooner C, . First-generation versus second-generation antipsychotics in adults: comparative effectiveness. Comparative effectiveness review No. 63. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-200-10021.) AHRQ Publication No. 12-EHC054-EF. Rockville, MD: Agency for Healthcare Research and Quality: 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm Accessed April 22, 2017. PMID: 2303527523035275.
31 Marshall M, Lockwood A. Assertive community treatment for people with severe mental disorders. Cochrane Database Syst Rev. 2000a(2):Cd001089. doi: 10.1002/14651858.cd001089. PMID: 10796415.10796415
32 Sytema S, Wunderink L, Bloemers W, . Assertive community treatment in the Netherlands: a randomized controlled trial. Acta Psychiatr Scand. 2007 Aug;116(2):105–12. PMID: 17650271.17650271
33 Jones C, Hacker D, Cormac I, . Cognitive behavioural therapy versus other psychosocial treatments for schizophrenia. Cochrane Database Syst Rev. 2012 Apr 18(4):Cd008712. doi: 10.1002/14651858.CD008712.pub2. PMID: 22513966.22513966
34 Barrowclough C, Haddock G, Lobban F, . Group cognitive-behavioural therapy for schizophrenia. Randomised controlled trial. Br J Psychiatry. 2006 Dec;189:527–32. PMID: 17139037.17139037
35 Lincoln TM, Ziegler M, Mehl S, . Moving from efficacy to effectiveness in cognitive behavioral therapy for psychosis: a randomized clinical practice trial. J Consult Clin Psychol. 2012 Aug;80(4):674–86. doi: 10.1037/a0028665. PMID: 22663901.22663901
36 Sellwood W, Barrowclough C, Tarrier N, . Needs-based cognitive-behavioural family intervention for carers of patients suffering from schizophrenia: 12-month follow-up. Acta Psychiatr Scand. 2001 Nov;104(5):346–55. PMID: 11722315.11722315
37 van der Gaag M, Stant AD, Wolters KJ, . Cognitive-behavioural therapy for persistent and recurrent psychosis in people with schizophrenia-spectrum disorder: cost-effectiveness analysis. Br J Psychiatry. 2011 Jan;198(1):59–65, sup 1. doi: 10.1192/bjp.bp.109.071522. PMID: 21200078.21200078
38 Zimmer M, Duncan AV, Laitano D, . A twelve-week randomized controlled study of the cognitive-behavioral integrated psychological therapy program: positive effect on the social functioning of schizophrenic patients. Rev Bras Psiquiatr. 2007 Jun;29(2):140–7. PMID: 17650536.17650536
39 Garety PA, Fowler DG, Freeman D, . Cognitive--behavioural therapy and family intervention for relapse prevention and symptom reduction in psychosis: randomised controlled trial. Br J Psychiatry. 2008 Jun;192(6):412–23. doi: 10.1192/bjp.bp.107.043570. PMID: 18515890.18515890
40 Grant PM, Huh GA, Perivoliotis D, . Randomized trial to evaluate the efficacy of cognitive therapy for low-functioning patients with schizophrenia. Arch Gen Psychiatry. 2012 Feb;69(2):121–7. doi: 10.1001/archgenpsychiatry.2011.129. PMID: 21969420.21969420
41 Velligan DI, Tai S, Roberts DL, . A randomized controlled trial comparing cognitive behavior therapy, cognitive adaptation training, their combination and treatment as usual in chronic schizophrenia. Schizophr Bull. 2015 May;41(3):597–603. doi: 10.1093/schbul/sbu127. PMID: 25193976.25193976
42 Granholm E, McQuaid JR, McClure FS, . A randomized, controlled trial of cognitive behavioral social skills training for middle-aged and older outpatients with chronic schizophrenia. Am J Psychiatry. 2005 Mar;162(3):520–9. PMID: 15741469.15741469
43 Lysaker PH, Davis LW, Bryson GJ, . Effects of cognitive behavioral therapy on work outcomes in vocational rehabilitation for participants with schizophrenia spectrum disorders. Schizophr Res. 2009 Feb;107(2–3):186–91. doi: 10.1016/j.schres.2008.10.018. PMID: 19046856.19046856
44 Malik N, Kingdon D, Pelton J, . Effectiveness of brief cognitive-behavioral therapy for schizophrenia delivered by mental health nurses: relapse and recovery at 24 months. J Clin Psychiatry. 2009 Feb;70(2):201–7. PMID: 19210949.19210949
45 Freeman D, Dunn G, Startup H, . Effects of cognitive behaviour therapy for worry on persecutory delusions in patients with psychosis (WIT): a parallel, single-blind, randomised controlled trial with a mediation analysis. Lancet Psychiatry. 2015;2(4):305–13. PMID: 26360083.26360083
46 Lewis S, Tarrier N, Haddock G, . Randomised controlled trial of cognitive-behavioural therapy in early schizophrenia: acute-phase outcomes. Br J Psychiatry Suppl. 2002 Sep;43:s91–7. PMID: 12271807.12271807
47 Jauhar S, McKenna PJ, Radua J, . Cognitive-behavioural therapy for the symptoms of schizophrenia: systematic review and meta-analysis with examination of potential bias. Br J Psychiatry. 2014 Jan;204(1):20–9. doi: 10.1192/bjp.bp.112.116285. PMID: 24385461.24385461
48 Velthorst E, Koeter M, van der Gaag M, . Adapted cognitive-behavioural therapy required for targeting negative symptoms in schizophrenia: meta-analysis and meta-regression. Psychol Med. 2015 Feb;45(3):453–65. doi: 10.1017/S0033291714001147. PMID: 24993642.24993642
49 Gumley A, O’Grady M, McNay L, . Early intervention for relapse in schizophrenia: results of a 12-month randomized controlled trial of cognitive behavioural therapy. Psychol Med. 2003 Apr;33(3):419–31. PMID: 12701663.12701663
50 Sensky T, Turkington D, Kingdon D, . A randomized controlled trial of cognitive-behavioral therapy for persistent symptoms in schizophrenia resistant to medication. Arch Gen Psychiatry. 2000 Feb;57(2):165–72. PMID: 10665619.10665619
51 Tarrier N, Wittkowski A, Kinney C, . Durability of the effects of cognitive-behavioural therapy in the treatment of chronic schizophrenia: 12-month follow-up. Br J Psychiatry. 1999 Jun;174:500–4. doi: 10.1192/bjp.174.6.500. PMID: 10616627.10616627
52 Wykes T, Huddy V, Cellard C, . A meta-analysis of cognitive remediation for schizophrenia: methodology and effect sizes. Am J Psychiatry. 2011 May;168(5):472–85. doi: 10.1176/appi.ajp.2010.10060855. PMID: 21406461.21406461
53 Farreny A, Aguado J, Ochoa S, . REPYFLEC cognitive remediation group training in schizophrenia: looking for an integrative approach. Schizophr Res. 2012 Dec;142(1–3):137–44. doi: 10.1016/j.schres.2012.08.035. PMID: 23017827.23017827
54 Mueller DR, Schmidt SJ, Roder V. One-year randomized controlled trial and follow-up of integrated neurocognitive therapy for schizophrenia outpatients. Schizophr Bull. 2015 May;41(3):604–16. doi: 10.1093/schbul/sbu223. PMID: 25713462.25713462
55 Twamley EW, Vella L, Burton CZ, . Compensatory cognitive training for psychosis: effects in a randomized controlled trial. J Clin Psychiatry. 2012 Sep;73(9):1212–9. doi: 10.4088/JCP.12m07686. PMID: 22939029.22939029
56 Deste G, Barlati S, Cacciani P, . Persistence of effectiveness of cognitive remediation interventions in schizophrenia: a 1-year follow-up study. Schizophr Res. 2015 Feb;161(2–3):403–6. doi: 10.1016/j.schres.2014.12.004. PMID: 25533593.25533593
57 Cella M, Preti A, Edwards C, . Cognitive remediation for negative symptoms of schizophrenia: A network meta-analysis. Clin Psychol Rev. 2017 Mar;52:43–51. doi: 10.1016/j.cpr.2016.11.009. PMID: 27930934.27930934
58 Vita A, De Peri L, Barlati S, . Effectiveness of different modalities of cognitive remediation on symptomatological, neuropsychological, and functional outcome domains in schizophrenia: a prospective study in a real-world setting. Schizophr Res. 2011 Dec;133(1–3):223–31. doi: 10.1016/j.schres.2011.08.010. PMID: 21907544.21907544
59 Pharoah F, Mari J, Rathbone J, . Family intervention for schizophrenia. Cochrane Database Syst Rev. 2010 Dec 08(12):CD000088. doi: 10.1002/14651858.CD000088.pub2. PMID: 21154340.21154340
60 Lenior ME, Dingemans PM, Linszen DH, . Social functioning and the course of early-onset schizophrenia: five-year follow-up of a psychosocial intervention. Br J Psychiatry. 2001;179:53–8. PMID: 11435269.11435269
61 Mayoral F, Berrozpe A, de la Higuera J, . Efficacy of a family intervention program for prevention of hospitalization in patients with schizophrenia. A naturalistic multicenter controlled and randomized study in Spain. Rev Psiquiatr Salud Ment. 2015 Apr–Jun;8(2):83–91. doi: 10.1016/j.rpsm.2013.11.001. PMID: 25017624.25017624
62 Kopelowicz A, Zarate R, Wallace CJ, . The ability of multifamily groups to improve treatment adherence in Mexican Americans with schizophrenia. Arch Gen Psychiatry. 2012 Mar;69(3):265–73. doi: 10.1001/archgenpsychiatry.2011.135. PMID: 22393219.22393219
63 Valencia M, Rascon ML, Juarez F, . A psychosocial skills training approach in Mexican out-patients with schizophrenia. Psychol Med. 2007 Oct;37(10):1393–402. PMID: 17472761.17472761
64 Barrowclough C, Tarrier N, Lewis S, . Randomised controlled effectiveness trial of a needs-based psychosocial intervention service for carers of people with schizophrenia. Br J Psychiatry. 1999 Jun;174:505–11. PMID: 10616628.10616628
65 Marshall M, Gray A, Lockwood A, . Case management for people with severe mental disorders. Cochrane Database Syst Rev. 2000b(2):Cd000050. doi: 10.1002/14651858.cd000050. PMID: 10796288.10796288
66 Bjorkman T, Hansson L, Sandlund M. Outcome of case management based on the strengths model compared to standard care. A randomised controlled trial. Soc Psychiatry Psychiatr Epidemiol. 2002 Apr;37(4):147–52. PMID: 12027240.12027240
67 Zou H, Li Z, Nolan MT, . Self-management education interventions for persons with schizophrenia: a meta-analysis. Int J Ment Health Nurs. 2013 Jun;22(3):256–71. doi: 10.1111/j.1447-0349.2012.00863.x. PMID: 22882803.22882803
68 Pekkala E, Merinder L. Psychoeducation for schizophrenia. Cochrane Database Syst Rev. 2002(2):Cd002831. doi: 10.1002/14651858.cd002831. PMID: 12076455.12076455
69 Bartels SJ, Pratt SI, Mueser KT, . Long-term outcomes of a randomized trial of integrated skills training and preventive healthcare for older adults with serious mental illness. Am J Geriatr Psychiatry. 2014 Nov;22(11):1251–61. doi: 10.1016/j.jagp.2013.04.013. PMID: 23954039.23954039
70 Mueser KT, Pratt SI, Bartels SJ, . Randomized trial of social rehabilitation and integrated health care for older people with severe mental illness. J Consult Clin Psychol. 2010 Aug;78(4):561–73. doi: 10.1037/a0019629. PMID: 20658812.20658812
71 Valencia M, Fresan A, Juarez F, . The beneficial effects of combining pharmacological and psychosocial treatment on remission and functional outcome in outpatients with schizophrenia. J Psychiatr Res. 2013 Dec;47(12):1886–92. doi: 10.1016/j.jpsychires.2013.09.006. PMID: 24112947.24112947
72 Mueser KT, Clark RE, Haines M, . The Hartford study of supported employment for persons with severe mental illness. J Consult Clin Psychol. 2004 Jun;72(3):479–90. doi: 10.1037/0022-006x.72.3.479. PMID: 15279531.15279531
73 Cook JA, Leff HS, Blyler CR, . Results of a multisite randomized trial of supported employment interventions for individuals with severe mental illness. Arch Gen Psychiatry. 2005 May;62(5):505–12. PMID: 15867103.15867103
74 Cook JA, Blyler CR, Burke-Miller JK, . Effectiveness of supported employment for individuals with schizophrenia: results of a multi-site, randomized trial. Clin Schizophr Relat Psychoses. 2008;2(1):37–46.
75 Kinoshita Y, Furukawa TA, Kinoshita K, . Supported employment for adults with severe mental illness. Cochrane Database Syst Rev. 2013 Sep 13(9):Cd008297. doi: 10.1002/14651858.CD008297.pub2. PMID: 24030739.24030739
76 Buckley LA, Maayan N, Soares-Weiser K, . Supportive therapy for schizophrenia. Cochrane Database Syst Rev. 2015 Apr 14(4):Cd004716. doi: 10.1002/14651858.CD004716.pub4. PMID: 25871462.25871462
77 Marshall M, Rathbone J. Early intervention for psychosis. Cochrane Database Syst Rev. 2011 Jun 15(6):Cd004718. doi: 10.1002/14651858.CD004718.pub3. PMID: 21678345.21678345
78 Bertelsen M, Jeppesen P, Petersen L, . Course of illness in a sample of 265 patients with first-episode psychosis—five-year follow-up of the Danish OPUS trial. Schizophr Res. 2009;107(2–3):173–8. doi: 10.1016/j.schres.2008.09.018. PMID: 18945593.18945593
79 Guo X, Zhai J, Liu Z, . Effect of antipsychotic medication alone vs combined with psychosocial intervention on outcomes of early-stage schizophrenia: a randomized, 1-year study. Arch Gen Psychiatry. 2010 Sep;67(9):895–904. doi: 10.1001/archgenpsychiatry.2010.105. PMID: 20819983.20819983
80 Garety PA, Craig TK, Dunn G, . Specialised care for early psychosis: symptoms, social functioning and patient satisfaction: randomised controlled trial. Br J Psychiatry. 2006 Jan;188:37–45. doi: 10.1192/bjp.bp.104.007286. PMID: 16388068.16388068
81 Kane JM, Schooler NR, Marcy P, . The RAISE early treatment program for first-episode psychosis: background, rationale, and study design. J Clin Psychiatry. 2015 Mar;76(3):240–6. doi: 10.4088/JCP.14m09289. PMID: 25830446.25830446
82 Kane JM, Robinson DG, Schooler NR, . Comprehensive versus usual community care for first-episode psychosis: 2-year outcomes from the NIMH RAISE early treatment program. Am J Psychiatry. 2016 Apr 1;173(4):362–72. doi: 10.1176/appi.ajp.2015.15050632. PMID: 26481174.26481174
83 Craig TK, Garety P, Power P, . The Lambeth Early Onset (LEO) team: randomised controlled trial of the effectiveness of specialised care for early psychosis. BMJ. 2004 Nov 6;329(7474):1067. doi: 10.1136/bmj.38246.594873.7C. PMID: 15485934.15485934
84 Hunt GE, Siegfried N, Morley K, . Psychosocial interventions for people with both severe mental illness and substance misuse. Cochrane Database Syst Rev. 2013 Oct 03(10):Cd001088. doi: 10.1002/14651858.CD001088.pub3. PMID: 24092525.24092525