# Appendix G Forest Plots for Pooled Analyses and Matrixes of Results for Network Meta-Analyses

Appendix Table G-1a SGA versus SGA network analysis of response (odds ratio, 95% confidence interval)

ARI | 1.05 (0.35–3.02) | 0.97 (0.57–1.68) | 0.57 (0.20–1.63) | 1.16 (0.56–2.58) | 0.70 (0.35–1.45) | 0.67 (0.45–1.02) | 1.11 (0.65–2.00) | 1.15 (0.77–1.78) | 0.81 (0.58–1.16) | 0.98 (0.59–1.58)
0.96 (0.33–2.86) | ARI LAI-1 | 0.93 (0.28–3.13) | 0.55 (0.13–2.44) | 1.12 (0.30–4.26) | 0.67 (0.25–1.89) | 0.65 (0.18–2.26) | 1.06 (0.32–3.78) | 1.08 (0.35–3.57) | 0.78 (0.25–2.52) | 0.93 (0.28–3.16)
1.03 (0.59–1.76) | 1.08 (0.32–3.53) | ASE | 0.59 (0.18–1.81) | 1.20 (0.54–2.82) | 0.72 (0.33–1.64) | 0.69 (0.41–1.20) | 1.15 (0.57–2.32) | 1.18 (0.69–2.09) | 0.83 (0.49–1.43) | 1.01 (0.54–1.86)
1.75 (0.61–5.05) | 1.83 (0.41–7.68) | 1.69 (0.55–5.44) | BRE | 2.03 (0.62–7.08) | 1.23 (0.33–4.52) | 1.18 (0.36–3.90) | 1.94 (0.58–6.64) | 1.99 (0.67–6.25) | 1.43 (0.46–4.46) | 1.70 (0.53–5.51)
0.86 (0.39–1.79) | 0.90 (0.24–3.31) | 0.83 (0.36–1.87) | 0.49 (0.14–1.63) | CAR | 0.59 (0.23–1.56) | 0.58 (0.25–1.26) | 0.95 (0.39–2.36) | 0.98 (0.48–2.04) | 0.70 (0.33–1.44) | 0.84 (0.36–1.87)
1.43 (0.69–2.88) | 1.50 (0.53–4.06) | 1.38 (0.61–3.05) | 0.82 (0.22–3.00) | 1.69 (0.65–4.38) | CLO | 0.96 (0.46–1.96) | 1.58 (0.69–3.71) | 1.63 (0.84–3.36) | 1.16 (0.61–2.24) | 1.39 (0.63–2.94)
1.49 (0.98–2.22) | 1.54 (0.45–5.48) | 1.44 (0.83–2.47) | 0.85 (0.26–2.79) | 1.74 (0.79–3.94) | 1.04 (0.51–2.19) | OLA | 1.65 (0.95–2.95) | 1.71 (1.11–2.68) | 1.21 (0.94–1.59) | 1.45 (0.94–2.25)
0.90 (0.50–1.54) | 0.94 (0.26–3.12) | 0.87 (0.43–1.75) | 0.52 (0.15–1.74) | 1.05 (0.42–2.56) | 0.63 (0.27–1.45) | 0.61 (0.34–1.05) | PAL | 1.03 (0.55–1.94) | 0.73 (0.42–1.27) | 0.88 (0.44–1.71)
0.87 (0.56–1.29) | 0.92 (0.28–2.85) | 0.85 (0.48–1.46) | 0.50 (0.16–1.49) | 1.02 (0.49–2.09) | 0.61 (0.30–1.19) | 0.59 (0.37–0.90) | 0.97 (0.52–1.81) | QUE | 0.71 (0.50–0.99) | 0.85 (0.50–1.39)
1.23 (0.86–1.71) | 1.29 (0.40–4.08) | 1.20 (0.70–2.02) | 0.70 (0.22–2.16) | 1.43 (0.69–3.00) | 0.86 (0.45–1.65) | 0.83 (0.63–1.07) | 1.36 (0.79–2.40) | 1.41 (1.01–2.00) | RIS | 1.20 (0.78–1.82)
1.03 (0.63–1.70) | 1.08 (0.32–3.59) | 0.99 (0.54–1.85) | 0.59 (0.18–1.90) | 1.19 (0.53–2.81) | 0.72 (0.34–1.58) | 0.69 (0.44–1.07) | 1.14 (0.59–2.27) | 1.18 (0.72–2.01) | 0.84 (0.55–1.28) | ZIP

Drugs are reported in alphabetical order. Comparisons between treatments should be read from left to right and the estimate in each cell represents comparison between the row-defining treatment and the column-defining treatment. Odds ratios (ORs) higher than 1 favor the column-defining treatment, meaning less withdrawal in the column-defining treatment; and ORs less than 1 favor the row-defining treatment, meaning less withdrawal in the row-defining treatment. For example, the OR for comparing QUE (row-defining treatment) vs. RIS (column-defining treatment) is 0.71 (95% CrI 0.50 to 0.99), which means that QUE has lower odds of response and the comparison favors RIS, which has greater response. Each comparison is represented twice in the table, for example, for two treatments A and B, once with A versus B and once with B versus A (i.e. the reciprocal OR). For the example above, the OR for comparing RIS (now the row-defining treatment) vs. QUE (now the column-defining treatment) is 0.1.41 (95% CrI 1.01 to 2.00), which means that RIS has a higher odds of response and again, it means that the comparison favors RIS, which has greater response. Significant results are in bold.

ARI = aripiprazole- ASE = asenapine- BRE = brepiprazole- CAR = cariprazine- CLO=clozapine- ILO = iloperidone- LUR = lurasidone- OLA = olanzapine. PAL=paliperidone, QUE=quetiapine, RIS=risperidone- ZIP=ziprasidone. LAI = long-acting injection; 1 = once monthly- 3 – every 3 months.

Appendix Table G1b Numbers of studies per comparison contributing to network meta-analysis of response for SGAs versus SGAs

Comparison | No. Studies
Aripiprazole : Brexipiprazole | 1
Aripiprazole : Olanzapine | 3
Aripiprazole : Quetiapine IR | 1
Aripiprazole : Risperidone | 3
Aripiprazole Monthly LAI : Aripiprazole | 1
Asenapine : Olanzapine | 3
Cariprazine : Risperidone | 1
Clozapine : Olanzapine | 3
Clozapine : Risperidone | 4
Paliperidone : Aripiprazole | 1
Paliperidone : Olanzapine | 1
Paliperidone Monthly LAI : Paliperidone 3-month LAI | 1
Paliperidone Monthly LAI : Risperidone LAI | 3
Quetiapine IR : Olanzapine | 5
Quetiapine IR : Risperidone | 9
Risperidone : Olanzapine | 16
Ziprasidone : Aripiprazole | 1
Ziprasidone : Olanzapine | 3
Ziprasidone : Quetiapine IR | 1
Ziprasidone : Risperidone | 1

Appendix Table G-1c SGAs versus SGAs meta-regression results for response

Meta-regression variables | OR (95% CI)
OR for duration | 1.15 (0.57 to 2.07)
Drug dose: Low versus Medium | 1.00 (0.53 to 1.78)
Drug dose: High versus Medium | 1.02 (0.99 to 1.04)
Response definition category B, as compared to category A | 0.94 (0.67 to 1.27)
Response definition category C, as compared to category A | 0.94 (0.63 to 1.34)
Treatment Resistant | 0.84 (0.44 to 1.49)
First Episode | 1.29 (0.82 to 2.0)

Appendix Table G-2a SGA versus SGA network meta-analysis of withdrawals from study due to adverse events (odds ratio, 95% confidence interval)

ARI | 0.90 (0.31–2.69) | 0.83 (0.54–1.25) | 0.48 (0.02–5.34) | 1.08 (0.56–2.12) | 0.43 (0.21–0.88) | 1.25 (0.58–2.76) | 0.62 (0.37–1.08) | 1.11 (0.82–1.48) | 0.69 (0.21–2.40) | 0.72 (0.38–1.30) | 0.80 (0.35–1.99) | 0.73 (0.21–2.78) | 0.32 (0.04–1.75) | 0.68 (0.48–1.01) | 0.80 (0.57–1.13) | 1.60 (0.85–3.05) | 0.64 (0.44–0.94)
1.12 (0.37–3.19) | ARI LAI-1 | 0.92 (0.28–2.80) | 0.52 (0.02–7.79) | 1.21 (0.34–3.98) | 0.49 (0.19–1.16) | 1.43 (0.38–5.04) | 0.71 (0.21–2.19) | 1.24 (0.37–3.76) | 0.78 (0.15–3.92) | 0.81 (0.21–2.94) | 0.89 (0.42–1.94) | 0.82 (0.23–2.86) | 0.36 (0.03–2.76) | 0.77 (0.25–2.28) | 0.89 (0.28–2.59) | 1.77 (0.57–5.56) | 0.72 (0.23–2.16)
1.21 (0.80–1.85) | 1.09 (0.36–3.59) | ASE | 0.58 (0.02–6.68) | 1.32 (0.65–2.62) | 0.52 (0.25–1.10) | 1.51 (0.67–3.49) | 0.75 (0.43–1.36) | 1.34 (0.95–1.87) | 0.85 (0.25–2.88) | 0.88 (0.44–1.63) | 0.96 (0.40–2.54) | 0.90 (0.24–3.64) | 0.39 (0.04–2.22) | 0.83 (0.54–1.28) | 0.97 (0.65–1.47) | 1.93 (0.96–4.08) | 0.78 (0.51–1.24)
2.08 (0.19–57.77) | 1.92 (0.13–62.00) | 1.72 (0.15–48.12) | BRE | 2.34 (0.19–62.11) | 0.89 (0.07–26.93) | 2.57 (0.21–78.40) | 1.27 (0.11–36.14) | 2.29 (0.20–66.19) | 1.50 (0.09–51.64) | 1.52 (0.13–44.95) | 1.71 (0.13–53.38) | 1.60 (0.10–58.93) | 0.68 (0.03–30.54) | 1.42 (0.12–39.94) | 1.65 (0.15–46.54) | 3.32 (0.28–100.40) | 1.33 (0.12–37.67)
0.92 (0.47–1.79) | 0.83 (0.25–2.96) | 0.76 (0.38–1.54) | 0.43 (0.02–5.42) | CAR | 0.40 (0.17–0.95) | 1.15 (0.46–2.88) | 0.58 (0.28–1.18) | 1.02 (0.51–1.99) | 0.65 (0.18–2.32) | 0.66 (0.28–1.50) | 0.73 (0.29–2.06) | 0.67 (0.18–2.75) | 0.30 (0.03–1.73) | 0.63 (0.35–1.15) | 0.74 (0.41–1.33) | 1.47 (0.66–3.32) | 0.60 (0.31–1.16)
2.32 (1.13–4.71) | 2.05 (0.87–5.26) | 1.91 (0.91–3.96) | 1.12 (0.04–13.61) | 2.52 (1.06–5.90) | CLO | 2.93 (1.10–7.54) | 1.46 (0.67–3.18) | 2.54 (1.27–5.21) | 1.60 (0.41–6.43) | 1.66 (0.64–4.20) | 1.85 (0.80–4.37) | 1.71 (0.46–6.38) | 0.75 (0.07–4.66) | 1.58 (0.81–3.08) | 1.84 (0.96–3.58) | 3.66 (1.42–10.05) | 1.50 (0.76–2.91)
0.80 (0.36–1.73) | 0.70 (0.20–2.65) | 0.66 (0.29–1.49) | 0.39 (0.01–4.68) | 0.87 (0.35–2.17) | 0.34 (0.13–0.91) | ILO | 0.50 (0.22–1.16) | 0.89 (0.41–1.88) | 0.55 (0.14–2.24) | 0.57 (0.22–1.43) | 0.63 (0.21–2.06) | 0.58 (0.13–2.85) | 0.25 (0.02–1.60) | 0.54 (0.26–1.16) | 0.64 (0.31–1.27) | 1.27 (0.47–3.40) | 0.51 (0.24–1.13)
1.61 (0.93–2.69) | 1.42 (0.46–4.87) | 1.33 (0.74–2.34) | 0.78 (0.03–8.97) | 1.73 (0.85–3.54) | 0.68 (0.31–1.50) | 2.01 (0.86–4.57) | LUR | 1.77 (1.06–2.90) | 1.11 (0.32–3.93) | 1.15 (0.53–2.39) | 1.27 (0.51–3.50) | 1.17 (0.30–4.71) | 0.52 (0.06–3.02) | 1.09 (0.67–1.79) | 1.28 (0.79–2.03) | 2.55 (1.19–5.62) | 1.03 (0.63–1.68)
0.90 (0.68–1.23) | 0.81 (0.27–2.71) | 0.75 (0.54–1.05) | 0.44 (0.02–4.92) | 0.98 (0.50–1.95) | 0.39 (0.19–0.79) | 1.13 (0.53–2.48) | 0.57 (0.34–0.94) | OLA | 0.63 (0.19–2.18) | 0.65 (0.36–1.14) | 0.72 (0.29–1.95) | 0.66 (0.18–2.74) | 0.29 (0.03–1.61) | 0.62 (0.44–0.87) | 0.72 (0.55–0.96) | 1.44 (0.72–2.98) | 0.58 (0.41–0.82)
1.44 (0.42–4.92) | 1.28 (0.26–6.56) | 1.19 (0.35–4.04) | 0.67 (0.02–10.97) | 1.54 (0.43–5.67) | 0.63 (0.16–2.43) | 1.81 (0.45–7.35) | 0.90 (0.26–3.15) | 1.59 (0.46–5.34) | OLA LAI | 1.03 (0.27–3.81) | 1.14 (0.28–4.90) | 1.04 (0.20–6.14) | 0.46 (0.04–3.89) | 0.98 (0.29–3.38) | 1.15 (0.33–4.00) | 2.28 (0.66–8.33) | 0.93 (0.27–3.15)
1.38 (0.77–2.65) | 1.24 (0.34–4.78) | 1.14 (0.62–2.26) | 0.66 (0.02–8.01) | 1.51 (0.67–3.62) | 0.60 (0.24–1.57) | 1.74 (0.70–4.56) | 0.87 (0.42–1.88) | 1.54 (0.88–2.77) | 0.97 (0.26–3.65) | PAL | 1.11 (0.38–3.40) | 1.01 (0.24–4.60) | 0.46 (0.05–2.79) | 0.95 (0.51–1.82) | 1.11 (0.60–2.09) | 2.20 (0.96–5.38) | 0.89 (0.48–1.73)
1.25 (0.50–2.90) | 1.13 (0.52–2.41) | 1.04 (0.40–2.50) | 0.59 (0.02–7.96) | 1.37 (0.49–3.41) | 0.54 (0.23–1.25) | 1.59 (0.49–4.76) | 0.79 (0.29–1.99) | 1.39 (0.51–3.43) | 0.88 (0.21–3.54) | 0.91 (0.30–2.62) | PAL LAI | 0.92 (0.36–2.28) | 0.41 (0.04–2.57) | 0.86 (0.36–1.95) | 1.01 (0.40–2.32) | 1.99 (1.00–3.89) | 0.81 (0.32–1.92)
1.37 (0.36–4.80) | 1.22 (0.35–4.31) | 1.12 (0.28–4.19) | 0.63 (0.02–10.31) | 1.50 (0.36–5.65) | 0.59 (0.16–2.16) | 1.73 (0.35–7.58) | 0.85 (0.21–3.32) | 1.51 (0.37–5.71) | 0.96 (0.16–5.01) | 0.99 (0.22–4.26) | 1.09 (0.44–2.77) | PAL LAI-3 | 0.43 (0.03–3.66) | 0.93 (0.25–3.35) | 1.09 (0.27–4.05) | 2.18 (0.69–6.83) | 0.88 (0.23–3.20)
3.13 (0.57–28.00) | 2.80 (0.36–34.90) | 2.56 (0.45–23.78) | 1.48 (0.03–36.92) | 3.32 (0.58–32.31) | 1.34 (0.22–13.96) | 3.93 (0.63–41.77) | 1.94 (0.33–18.04) | 3.40 (0.62–32.84) | 2.17 (0.26–24.49) | 2.19 (0.36–22.09) | 2.46 (0.39–28.03) | 2.30 (0.27–31.13) | QUE ER | 2.10 (0.39–20.33) | 2.43 (0.47–23.59) | 4.83 (0.82–47.58) | 1.97 (0.36–18.35)
1.47 (0.99–2.10) | 1.30 (0.44–4.04) | 1.21 (0.78–1.85) | 0.70 (0.03–8.16) | 1.59 (0.87–2.89) | 0.63 (0.33–1.23) | 1.84 (0.87–3.82) | 0.92 (0.56–1.50) | 1.62 (1.15–2.26) | 1.02 (0.30–3.44) | 1.05 (0.55–1.97) | 1.17 (0.51–2.81) | 1.07 (0.30–4.06) | 0.48 (0.05–2.61) | QUE | 1.17 (0.89–1.49) | 2.33 (1.24–4.46) | 0.94 (0.66–1.33)
1.26 (0.89–1.77) | 1.12 (0.39–3.53) | 1.04 (0.68–1.54) | 0.61 (0.02–6.63) | 1.35 (0.75–2.45) | 0.54 (0.28–1.04) | 1.57 (0.79–3.24) | 0.78 (0.49–1.26) | 1.39 (1.04–1.81) | 0.87 (0.25–3.08) | 0.91 (0.48–1.68) | 0.99 (0.43–2.52) | 0.92 (0.25–3.67) | 0.41 (0.04–2.16) | 0.85 (0.67–1.13) | RIS | 1.99 (1.01–4.07) | 0.81 (0.58–1.11)
0.63 (0.33–1.17) | 0.57 (0.18–1.74) | 0.52 (0.25–1.04) | 0.30 (0.01–3.54) | 0.68 (0.30–1.52) | 0.27 (0.10–0.71) | 0.79 (0.29–2.12) | 0.39 (0.18–0.84) | 0.70 (0.34–1.40) | 0.44 (0.12–1.53) | 0.45 (0.19–1.04) | 0.50 (0.26–1.00) | 0.46 (0.15–1.45) | 0.21 (0.02–1.22) | 0.43 (0.22–0.81) | 0.50 (0.25–0.99) | RIS LAI | 0.40 (0.20–0.82)
1.55 (1.06–2.26) | 1.39 (0.46–4.44) | 1.28 (0.81–1.98) | 0.75 (0.03–8.36) | 1.68 (0.86–3.19) | 0.67 (0.34–1.31) | 1.95 (0.89–4.18) | 0.97 (0.59–1.59) | 1.72 (1.22–2.42) | 1.08 (0.32–3.77) | 1.12 (0.58–2.09) | 1.24 (0.52–3.10) | 1.14 (0.31–4.44) | 0.51 (0.05–2.80) | 1.06 (0.75–1.52) | 1.24 (0.90–1.73) | 2.47 (1.23–5.08) | ZIP

Drugs are reported in alphabetical order. Comparisons between treatments should be read from left to right and the estimate in each cell represents comparison between the row-defining treatment and the column-defining treatment. Odds ratios (ORs) higher than 1 favor the column-defining treatment, meaning less withdrawal in the column-defining treatment; and ORs less than 1 favor the row-defining treatment, meaning less withdrawal in the row-defining treatment. For example, the OR for comparing LUR (row-defining treatment) vs. OLA (column-defining treatment) is 1.77 (95% CrI 1.06 to 2.90), which means that LUR has higher odds of withdrawal and the comparison favors OLA, which has less withdrawal. Each comparison is represented twice in the table, for example, for two treatments A and B, once with A versus B and once with B versus A (i.e. the reciprocal OR). For the example above, the OR for comparing OLA (now the row-defining treatment) vs. LUR (now the column-defining treatment) is 0.57 (95% CrI 0.34 to 0.94), which means that OLA has a lower odds of withdrawal and again, it means that the comparison favors OLA, which has less withdrawal. Significant results are in bold.

ARI = aripiprazole- ASE = asenapine- BRE = brepiprazole- CAR = cariprazine- CLO=clozapine- ILO = iloperidone- LUR = lurasidone- OLA = olanzapine. PAL=paliperidone, QUE=quetiapine, RIS=risperidone- ZIP=ziprasidone. LAI = long-acting injection; 1 = once monthly- 3 – every 3 months.

Appendix Table G-2b SGA versus SGA: numbers of studies per comparison contributing to network meta-analysis of withdrawals due to adverse events

Comparison | No. of studies
Aripiprazole : Brexipiprazole | 1
Aripiprazole : Olanzapine | 9
Aripiprazole : Quetiapine IR | 3
Aripiprazole : Risperidone | 6
Aripiprazole : Risperidone LAI | 1
Aripiprazole : Ziprasidone | 3
Aripiprazole Monthly LAI : Aripiprazole | 2
Asenapine : Olanzapine | 6
Asenapine : Risperidone | 1
Cariprazine : Risperidone | 2
Clozapine : Olanzapine | 9
Clozapine : Risperidone | 9
Iloperidone : Risperidone | 2
Lurasidone : Olanzapine | 1
Lurasidone : Risperidone | 1
Lurasidone : Ziprasidone | 1
Olanzapine LAI : Olanzapine | 1
Paliperidone : Aripiprazole | 2
Paliperidone : Olanzapine | 3
Paliperidone : Risperidone | 1
Paliperidone : Ziprasidone | 1
Paliperidone Monthly LAI : Aripiprazole | 1
Paliperidone Monthly LAI : Paliperidone 3-month LAI | 1
Paliperidone Monthly LAI : Risperidone LAI | 4
Quetiapine ER : Risperidone | 1
Quetiapine IR : Clozapine | 2
Quetiapine IR : Olanzapine | 9
Quetiapine IR : Risperidone | 14
Quetiapine IR : Risperidone LAI | 1
Risperidone : Olanzapine | 16
Risperidone LAI : Risperidone | 1
Ziprasidone : Clozapine | 1
Ziprasidone : Olanzapine | 9
Ziprasidone : Quetiapine IR | 5
Ziprasidone : Risperidone | 5

Appendix Table G-2c Meta-regression results for withdrawals due to adverse events

Meta-regression variables | OR (95% CI)
Duration | 0.69 (0.36 to 1.19)
Drug dose: Low versus Medium | 1.67 (0.96 to 2.60)
Drug dose: High versus Medium | 1.01 (0.99 to 1.03)
Treatment Resistant | 1.63 (0.72 to 3.26)
First Episode | 0.54 (0.25 to 1.03)

Appendix Table G-3a SGA versus SGA network meta-analysis of discontinuation from study for any cause (odds ratio, 95% confidence interval)

ARI | 1.18 (0.73–1.95) | 0.84 (0.64–1.09) | 0.94 (0.37–2.38) | 0.84 (0.55–1.29) | 1.45 (0.97–2.19) | 0.61 (0.40–0.94) | 0.76 (0.54–1.10) | 1.45 (1.20–1.76) | 0.66 (0.37–1.20) | 0.97 (0.71–1.32) | 0.81 (0.51–1.34) | 0.88 (0.45–1.82) | 2.16 (0.77–6.15) | 0.76 (0.61–0.95) | 0.99 (0.82–1.20) | 1.02 (0.70–1.50) | 0.84 (0.67–1.07)
0.85 (0.51–1.37) | ARI LAI-1 | 0.71 (0.41–1.23) | 0.80 (0.27–2.25) | 0.71 (0.38–1.31) | 1.23 (0.79–1.93) | 0.52 (0.28–0.98) | 0.65 (0.36–1.17) | 1.23 (0.72–2.10) | 0.56 (0.26–1.17) | 0.82 (0.45–1.47) | 0.69 (0.43–1.09) | 0.75 (0.37–1.44) | 1.83 (0.61–5.84) | 0.65 (0.38–1.08) | 0.84 (0.50–1.39) | 0.87 (0.47–1.55) | 0.72 (0.42–1.21)
1.19 (0.92–1.57) | 1.41 (0.81–2.44) | ASE | 1.12 (0.42–2.94) | 1.00 (0.64–1.56) | 1.73 (1.15–2.63) | 0.73 (0.46–1.14) | 0.91 (0.62–1.32) | 1.73 (1.37–2.19) | 0.79 (0.43–1.43) | 1.15 (0.81–1.64) | 0.97 (0.57–1.63) | 1.06 (0.51–2.17) | 2.56 (0.90–7.47) | 0.91 (0.69–1.19) | 1.18 (0.92–1.51) | 1.23 (0.78–1.85) | 1.00 (0.76–1.33)
1.06 (0.42–2.74) | 1.25 (0.44–3.77) | 0.89 (0.34–2.41) | BRE | 0.90 (0.32–2.57) | 1.55 (0.57–4.38) | 0.65 (0.23–1.80) | 0.81 (0.30–2.27) | 1.54 (0.60–4.02) | 0.71 (0.23–2.14) | 1.03 (0.40–2.75) | 0.86 (0.31–2.52) | 0.94 (0.31–3.10) | 2.29 (0.57–9.56) | 0.81 (0.31–2.11) | 1.05 (0.41–2.73) | 1.08 (0.40–3.03) | 0.89 (0.34–2.37)
1.19 (0.77–1.83) | 1.42 (0.76–2.63) | 1.00 (0.64–1.57) | 1.12 (0.39–3.12) | CAR | 1.72 (1.01–2.93) | 0.73 (0.42–1.25) | 0.91 (0.56–1.48) | 1.73 (1.13–2.69) | 0.79 (0.40–1.53) | 1.15 (0.71–1.90) | 0.97 (0.57–1.71) | 1.06 (0.50–2.24) | 2.56 (0.92–7.72) | 0.91 (0.60–1.37) | 1.18 (0.80–1.75) | 1.22 (0.75–2.01) | 1.00 (0.65–1.58)
0.69 (0.46–1.03) | 0.82 (0.52–1.26) | 0.58 (0.38–0.87) | 0.65 (0.23–1.76) | 0.58 (0.34–0.99) | CLO | 0.42 (0.25–0.70) | 0.53 (0.32–0.84) | 1.00 (0.68–1.45) | 0.46 (0.23–0.90) | 0.67 (0.41–1.07) | 0.56 (0.33–0.92) | 0.61 (0.29–1.24) | 1.49 (0.54–4.52) | 0.53 (0.35–0.78) | 0.69 (0.47–0.98) | 0.71 (0.40–1.24) | 0.58 (0.39–0.84)
1.65 (1.06–2.48) | 1.93 (1.02–3.62) | 1.37 (0.87–2.19) | 1.53 (0.56–4.28) | 1.38 (0.80–2.36) | 2.37 (1.42–4.03) | ILO | 1.25 (0.76–2.04) | 2.38 (1.57–3.60) | 1.09 (0.53–2.20) | 1.59 (0.97–2.61) | 1.34 (0.73–2.46) | 1.44 (0.64–3.25) | 3.53 (1.19–10.58) | 1.25 (0.83–1.88) | 1.63 (1.11–2.34) | 1.68 (0.97–2.90) | 1.38 (0.89–2.13)
1.32 (0.91–1.87) | 1.55 (0.86–2.82) | 1.10 (0.76–1.60) | 1.23 (0.44–3.37) | 1.10 (0.68–1.78) | 1.89 (1.19–3.10) | 0.80 (0.49–1.31) | LUR | 1.91 (1.35–2.67) | 0.86 (0.46–1.67) | 1.27 (0.83–1.94) | 1.06 (0.62–1.89) | 1.16 (0.54–2.53) | 2.81 (1.00–8.57) | 1.00 (0.71–1.40) | 1.30 (0.93–1.79) | 1.34 (0.84–2.15) | 1.10 (0.78–1.54)
0.69 (0.57–0.84) | 0.81 (0.48–1.40) | 0.58 (0.46–0.73) | 0.65 (0.25–1.68) | 0.58 (0.37–0.89) | 1.00 (0.69–1.48) | 0.42 (0.28–0.64) | 0.52 (0.37–0.74) | OLA | 0.46 (0.25–0.84) | 0.67 (0.50–0.89) | 0.56 (0.33–0.96) | 0.60 (0.29–1.31) | 1.49 (0.54–4.29) | 0.53 (0.42–0.65) | 0.68 (0.59–0.79) | 0.71 (0.45–1.09) | 0.58 (0.48–0.71)
1.52 (0.84–2.73) | 1.78 (0.85–3.81) | 1.27 (0.70–2.32) | 1.41 (0.47–4.28) | 1.27 (0.65–2.52) | 2.18 (1.12–4.32) | 0.92 (0.46–1.89) | 1.16 (0.60–2.20) | 2.19 (1.19–3.99) | OLA LAI | 1.47 (0.77–2.75) | 1.23 (0.62–2.47) | 1.34 (0.58–3.11) | 3.28 (1.02–10.80) | 1.16 (0.64–2.04) | 1.50 (0.82–2.66) | 1.55 (0.83–2.91) | 1.27 (0.69–2.31)
1.03 (0.76–1.41) | 1.22 (0.68–2.20) | 0.87 (0.61–1.24) | 0.97 (0.37–2.52) | 0.87 (0.53–1.40) | 1.50 (0.93–2.43) | 0.63 (0.38–1.03) | 0.79 (0.52–1.21) | 1.50 (1.13–2.00) | 0.68 (0.36–1.30) | PAL | 0.84 (0.48–1.48) | 0.91 (0.43–1.99) | 2.24 (0.77–6.63) | 0.79 (0.57–1.08) | 1.02 (0.75–1.39) | 1.06 (0.66–1.67) | 0.87 (0.63–1.20)
1.23 (0.75–1.97) | 1.44 (0.92–2.31) | 1.03 (0.62–1.76) | 1.16 (0.40–3.27) | 1.03 (0.58–1.77) | 1.77 (1.09–3.01) | 0.75 (0.41–1.36) | 0.94 (0.53–1.62) | 1.78 (1.04–3.03) | 0.81 (0.41–1.61) | 1.19 (0.68–2.10) | PAL LAI-1 | 1.09 (0.68–1.72) | 2.66 (0.90–8.31) | 0.94 (0.59–1.50) | 1.22 (0.74–1.99) | 1.26 (0.86–1.80) | 1.04 (0.62–1.73)
1.14 (0.55–2.25) | 1.33 (0.70–2.71) | 0.95 (0.46–1.99) | 1.06 (0.32–3.27) | 0.94 (0.45–2.02) | 1.63 (0.81–3.43) | 0.70 (0.31–1.56) | 0.86 (0.40–1.84) | 1.65 (0.77–3.42) | 0.75 (0.32–1.72) | 1.10 (0.50–2.35) | 0.92 (0.58–1.48) | PAL LAI-3 | 2.45 (0.72–8.27) | 0.87 (0.43–1.72) | 1.13 (0.54–2.27) | 1.16 (0.65–2.06) | 0.95 (0.46–1.95)
0.46 (0.16–1.30) | 0.55 (0.17–1.65) | 0.39 (0.13–1.12) | 0.44 (0.11–1.76) | 0.39 (0.13–1.09) | 0.67 (0.22–1.87) | 0.28 (0.09–0.84) | 0.36 (0.12–1.00) | 0.67 (0.23–1.86) | 0.31 (0.09–0.99) | 0.45 (0.15–1.30) | 0.38 (0.12–1.11) | 0.41 (0.12–1.39) | QUE ER | 0.35 (0.12–0.98) | 0.46 (0.16–1.26) | 0.47 (0.16–1.38) | 0.39 (0.14–1.06)
1.31 (1.05–1.64) | 1.55 (0.93–2.63) | 1.09 (0.84–1.45) | 1.23 (0.48–3.20) | 1.10 (0.73–1.66) | 1.90 (1.28–2.85) | 0.80 (0.53–1.20) | 0.99 (0.71–1.41) | 1.90 (1.54–2.36) | 0.86 (0.49–1.58) | 1.27 (0.92–1.76) | 1.06 (0.67–1.70) | 1.15 (0.58–2.35) | 2.82 (1.02–8.21) | QUE | 1.30 (1.10–1.52) | 1.34 (0.92–1.91) | 1.10 (0.88–1.40)
1.01 (0.83–1.22) | 1.19 (0.72–2.01) | 0.85 (0.66–1.09) | 0.95 (0.37–2.43) | 0.85 (0.57–1.25) | 1.45 (1.02–2.12) | 0.62 (0.43–0.90) | 0.77 (0.56–1.08) | 1.47 (1.26–1.70) | 0.67 (0.38–1.23) | 0.98 (0.72–1.33) | 0.82 (0.50–1.35) | 0.89 (0.44–1.86) | 2.17 (0.80–6.36) | 0.77 (0.66–0.91) | RIS | 1.03 (0.69–1.54) | 0.85 (0.70–1.05)
0.98 (0.67–1.43) | 1.15 (0.65–2.14) | 0.82 (0.54–1.28) | 0.93 (0.33–2.50) | 0.82 (0.50–1.34) | 1.42 (0.81–2.49) | 0.60 (0.34–1.03) | 0.74 (0.47–1.19) | 1.42 (0.92–2.21) | 0.65 (0.34–1.21) | 0.95 (0.60–1.51) | 0.80 (0.56–1.17) | 0.87 (0.49–1.54) | 2.12 (0.72–6.34) | 0.75 (0.53–1.08) | 0.97 (0.65–1.45) | RIS LAI | 0.82 (0.54–1.27)
1.19 (0.94–1.50) | 1.40 (0.83–2.38) | 1.00 (0.76–1.32) | 1.12 (0.42–2.92) | 1.00 (0.64–1.53) | 1.72 (1.19–2.56) | 0.72 (0.47–1.12) | 0.91 (0.65–1.28) | 1.72 (1.41–2.10) | 0.79 (0.43–1.46) | 1.16 (0.83–1.58) | 0.96 (0.58–1.63) | 1.05 (0.51–2.20) | 2.55 (0.94–7.38) | 0.91 (0.72–1.14) | 1.18 (0.95–1.43) | 1.22 (0.79–1.87) | ZIP

Drugs are reported in alphabetical order. Comparisons between treatments should be read from left to right and the estimate in each cell represents comparison between the row-defining treatment and the column-defining treatment. Odds ratios (ORs) higher than 1 favor the column-defining treatment, meaning less withdrawal in the column-defining treatment; and ORs less than 1 favor the row-defining treatment, meaning less withdrawal in the row-defining treatment. For example, the OR for comparing LUR (row-defining treatment) vs. OLA (column-defining treatment) is 1.91 (95% CrI 1.35 to 2.67), which means that LUR has higher odds of withdrawal and the comparison favors OLA, which has less withdrawal. Each comparison is represented twice in the table, for example, for two treatments A and B, once with A versus B and once with B versus A (i.e. the reciprocal OR). For the example above, the OR for comparing OLA (now the row-defining treatment) vs. LUR (now the column-defining treatment) is 0.52 (95% CrI 0.37 to 0.74), which means that OLA has a lower odds of withdrawal and again, it means that the comparison favors OLA, which has less withdrawal. Significant results are in bold. ARI = aripiprazole- ASE = asenapine- BRE = brepiprazole- CAR = cariprazine- CLO=clozapine- ILO = iloperidone- LUR = lurasidone- OLA = olanzapine. PAL=paliperidone, QUE=quetiapine, RIS=risperidone- ZIP=ziprasidone. LAI = long-acting injection; 1 = once monthly- 3 – every 3 months.

Appendix Table G-3b SGA versus SGA: numbers of studies per comparison contributing to network meta-analysis of discontinuation for any cause

Comparison | No. of studies
Aripiprazole : Brexipiprazole | 1
Aripiprazole : Olanzapine | 9
Aripiprazole : Quetiapine IR | 3
Aripiprazole : Risperidone | 6
Aripiprazole : Risperidone LAI | 1
Aripiprazole : Ziprasidone | 3
Aripiprazole Monthly LAI : Aripiprazole | 2
A--senapine : Olanzapine | 6
Asenapine : Risperidone | 1
Cariprazine : Risperidone | 1
Clozapine : Olanzapine | 10
Clozapine : Risperidone | 9
Iloperidone : Risperidone | 2
Lurasidone : Olanzapine | 1
Lurasidone : Risperidone | 1
Lurasidone : Ziprasidone | 1
Olanzapine LAI : Olanzapine | 1
Paliperidone : Aripiprazole | 2
Paliperidone : Olanzapine | 3
Paliperidone : Risperidone | 1
Paliperidone : Ziprasidone | 1
Paliperidone Monthly LAI : Aripiprazole | 1
Paliperidone Monthly LAI : Paliperidone | 1
Paliperidone Monthly LAI : Risperidone | 4
Quetiapine ER : Risperidone | 1
Quetiapine IR : Clozapine | 2
Quetiapine IR : Olanzapine | 17
Quetiapine IR : Risperidone | 19
Quetiapine IR : Risperidone LAI | 1
Risperidone : Olanzapine | 31
Risperidone LAI : Risperidone | 1
Ziprasidone : Clozapine | 1
--Ziprasidone : Olanzapine | 10
Ziprasidone : Quetiapine IR | 5
Ziprasidone : Risperidone | 5

Appendix Table G-3c SGA versus SGA: meta-regression results for discontinuations for any cause

Meta-regression variables | OR (95% CI)
Duration | 1.14 (0.82 to 1.55)
Drug dose: Low versus Medium | 1.13 (0.84 to 1.48)
Drug dose: High versus Medium | 1.00 (0.99 to 1.01)
Treatment Resistant | 1.47 (0.93 to 2.25)
First Episode | 0.78 (0.58 to 1.02)

Appendix Figure G-4 Haloperidol versus aripiprazole withdrawals due to adverse events

Appendix Figure G-4 is a forest plot. Risk ratios were reported or calculated for 8 studies, with a pooled risk ratio of 1.25 (95% confidence interval 1.07 to 1.47) and an overall I-squared value of 0%.

Appendix Figure G-5 Haloperidol versus olanzapine withdrawals due to adverse events

Appendix Figure G-5 is a forest plot. Risk ratios were reported or calculated for 24 studies, with a pooled risk ratio of 1.89 (95% confidence interval 1.57 to 2.27) and an overall I-squared value of 0%.

Appendix Figure G-6 Haloperidol versus risperidone withdrawals due to adverse events

Appendix Figure G-6 is a forest plot. Risk ratios were reported or calculated for 25 studies, with a pooled risk ratio of 1.32 (95% confidence interval 1.09 to 1.60) and an overall I-squared value of 0%.

Appendix Figure G-7 Haloperidol versus ziprasidone withdrawals due to adverse events

Appendix Figure G-7 is a forest plot. Risk ratios were reported or calculated for 7 studies, with a pooled risk ratio of 1.68 (95% confidence interval 1.26 to 2.23) and an overall I-squared value of 0%.

Appendix Figure G-8 Haloperidol versus quetiapine withdrawals due to adverse events

Appendix Figure G-8 is a forest plot. Risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 1.97 (95% confidence interval 0.96 to 4.01) and an overall I-squared value of 64%.

Appendix Figure G-9 Assertive community treatment: unable to live independently

Appendix Figure G-9 is a forest plot. Risk ratios were reported or calculated for 4 studies, with a pooled risk ratio of 0.52 (95% confidence interval 0.35 to 0.79) and an overall I-squared value of 0%.

Appendix Figure G-10 Assertive community treatment versus usual care: homelessness

Appendix Figure G-10 is a forest plot. Risk ratios were reported or calculated for 4 studies, with a pooled risk ratio of 0.20 (95% confidence interval 0.09 to 0.47) and an overall I-squared value of 41%.

Appendix Figure G-11 Assertive community treatment: unemployment

Appendix Figure G-11 is a forest plot. Risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.46 (95% confidence interval 0.21 to 0.99) and an overall I-squared value of 72%.

Appendix Figure G-12 Assertive community treatment: loss to followup

Appendix Figure G-12 is a forest plot. Risk ratios were reported or calculated for 12 studies, with a pooled risk ratio of 0.51 (95% confidence interval 0.41 to 0.63) and an overall I-squared value of 0%.

Appendix Figure G-13 Cognitive behavioral therapy: short-term function

Appendix Figure G-13 is a set of forest plots. For the first plot risk ratios were reported or calculated for 5 studies, with a pooled risk ratio of 5.35 (95% confidence interval 1.05 to 9.65) and an overall I-squared value of 77%. For the second plot ratios were reported or calculated for 2 studies, with a pooled risk ratio of 9.11 (95% confidence interval 6.31 to 11.91) and an overall I-squared value of 0%.

Appendix Figure G-14 Cognitive behavioral therapy: treatment maintenance

Appendix Figure G-14 is a forest plot. Risk ratios were reported or calculated for 12 studies, with a pooled risk ratio of 1.02 (95% confidence interval 0.95 to 1.10) and an overall I-squared value of 66%.

Appendix Figure G-15 Cognitive behavioral therapy: relapse

Appendix Figure G-15 is a forest plot. Risk ratios were reported or calculated for 5 studies, with a pooled risk ratio of 0.93 (95% confidence interval 0.61 to 1.42) and an overall I-squared value of 73%.

Appendix Figure G-16 Family interventions: unemployment

Appendix Figure G-16 is a forest plot. Risk ratios were reported or calculated for 4 studies, with a pooled risk ratio of 1.09 (95% confidence interval 0.91 to 1.29) and an overall I-squared value of 0.0%.

Appendix Figure G-17 Family interventions: suicide

Appendix Figure G-17 is a forest plot. Risk ratios were reported or calculated for 6 studies, with a pooled risk ratio of 0.85 (95% confidence interval 0.24 to 3.02) and an overall I-squared value of 23.4%.

Appendix Figure G-18 Family interventions: core illness symptoms

Appendix Figure G-18 is a forest plot. Risk ratios were reported or calculated for 4 studies, with a pooled risk ratio of -0.46 (95% confidence interval -0.73 to 0.20) and an overall I-squared value of 0.0%.

Appendix Figure G-19 Family interventions: negative symptoms

Appendix Figure G-19 is a forest plot. Risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of -0.38 (95% confidence interval -0.69 to -0.07) and an overall I-squared value of 0.0%.

Appendix Figure G-20 Family interventions: treatment maintenance at 3–6 months

Appendix Figure G-20 is a forest plot. Risk ratios were reported or calculated for 6 studies, with a pooled risk ratio of 0.86 (95% confidence interval 0.51 to 1.45) and an overall I-squared value of 18.6%.

Appendix Figure G-21 Family interventions: treatment maintenance at 7–12 months

Appendix Figure G-21 is a forest plot. Risk ratios were reported or calculated for 13 studies, with a pooled risk ratio of 0.77 (95% confidence interval 0.64 to 0.93) and an overall I-squared value of 0.0%.

Appendix Figure G-22 Family Interventions: relapse at 0–6 months by number of sessions

Appendix Figure G-22 is a forest plot. Risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.62 (95% confidence interval 0.41 to 0.92) and an overall I-squared value of 0.0%.

Appendix Figure G-23 Family interventions: relapse at 7–12 months by number of sessions

Appendix Figure G-23 is a forest plot. Risk ratios were reported or calculated for 19 studies, with a pooled risk ratio of 0.67 (95% confidence interval 0.54 to 0.83) and an overall I-squared value of 40.6%.

Appendix Figure G-24 Family interventions: relapse at 7–12 months by duration of intervention

Appendix Figure G-24 is a forest plot. Risk ratios were reported or calculated for 19 studies, with a pooled risk ratio of 0.67 (95% confidence interval 0.53 to 0.83) and an overall I-squared value of 40.6%.

Appendix Figure G-25 Family interventions: relapse at 7–12 months by psychoeducation

Appendix Figure G-25 is a forest plot. Risk ratios were reported or calculated for 19 studies, with a pooled risk ratio of 0.67 (95% confidence interval 0.54 to 0.83) and an overall I-squared value of 40.6%.

Appendix Figure G-26 Family interventions: relapse at 13–18 months by number of sessions

Appendix Figure G-26 is a forest plot. Risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 0.75 (95% confidence interval 0.58 to 0.99) and an overall I-squared value of 57.7%.

Appendix Figure G-27 Family interventions; relapse at 13–24 months by duration of intervention

Appendix Figure G-26 is a forest plot. Risk ratios were reported or calculated for 9 studies, with a pooled risk ratio of 0.75 (95% confidence interval 0.58 to 0.99) and an overall I-squared value of 57.7%.

Appendix Figure G-28 Family interventions: relapse at 25–36 months by duration of intervention

Appendix Figure G-28 is a forest plot. Risk ratios were reported or calculated for 2 studies, with a pooled risk ratio of 1.05 (95% confidence interval 0.79 to 1.39) and an overall I-squared value of 45.5%.

Appendix Figure G-29 Family interventions: relapse at 5 years by duration of intervention

Appendix Figure G-29 is a forest plot. Risk ratios were reported or calculated for 2 studies, with a pooled risk ratio of 0.82 (95% confidence interval 0.72 to 0.94) and an overall I-squared value of 0.0%.

Appendix Figure G-30 Family interventions: nonsuicide mortality

Appendix Figure G-30 is a forest plot. Risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.96 (95% confidence interval 0.17 to 5.33) and an overall I-squared value of 0.0%.

Appendix Figure G-31 Family interventions: poor compliance with medication

Appendix Figure G-31 is a forest plot. Risk ratios were reported or calculated for 6 studies, with a pooled risk ratio of 0.78 (95% confidence interval 0.65 to 0.92) and an overall I-squared value of 0.0%.

Appendix Figure G-32 Intensive case management: loss to followup

Appendix Figure G-32 is a forest plot. Risk ratios were reported or calculated for 8 studies, with a pooled risk ratio of 0.71 (95% confidence interval 0.54 to 0.95) and an overall I-squared value of 11%.