# Appendix F Quality Assessment

Appendix Table F-1 Quality assessment of systematic reviews of pharmacological treatments

Author, Year | 1. Was an “a priori” design provided? | 2. Was there duplicate study selection and data extraction? | 3. Was a comprehensive literature search performed? | 4. Was the status of publication (i.e. grey literature) used as an inclusion criterion? | 5. Was a list of studies (included and excluded) provided? | 6. Were the characteristics of the included studies provided? | 7. Was the scientific quality of the included studies assessed and documented? | 8. Was the scientific quality of the included studies used appropriately in formulating conclusions? | 9. Were the methods used to combine the findings of studies appropriate? | 10. Was the likelihood of publication bias assessed? | 11. Was the conflict of interest included? | Quality Rating
Abou-Setta 2012 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
DERP SGA systematic review, 2013 (Update 4) | Yes | Yes Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not applicable due to number of poolable studies | Yes for report authors No for individual studies in this update, but they are likely mostly industry funded | Good

Please see Appendix B. Included Studies for full study references

Appendix Table F-2 Quality assessment of randomized controlled trials of pharmacological treatments

Author, Year Study Name | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Outcome assessors blinded? | Clinician blinded? | Patient blinded? | Intention to treat? | Acceptable level of overall attrition (≤30%)? | Acceptable level of differential attrition (<10%)? | Overall Quality
Amr, 2013 | Yes | Yes | Yes | No (clinicians were one of the raters) | No | Yes | No | No 73/156 = 47% | No 55% quetiapine, 39% haloperidol | Poor
Citrome, 2016 | Unclear | Yes Interactive response system | Yes, though comorbidity NR | No (raters aware) | No (open-label) | No | Yes (none excluded) | No 37% | Yes (38% vs. 36%) | Fair
Crespo-Faccoro 2011 | Yes | Unclear | No Not schizophrenia diagnosis | No | No | No | Yes | Yes | Yes | Fair
Detke, 2014 | Unclear | Unclear | Yes Age, sex, age at onset, length of current episode, and baseline severity all similar | Unclear | No (open-label) | No | Yes | No 52.5% | Yes | Poor
Di Fiorino, 2014 | Yes | Yes | Unclear | No | No | No | Yes | Yes (25%) | Yes 17% vs. 25% | Fair
Durgam, 2014 | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | No Excluding placebo arm, 193/578 = 33% discontinued | Yes Excluding placebo, range 27.9 to 37.9% | Fair
Fleischhacker, 2014 ASPIRE EU | Unclear | Unclear | Yes | Unclear Dosing adjustments allowed - no explanation given for how conducted to maintain blinding | Unclear Dosing adjustments allowed - no explanation given for how conducted to maintain blinding | Yes | Yes | No 157/531 = 30% | Yes 26% vs. 33% | Fair
Green, 2015 | Yes | Unclear | Yes | Yes | Yes | No | Yes | Yes | Yes | Fair
Ishigooka, 2015 ALPHA | Yes | Yes | Unclear Gender, age, baseline severity similar, but duration of illness 163 vs. 140 months | Unclear Dosing adjustments allowed - no explanation given for how conducted to maintain blinding | Unclear Dosing adjustments allowed - no explanation given for how conducted to maintain blinding | Yes | Yes | No 135/455 = 30% | Yes 26% to 33% | Fair
Koshikawa, 2016 | Yes Computer-generated | Unclear | Unclear Reported only for the 70% of participants completing the study | No Open-label | No Open-label | No Open-label | No 9/30 (30%) excluded | Yes 30% | Yes 29% vs. 31% | Fair
Li, 2014 | Unclear Only described as randomized | Unclear “Assigned sequentially in ascending order” | Yes | Yes Double-dummy | Yes Double-dummy | Yes Double-dummy | Yes None excluded | Yes 41/279 = 15% | Yes 17% vs. 12% | Fair
Lieberman 2005 (CATIE Study) | Yes | Yes “Done under DB conditions” | Few minor differences | Yes | Yes | Yes | Yes | No | No | Good
Liu, 2014 | Yes | Unclear | Unclear Age and baseline PANSS similar but duration of illness 4.5 vs. 5.5 months | No | No | No | Yes | Yes | Yes | Fair
Maat, 2014 | Unclear Only described as randomized | Unclear | Yes | No Open-label | No Open-label | No Open-label | No 36/80 = 45% excluded | No 40% discontinued | No 47.4% vs. 33.3% | Poor
McEvoy, 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No 130/311 = 42% | Yes | Good
Naber, 2013 RECOVER | Unclear | Yes IVRS | Mostly yes | No | No | No | Yes With LOCF | No 45% | Yes | Fair
Naber, 2015 QUALIFY | Yes Stratified randomization | Unclear | Unclear Age, age at onset, and gender similar, but baseline severity not reported for all patients randomized (9% excluded) | Yes for QLS and IAQ but not for other assessments | No | No | No | No 112/295 = 38% | No 32% vs. 44% | Fair
Nemeth, 2017 | Yes | Yes | Yes | Yes | Unclear | Yes | Yes (99% in each group) | Yes (23% in each group) | Yes | Good
Parabiaghi, 2016 GiSAS | Yes Computer-generated, stratified, block | Yes Central with IVRS | Yes Mostly similar though some baseline data incomplete | Yes Outcome assessment and data analysis blinded | No Open-label | No Open-label | Yes None excluded, both LOCF and multiple imputation used | No 86/200 = 43% | No 53% vs. 33% | Fair
Park, 2013 | Yes Stratified randomization | Unclear | Unclear PANSS 67.5 vs. 82.0 (small sample, N=20) | No Open-label | No Open-label | No Open-label | Unclear Followup and N’s analyzed NR | Unclear Followup NR | Unclear | Poor
Robinson, 2015 | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes Mixed models | No 93/209 = 44% | Yes | Fair
San, 2012 | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Good
Sanz-Fuentenebro, 2013 | No (alternating assignment) | No | Some differences: 60% vs. 80% male and duration of active psychosis 7.5 months vs. 12.3 months | Unclear | No | No | Yes with LOCF | No (53.3%) | No (20% vs. 47%) | Poor
Savitz, 2016 | Yes (computer-generated) | Yes (IWRS) | Yes, though comorbidity NR | Unclear | Yes (double dummy) | Yes (double dummy) | Yes (2.1% excluded from mITT set in double-blind phase) | Yes (17%) | Yes (16% vs. 18%) | Good
Shoja Shafti, 2015 | Unclear Only described as randomized | Unclear | Yes | Yes | Yes | Yes | Unclear Followup and N’s analyzed NR | Unclear Overall withdrawals NR | Unclear | Fair
Subotnik, 2015 | Unclear | Unclear | Unclear Age, sex, % schizoaffective and baseline symptoms similar but time since onset 7.9 vs. 6.9 months | No | No | No | Yes | 31% | No 25% vs 37% | Fair
Tybura, 2013 | Unclear | Unclear | Unclear Age and baseline PANSS similar, but no other baseline characteristics reported | No Open-label | No Open-label | No Open-label | Yes Tables show N’s at baseline and 3 months as the same | Yes Tables show N’s at baseline and 3 months as the same | Yes Tables show N’s at baseline and 3 months as the same | Poor
Tybura, 2014 | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes 36/131 = 27% discontinued (SGAs only) | Yes 32% vs. 24% | Fair
Wani, 2015 | Unclear Only described as randomized | Unclear | Yes | No Open-label | No Open-label | No Open-label | Unclear States that LOCF but gives N’s analyzed at 24 weeks as those continuing treatment (Fig 1; excludes 24%) | Yes 15/62 = 24% | No 16% vs. 32% | Fair

Please see Appendix B. Included Studies for full study references

CATIE=clinical Antipsychotic Trials of Intervention Effectiveness, DB=data base, EU=European Union, EUFEST=The European First Episode Schizophrenia Trial, IAQ=interviewer-administered questionnaires, IVRS=inverted repeats, IWRS=interactive web response system, LOCF=last observation carried forward, mITT=modified intention to treat, PANSS=Positive and Negative Syndrome Scale, QLS=quality of life scale, SGA=second-generation antipsychotics

Appendix Table F-3 Quality assessment of systematic reviews of psychosocial and nonpharmacological treatments

Author, Year | 1. Was an “a priori” design provided? | 2. Was there duplicate study selection and data extraction? | 3. Was a comprehensive literature search performed? | 4. Was the status of publication used as an inclusion criterion (i.e. was grey literature included)? | 5. Was a list of studies (included and excluded) provided? | 6. Were the characteristics of the included studies provided? | 7. Was the scientific quality of the included studies assessed and documented? | 8. Was the scientific quality of the included studies used appropriately in formulating conclusions? | 9. Were the methods used to combine the findings of studies appropriate? | 10. Was the likelihood of publication bias assessed? | 11. Was the conflict of interest included? | Quality Rating
Assertive community treatment
Marshall 2000a | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | Yes | Good
Cognitive-behavioral therapy
Jauhar 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Jones 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Velthorst 2015 | Yes | Unclear | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Good
Cognitive remediation
Cella 2017 | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | Yes | Good
Wykes 2011 | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Good
Family interventions
Pharoah 2010 | Yes | Yes Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Intensive case management
Marshall 2000b | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | Yes | Good
Illness self-management
Zou, 2012 | Yes | Yes | Yes | Unclear | No | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Psychoeducation
Pekkala 2009 | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
Substance use and schizophrenia
Hunt, 2013 | Yes | Yes Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Good
Supported employment
Kinoshita, 2013 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Supportive therapy
Buckley, 2015 | Yes | Yes Yes | Yes | No | Yes | Yes | Yes | Unclear | Yes | No | Yes | Good

Please see Appendix B. Included Studies for full study references

ACT=assertive community treatment, ICM=intensive case management

Appendix Table F-4 Quality assessment of randomized controlled trials of psychosocial and nonpharmacological treatments

Author, Year Study name | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Outcome assessors blinded? | Intention to treat? | Acceptable level of overall attrition (≤30%)? | Acceptable level of differential attrition (<10%)? | Overall Quality
Assertive community Treatment
Sytema, 2007 | Yes | Unclear | Yes | Unclear | Yes | No | No | Fair
Cognitive-behavioral Therapy
Freeman 2015 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Lysaker 2009 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Fair
Malik 2009 | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Fair
Velligan 2015b | Yes | Unclear | Yes | Yes | Unclear | Yes | Unclear | Fair
Zimmer 2007 | Yes | Unclear | Yes | Yes | No | Yes | Yes | Fair
Cognitive remediation
Farreny 2012 | Yes | Unclear | Yes | Unclear | No | Yes | Yes | Fair
Mueller 2015 | Yes | Unclear | Yes | Yes | No | Yes | Yes | Fair
Twamley 2012 | Unclear | Unclear | No | Yes | Yes | Yes | Yes | Fair
Vita 2011 and Deste 2015 | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Good
Early intervention for patients with first-episode psychosis
ETP-RAISE trial Kane 2015 and Kane 2016 | Unclear | Unclear | No | Yes | Unclear | Unclear | Unclear | Poor
Guo 2007 and Guo 2010 | Unclear | Unclear | Yes | Yes | Yes | No | No | Fair
LEO trial Craig 2004, Garety 2006 | Yes | Yes | No | Yes | Yes | Yes | Yes | Good
LEO trial Tempier, 2012 | Yes | Yes | No | Yes | Yes | No | No | Fair
OPUS trial Secher 2015, Bertelsen 2009 | Yes | Yes | Yes | Yes | Yes | No | Yes | Good
Family interventions
Dyck 2000 | Unclear | Unclear | Yes | Unclear | No | No | Yes | Poor
Garety 2008 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Kopelowicz 2012 | Yes | Unclear | Yes | Unclear | Yes | No | No, 27%, 37%, and 51% | Poor
Mayoral, 2015 | Unclear | Unclear | Yes | Yes | Unclear; likely no | Yes | Yes | Fair
Sellwood 2001 | Yes | Unclear | Unclear | Yes | Unclear | Yes | Yes | Fair
Valencia 2007 | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Fair
Intensive case Management
Bjorkman, 2002 | Yes | Unclear | No | Unclear | Yes | Yes | No | Fair
Illness self-management and recovery
Hasson-Ohayon, 2007 | Yes | Unclear | Yes | Unclear | Unclear | Yes | Unclear | Fair
Social skills training
Mueser 2010 and Bartels 2014 | Yes | Unclear | No | Yes | No | Yes | Yes | Fair
Valencia 2007 | Unclear | Unclear | Yes | Yes | No | Yes | Yes | Fair
Valencia 2013 | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Fair
Supported employment
Cook, 2008, 2005 | Yes, for entire study population; data not reported for schizophrenia subgroup | Unclear | Yes, for entire study population; data not reported for schizophrenia subgroup (Numerous baseline differences were found between those with schizophrenia and those with other diagnoses) | Unclear | Unclear | Yes, for entire study population; data not reported for schizophrenia subgroup | Yes, for entire study population; data not reported for schizophrenia subgroup | Fair
Mueser, 2004 | Unclear | Unclear | Yes | No | Yes | Yes | Yes | Fair

Please see Appendix B. Included Studies for full study references