# Appendix E Data Abstraction

Appendix Table E-1 Data abstraction of systematic reviews of pharmacological interventions

Appendix Table E-2 Data abstraction of randomized controlled trials of pharmacological interventions

Appendix Table E-3 Data abstraction of systematic reviews of assertive community treatment

Appendix Table E-4 Data abstraction of randomized controlled trial of assertive community treatment

Appendix Table E-5 Data abstraction of randomized controlled trials of cognitive adaptation training*

Appendix Table E-6 Data abstraction of systematic reviews of cognitive-behavioral therapy

Appendix Table E-7 Data abstraction of randomized controlled trials of cognitive-behavioral therapy

Appendix Table E-8 Data abstraction of systematic reviews of cognitive remediation therapy

Appendix Table E-9 Data abstraction of randomized controlled trials of cognitive remediation therapy

Appendix Table E-10 Data abstraction of systematic reviews of family interventions

Appendix Table E-11 Data abstraction of randomized controlled trials of family interventions

Appendix Table E-12 Descriptions of family interventions in randomized controlled trials with relapse as an outcome

Appendix Table E-13 Data abstraction of systematic reviews of intensive case management

Appendix Table E-14 Data abstraction of randomized controlled trials of intensive case management

Appendix Table E-15 Data abstraction of systematic reviews of illness self-management and recovery

Appendix Table E-16 Data abstraction of randomized controlled trials of illness self-management and recovery

Appendix Table E-17 Data abstraction of systematic reviews of psychoeducation

Appendix Table E-18 Data abstraction of randomized controlled trials of social skills training

Appendix Table E-19 Data abstraction of randomized controlled trials of supported employment

Appendix Table E-20 Data abstraction of systematic reviews of supported employment

Appendix Table E-21 Data abstraction of systematic reviews in trials of supportive therapy

Appendix Table E-22 Data abstraction of randomized controlled trials of early interventions for patients with first-episode psychosis

Appendix Table E-23 Data abstraction of systematic reviews of co-occurring substance use and schizophrenia