# Appendix D Scale Abbreviations and Scoring

Abbreviation | Measure | Scale | Direction
ABS | Agitated Behavior Scale | 15 to 56 | Higher score=more dangerous behavior
ACES | Agitation-Calmness Scale | 1 to 9 | Higher score=calmer
ADL | Activities of Daily Living | 0 to 6 | Higher score=greater independence in daily living
AIMS | Abnormal Involuntary Movement Scale | 0 to 4 | Higher score=greater severity of tardive dyskinesia
ASEX | Arizona Sexual Experiences Scale | 5 to 30 | Higher score=greater sexual dysfunction
BARS | Barnes Akathisia Rating Scale | 0 to 9 | Higher score=greater severity of akathisia
BPRS | Brief Psychiatric Rating Scale | 16 to 112 | Higher score=more severe symptoms
C-SSRS | Columbia Suicide Severity Rating Scale | 2 to 25 | Higher score=greater suicide ideation severity
CABS | Corrigan Agitated Behavior Scale | 14 to 56 | Higher score=more dangerous behavior
CDSS | Calgary Depression Rating Scale for Schizophrenia | 0 to 27 | Higher score=worse depression
CES | Coping Efficacy Scale | 1 to 5 | Higher score=more effective coping
CGI | Clinical Global Impression | 1 to 7 | Higher score=more severe illness
CGI-I | Clinical Global Impression – Improvement | 1 to 7 | Higher score=higher degree of mental illness relative to other patients with the same diagnosis
CGI-S | Clinical Global Impression-Severity | 1 to 7 | Higher score=higher degree of mental illness
CHOICE | CHoice of Outcome in Cbt for psychosEs | 0 to 210 | Higher score=more satisfied and better
DIEPSS | Drug-Induced Extrapyramidal Symptoms Scale | 0 to 36 | Higher score=more severe symptoms
GAF | Global Assessment of Function | 1 to 100 | Higher score=better functioning
GAS | Goal Attainment Scaling | −2 to +2 | Higher score=higher goal attainment
GPTS | Green Paranoid Thoughts Scale | 32 to 160 | Higher score=more paranoid thoughts
Heinrich’s | Heinrichs-Carpenter Quality of Life Scale | 0 to 126 | Higher score=greater mental health
HoNDS | Health of the Nation Outcomes Scales | 0 to 48 | Higher score=more severe outcomes of mental illness
ILSS | Independent Living Skills Survey | 0 to 70 | Higher score=better functioning
ISSI | Interview Schedule for Social Interaction | 0 to 30 | Higher score=better social integration and attachment
ITAQ | Insight and Treatment Attitudes Questionairre | 0 to 22 | Higher score=more complete insight
LOS | Strauss-Carpenter Level of Function Scale | 0 to 36 | Higher score=more functionality
LQLP or LQOLP | Lancashire Quality of Life Profile | 105 to 735 | Higher score=higher quality of life
LSP | Life Skills Profile | 39 to 156 | Higher score =higher levels of life skills
LUNSERS | Liverpool University Neuroleptic Side Effect Rating Scale | 0 to 204 | Higher score=worse neuroleptic side effects
MANSA | Manchester Short Assessment of Quality of Life | 16 to 112 | Higher score=higher quality of life
MASC | Maryland Assessment of Social Competence | 12 to 60 | Higher score=better social skills
MCAS | Multnomah Community Ability Scale | 17 to 85 | Higher score=better functioning
MOAS | Modified Overt Aggression Scale | 0 to 40 | Higher score=higher frequency of aggressive behaviors
PANSS | Positive and Negative Syndromes Scale | 30 to 210 | Higher score=more severe symptoms
PSP | Personal and Social Performance Scale | 0 to 100 | Higher score=better personal and social functioning
PSR Toolkit | Psychosocial Rehabilitation Toolkit | 0 to 5 | Higher score=better functioning
PSWQ | Penn State Worry Questionairre | 16 to 18 | Higher score=more worry
PSYRATS | The Psychotic Symptom Rating Scales | 0 to 70 | Higher score=more severe psychotic symptoms
PTQ | Perservative Thinking Questionaire | 0 to 60 | Higher score=higher levels of repetitive thought
QLS | Quality of Life Scale | 0 to 126 | Higher score=better functioning
QOLI | Quality of Life Interview | 143 to 1001 | Higher score=better quality of life
R-SES | Revised Self-efficacy Scale | 0 to 100 | Higher score=higher self-efficacy
RFS | Role Functioning Scale | 4 to 28 | Higher score=more optimal functioning
SADS-C | Schedule for Affective Disorders and Schizophrenia - Change | 75 to 406 | Higher score=more severe symptoms
SAI | Scale for the Assessment of Insight Expanded | 0 to 24 | Higher score=better insight
SANS | Scale for Assessment of Negative Symptoms | 0 to 130 | Higher score=more severe negative symptoms
SAS or SAS-II | Social Adjustment Scale | 0 to 125 | Higher score=better functioning
SAPS | Scale for the Assessment of Positive Symptoms | 0 to 175 | Higher score=more severe positive symptoms
SBS | Social Behavior Survey | 0 to 84 | Higher score=worse social function
SCL or SCL-90-R | Symptom Checklist-90-Revised | 30 to 80 | Higher score=more symptom severity
SF-36 | 36-Item Short Form health Survey | 0 to 100 | Higher score=more favorable health state
SFS | Social Functioning Scale | 40 to 160 | Higher score=greater social function
SOFAS | Social and Occupational Functioning Assessment Scale | 1 to 100 | Higher score=more impairment
SWBUNS | Subjective Well-being Under Narcoleptics Scale | 20 to 120 | Higher score=higher wellbeing
UPSA | UCSD Performance-based Skills Assessment | 0 to 100 | Higher score=higher levels of functioning
WBI | Work Behavior Inventory | 35 to 175 | Higher score=better work behavior
WEMWEBS | Warwick-Edinburgh Mental Wellbeing Scale | 14 to 70 | Higher score=higher wellbeing
WHOQOL-BREF | World Health Organization Brief Quality of Life Assessment Instrument | 32 to 160 | Higher score=better quality of life
YMRS | Young Mania Rating Scale | 0 to 60 | Higher score=greater severity of manic symptoms